# Methods

## Methods for the Systematic Review

### Literature Search

The research librarian, in collaboration with the TEP (Technical Expert Panel), identified appropriate electronic databases and developed search strategies tailored to the specific database. The search strategies were based on variations of the following keywords and subject headings: “toilet training,” “potty training,” and a combination of “toilet” or “potty” with “learning,” “conditioning,” “teaching,” “educating,” and “behaviors.”

The search strategies were used to search the following electronic databases: MEDLINE^®^, Ovid MEDLINE^®^ In-Process & Other Non-Indexed Citations, Ovid OLDMEDLINE^®^, Cochrane Central Register of Controlled Trials (which contains the Cochrane Developmental, Psychosocial and Learning Problems Group's specialized register of trials and the Cochrane Incontinence Group's specialized register of trials; these groups hand search journals pertinent to their content areas and add relevant trials), EMBASE, CINAHL^®^, PsycINFO^®^, ERIC^®^ (Educational Resources Information Center), EBM Reviews (Cochrane Database of Systematic Reviews, ACP Journal Club, Database of Abstracts of Reviews of Effects), HealthSTAR, AMED (Allied and Complementary Medicine), Web of Science^®^ (Science Citation Index Expanded and Social Sciences Citation Index), Biological Abstracts, Sociological Abstracts, OCLC ProceedingsFirst, OCLC PapersFirst, Dissertation Abstracts, Index to Theses, and the National Research Register's Projects Database. Trials registers (Current Controlled Trials and ClinicalTrials.gov) were searched for trials. Position statements by the American Academy of Pediatrics (Web site at http://www.aap.org/) and the Canadian Paediatric Society (Web site at http://www.cps.ca/) were sought. The NLM Gateway was searched for identification of meeting abstracts. The detailed search strategies appear in Appendix A.^*^

* Appendixes and Evidence Tables are provided electronically at http://www.ahrq.gov/clinic/tp/toilettrtp.htm.

In addition to the above search strategy, annual conference proceedings of the American Academy of Pediatrics and the Canadian Paediatric Society were hand searched for the years 2002-2005 inclusive. Also, reference lists were reviewed. Sentinel articles identified by TEP members were tracked forward using the Cited Reference Search feature in Web of Science^®^.

### Selection and Inclusion

Screening. Once all duplicate references were removed, two reviewers independently screened the electronic search output. The title and when available, the abstract were assessed for possible inclusion using general inclusion criteria (i.e., was it primary research assessing a toilet training method) and classified as “include,” “exclude,” or “unclear.” The full text of all “include” and “unclear” studies was obtained and formally assessed for inclusion.

Inclusion. A priori inclusion criteria were developed (Table 3) and the studies were assessed for inclusion using a standardized form (Appendix B). Two reviewers independently applied the inclusion criteria and all discrepancies were resolved through discussion or consulting with a pediatrician and a pediatric urologist.

Table 3 Inclusion and exclusion criteria for review on the effectiveness of different methods for bladder and bowel control*

Criterion | Toilet Training Review
Study Design | Include: RCT, CCT, prospective or retrospective cohort, case-control, cross-sectional or case-series of at least 5 children.
| Exclude: case studies or case-series of <5 children.
Participants | Include: infants, toddlers, or children with or without co-morbidities, neuromuscular, cognitive, and/or behavioral disabilities.
| Exclude: children with enuresis or encopresis and adults with special needs.
Intervention | One or more of the following methods: Azrin and Foxx method, child-oriented method, operant conditioning, assisted infant toilet training, or any other toilet training program or intervention aimed at achieving bladder and/or bowel control.
Outcome Measures | Bladder control, bowel control, successes, failures/accidents, adverse outcomes (e.g.: enuresis, encopresis, stool withholding).

* RCT indicates randomized controlled trial; CCT, controlled clinical trials

Studies examining the treatment of children with enuresis and/or encopresis were excluded. Although treatment components of enuresis and encopresis are similar to toilet training, it was believed that an enuretic and/or encopretic child would have already experienced at least one method of toilet training. The treatment of enuresis and encopresis was considered to be outside the scope of this review and there are several published systematic reviews that address these topics. Studies that measured the development of enuresis or encopresis as the result of a specific toilet training method were included.

The studies must have been published in English and all study participants had to be children, defined as less than 18 years of age. With the special needs literature, studies have applied toilet training methods to both children and adults. If the pediatric and adult data were presented separately, the study was included. In addition, the exact condition or diagnosis of special needs was not required. For example, studies describing children as “severely retarded” or “profoundly retarded” were included.

A wide spectrum of toilet training programs was included. The study could examine a program specifically designed to toilet train children or, for example, an operant conditioning program that aimed to change several behaviors. The study was included as long as toileting was one of the targeted behaviors and a toileting outcome was measured.

When it appeared that outcomes on the same or a portion of the same cohort of children were reported upon in multiple publications, a primary publication was identified. In general, the largest, most recent publication was assigned as the primary publication. If it was unclear if the studies reported on discrete children, individual investigators were contacted.

### Quality Assessment

Two reviewers independently assessed the methodological quality of the included studies. Any discrepancies were resolved through discussion or consulting a third party as needed. The reviewers, a pediatrician, and a pediatric urologist developed a priori guidelines regarding the interpretation and implementation of the quality tool. If a specific question from the quality assessment tool was not applicable to the study design, the question was answered “no.” When the same cohort of children was examined in multiple publications, the methodological quality was assessed on the primary publication.

The methodological quality of observational studies was assessed using the Downs and Black partially validated “Checklist of the assessment of methodological quality of both randomized and non-randomized studies of health care interventions” (Appendix B *).^47^ This tool comprises six sections that assess reporting (10 questions, total score 11), external validity (three questions, total score three), internal validity-bias (seven questions, total score seven), internal validity-confounding (six questions, total score six), and power (two questions, total score two). A maximum score of 29 indicates the highest methodological quality and a score of zero represents the poorest methodological quality. The funding source of each study was recorded.

The Jadad Scale was used to assess the methodological quality of randomized and non-randomized controlled clinical trials.^48^ The Jadad Scale is a validated five-point scale that examines the methods of randomization, double-blinding, and the reporting of withdrawals and dropouts. In addition, Schultz's definitions of concealment of allocation were applied and each trial was described as “adequate,” “inadequate,” or “unclear.”^49^ The funding source of each study was recorded.

### Data Extraction

The reviewers, a pediatrician and a pediatric urologist, developed and piloted a data extraction form (Appendix B). Data were extracted by one reviewer and checked for accuracy and completeness by a second. All data were entered into SRS 3.0, a web-based software program designed specifically for systematic reviews. Any discrepancies were resolved through consensus or consultation with the co-task leaders as required. To facilitate extracting graphical data points with the greatest accuracy, graphs were scanned into CorelDraw^®^.

Data regarding the study design, toilet training objective (bladder versus bowel and daytime versus nighttime), patient demographics, toilet training interventions, and outcomes were extracted. Children were described as healthy, mentally handicapped, or physically handicapped. Sex, race, culture, socioeconomic status, age of toilet training initiation, and baseline bladder and bowel function were extracted. Chronological age and developmental or social ages or both if reported were also extracted. Developmental or social age refers to a child's specific motor and mental capabilities. The source of the study population was also recorded. Details concerning the toilet training program were documented. The toilet training intervention was classified as Azrin and Foxx, child-oriented, operant conditioning, or other. In situations where the toilet training method was not specifically called one of the specific methods but was similar, it was classified as the specific method. When applicable to the specific toilet training intervention, the frequency of accident checks, and toileting was documented. Information on the length of the program, use of positive or negative reinforcement, external signaling devices, special toilet training equipment, and/or a specific toilet training room was recorded. Any training the parents or caregivers received was also recorded. A number of outcomes were extracted, including change in bladder and bowel function, number of successes and accidents, success and failure rates, time to toilet train, and the occurrence of adverse events (e.g., enuresis, encopresis, stool withholding, etc.). Where possible, results were extracted by effect modifiers, such as age or sex.

### Data Analysis

Due to extreme clinical heterogeneity with respect to study designs, interventions, populations, and outcomes, no statistical meta-analysis was performed. Each study was organized by population (healthy, mentally handicapped, and physically handicapped) and the toilet training program was grouped as Azrin and Foxx (also including modified Azrin and Foxx), child-oriented, operant conditioning, and other. Each study was qualitatively summarized and the vast majority of this summary was taken directly from studies themselves. However, there were a few instances where the authors did not perform a statistical analysis and a Fisher's exact test was used to compute a p-value to compare dichotomous data between two groups.

There were instances when the data were manipulated. When individual data were presented in tabular form, a standard deviation (SD) was calculated. There were situations when the baseline characteristics and outcomes were stratified by age or another variable. When possible, the data were combined by toilet training program using the following formulas:

When applicable, each study was analyzed with respect to its definition of a child being successfully toilet trained and graphical summaries of such information were presented. The studies varied in their definitions of success and we attempted to classify the patients in each study as to whether they were toilet trained, i.e.: a “success.” Definitions considered equivalent to “fully trained” included (among others) self initiated elimination in toilet, daytime continence for bowel and bladder, continued absence of wetting or soiling between toileting, and complete toileting with no prompts. Definitions that were considered partial successes included (among others) one or fewer accidents per month, reduced number of accidental daytime wettings, increased toileting in commode, and less than four bladder and two bowel accidents per week. Only those studies that reported these numbers and had a well-defined intervention were included in the graphs.

Statistical tests were calculated using StatXact (Version 7, Cambridge, USA) while the graphs were produced using S-Plus (Version 7.0, Seattle, USA).

### Peer Review

Fourteen toilet training experts, developmental pediatricians, and methodological experts were asked to peer-review the draft of this evidence report. Nine agreed to do so and six provided comments within the allocated time period. We reviewed all comments and revised this report accordingly. A list of the peer-reviewers appears in Appendix F and is available on the AHRQ Web site.