# Appendix H: Toilet Training Methods

H-1. Child-Oriented Toilet Training Method

H-2. Azrin and Foxx Toilet Training in Less Than a Day Method

H-3. Early Elimination Toilet Training Method

H-4. Dr. Spock's Toilet Training Method

## H-1. Child-Oriented Toilet Training Method

### Objective

To prevent problems for a child in learning bowel and bladder control. Learning this control is a major developmental task and proper timing may enable a child to master the acts for him or herself. Training must proceed slowly to allow for periods of negativity that are common in this age group. If there is a breakdown at any time during training, parents are advised to stop and to reassure the child that he or she is not bad, but will learn when ready.

### Readiness

- Child must be able to sit and walk.
- Child must have some understanding of verbal commands.
- Child displays psychological readiness:
  - has a desire to develop autonomy and self mastery,
  - feels secure with parent figures and has a desire to please them, and
  - has a wish to identify with and imitate important people in the child's life.
- Parents must ready themselves and deal with outside pressures and anxieties about toilet training, aiming for a relaxed, pressure-free approach.

### Method

1 Around 18 months of age, introduce a potty chair as the child's “own chair”. Allow the child to get familiar with it and verbally associate it with the parents' toilet.
2 Daily, have the child sit on the chair fully clothed when the parent uses the toilet. Parents may read or offer treats to the child while he or she sits but allow the child to leave at will.
3 After 1 to 2 weeks cooperation, remove the child's diaper and have him or her sit on the potty. Make no demands nor attempts to catch anything.
4 When the child is comfortable with the potty and eliminates in his or her diaper, take the child to the potty, empty the diaper into it and explain that this is where bowel movements go.
5 If the child appears to understand, take the child to the potty several times a day.
6 As interest grows, remove diapers and pants for short periods, place potty nearby and encourage the child to use it at will and independently. Periodic reminders may be given.
7 If child is progressing then put into training pants and instruct how to raise and lower them.

After bowel control is obtained, boys can learn to urinate while standing by imitating other males. Nap and night training is left until later if it does not occur simultaneously with daytime control.

## H-2. Azrin and Foxx Toilet Training in Less Than a Day Method

### Objective

To teach child to toilet him/herself without reminders or assistance.

Training begins at about 20 months of age. Assess bladder control, physical development and ability to follow instructions to see if child has developed sufficiently to acquire toilet training skills. A child is ready to be trained if he or she:

- has bladder control, that is, the child urinates all at one time (not constant dribbling), stays dry for several hours and appears to know when he or she is about to urinate, e.g., facial expression or posture changes];
- is physically ready, i.e., picks up objects easily and walks without assistance; and
- can follow 10 instructions: point to nose, eyes, mouth, hair, sit on a chair, stand up, walk with parent to another room, imitate simple tasks, fetch a particular object, and place one object inside another.

### Pre-training experiences

- Teach the child to assist in own dressing and undressing, especially raising and lowering pants.
- Allow the child to watch others toilet and explain the steps they are following.
- Teach the toileting words to be used during training.
- Teach the child to cooperate when given instructions; do not allow an instruction of which the child is capable to go unfulfilled; do not allow temper tantrums to discourage progress.

### Training supplies and setup

- Conduct training in one room.
- Eliminate or minimize all interruptions and distractions, e.g., toys.
- Have a ready supply of child's favorite drinks, snacks, and treats.
- Use a potty chair designed so a child can easily remove the pot from the chair and replace it.
- Have a doll that wets to demonstrate to the child the urination process.
- Make up a list of the persons and characters (real or fictional) the child admires to use to praise the child and indicate how pleased they will be to hear of the child's success.
- Have at least eight pairs of training pants large enough for the child to easily lower and raise.
- Have child wear a short T-shirt that will not interfere with lowering and raising training pants. Teach child to grasp pants in the middle of the back, palm facing backward, and mid-front for easier lowering and raising.

### Method

Provide immediate, varied (juices, edibles, treats, hugs, etc.), positive reinforcement at every instance of correct toileting skill, e.g., approaching potty, grasping pants, sitting on potty, etc. Do not reinforce non-toileting acts. Tell the child how happy [name significant other] will be that the child is learning to use the potty and to keep pants dry.

Accidents: Verbal reprimand, omit reinforcement, have child change wet pants to dry ones by him or herself, conduct 10 rapid “positive practice” sessions as follows:

1 Use the doll that wets to imitate the processes of toileting and teach specific actions. Manually guide child through the proper actions, then let the child guide the doll through the process.
2 When the doll urinates in the potty, teach the child to remove the pot, empty it into the toilet, flush and return the pot to the chair. Once this is learned, begin training child.
3 Teach the child to check and identify dry pants from wet pants. Reward/praise dry pants. Perform checks every 3 to 5 minutes and keep track using a training reminder sheet.
4 Give child as much to drink as desired to create a strong, frequent desire to toilet (at least 8oz/hr). Use as a positive reinforcement.
5 Instruct child to walk to the potty, lower pants, sit down quietly for several minutes, stand up, and raise pants. Watch to see if urination begins and praise/ reward immediately.
6 After urination takes place, the have child wipe him or herself, and empty and replace pot as in 2 above.
7 Increased number of trials: give prompted potty trials every 15 minutes in the beginning, decrease frequency as child acquires skill.
8 Conduct “dry pants” checks every 5 minutes, have child do it as well.
9 At first, have child sit on the potty about 10 minutes; after two to three successful urinations into the potty and much praise, the child will begin to understand and prompting and sit time can be reduced.
10 Gradually change from directing child to “go potty” to asking child if he or she has to “go potty” to general questions such as “Where do you go potty?” and “Are your pants dry?”. Once child goes potty after a general question, only comment on dry pants.
11 As child acquires skills and performs actions correctly, give approval only at the end of an action rather than during it. Eventually reduce to praising only dry pants.
12 For next several days, do dry pants checks at meals, naps, bedtimes, etc., and praise each time pants are dry. If there is an accident, reprimand the child, have the child change by him or herself, and perform more practice sessions. No reminders to toilet are given.

## H-3. Early Elimination Toilet Training Method

### Objective

At one year old, child is expected to control elimination, walk, and verbalize simple needs.

### Method

1 Bowel and bladder training begin simultaneously at 2 to 3 weeks of age.
2 Initially, the mother assumes all responsibility by placing child in a special training position outside the house when she senses the child needs to eliminate (e.g., after feeding and waking).
  a For voiding, mother sits with legs extended straight out, places the child in a sitting position between them facing away from her and supported by her body. She then makes a “shuus” sound so child learns to associate it with voiding. This is done many times over 24 hours. If successful, the child is rewarded with feeding, close contact or other pleasurable activity.
    The child is expected to gain competence in communicating his or her need to void and climb into the assumed position and urinate by 4 to 5 months.
  b For bowel movements, mother sits on the floor with knees bent, infant facing her, supported by her lower legs. Child's legs are placed over hers. The mother's feet provide a kind of potty. No sound is made. If elimination occurs, the child is rewarded by pleasurable activity; if not, the child is returned matter-of-factly back to previous activity.
    During elimination, social activity carries on; elimination is not regarded as private or unclean.
    The mothers claim to learn to read infants' movements, skin and muscle tension, and also distinguish a language of grimaces, grunts and cries to signal need. When specific pushes and shoves are detected while carrying a child on her back she may occasionally stimulate a sphincter reflex with a gentle pat to the rear.
3 At 3 to 5 months, young girls 5 to 12 years old also learn the child's signals and participate in further training by assuming elimination positions at appropriate times. Helpers are scolded or punished if they are not responsive or sensitive to infant's needs.
4 Occasional accidents are expected and handled casually; caregiver cleans up immediately.
5 At one year, when infant begins walking, he or she is expected to eliminate away from the living area of the house. Accidents in the living area or courtyard first attract warnings and later physical punishment.

## H-4. Dr. Spock's Toilet Training Method

### Objective

To train without force. Most children are ready between 2 and 2.5 years of age. If parents wait until a child is ready, the child will learn without being forced, and the process will be more relaxed and pleasant with fewer power struggles. The child must decide to gain control of bowel and bladder to be more grown-up. Parents must trust the child's desire and be patient. Once training begins, parents must be consistent and convey the expectation that the child will toilet as older people do by praising and encouraging success, and avoiding criticism and anger in the event of accidents and refusal.

### Pre-training experiences

Allow the child into the bathroom with other family members to learn about potting, but without the pressure to perform. Teach the child to wash his or her hands afterwards. Talk about what is happening so the child learns the words and also that toileting is a straight forward fact of life and not dirty, shameful, secret, or mysterious. Avoid commenting on how smelly or messy “poop” is so the child does not confuse criticism of evacuation with criticism of him or herself.

### Training supplies and set-up

- small plastic child-size potty chair with the urine guard removed (boys and girls should learn to eliminate in the sitting position),
- step stool and small bar of soap so the child can learn handwashing, and
- books or toys near the potty to entertain the child.

### Method

1 Get the child used to the potty chair. Have the child sit on the potty fully clothed for as long or short as child chooses.
2 Once the child has accepted the seat, suggest the child use it for bowel movements the way the parents do. Let the child leave the seat whenever the child chooses so he or she does not associate potting with punishment or imprisonment. They ought to think of it as a voluntary act carried out with pride; do not urge or pressure the child if the child is unwilling. If movement occurs in diaper, show the child how to deposit it in the potty and say that is where he or she will do it soon, too. Do not empty the potty into the toilet and flush it while the child is watching.
3 Once the child shows interest, take the child to the potty two to three times per day, especially if signals of impending elimination are detected. Praise the child for being dry for long periods just like “parent or favorite character.” Do not over-praise, as this age group does not like to be too compliant. When the child appears ready to be more independent, remove all lower clothing and place the potty nearby explaining to the child that he or she can use it whenever they need to by him or herself. The parent may give occasional reminders. Put the child back in diapers if the child resists or has an accident.

Children usually achieve bowel and bladder control at the same time. Once this control is obtained, switch the child to training pants. Do not scold the child for the occasional accident. Boys will learn to stand and pee sooner or later from imitation.

Once control is achieved, teach proper wiping and handwashing Teach the child to wipe from front to back; the parent may have to complete the job at first.