# Appendix G: Abbreviations

AAP | American Academy of Pediatrics
ADHD | attention deficit and hyperactivity disorder
CCT | controlled clinical trial
CG | conventional group
CIC | clean intermittent catheterization
CPS | Canadian Paediatric Society
DSM IV-TR | Diagnosis and Statistical Manual IV - Text Revised
LUTS | lower urinary tract symptoms
MC | mentally handicapped children
NR | not reported
OC | operant conditioning
RCT | randomized controlled trial
RT | regular toileting
SA | social age
SCH | scheduled
SD | standard deviation
SI | self-initiated
SIE | self-initiated elimination
STR | stool toileting refusal
TEP | technical expert panel
TT | toilet training
UK | United Kingdom
VSMS | Vineland Social Maturity Scale