# Appendix F: Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

- Lola Baydala
- University of Alberta, Edmonton, AB

- Nathan Blum
- University of Pennsylvania, Philadelphia, PA

- Brenda Clark
- University of Alberta, Edmonton, AB

- Jennifer Shu
- Dartmouth Medical School, Hanover, NH

## Peer Reviewers

- Edward Christopherson
- Children's Mercy Specialty Center, Overland Park, KS

- Mark Feldman
- St. Joseph's Health Centre, Toronto, ON and The Hospital for Sick Children, Toronto, ON

- Lynne Haverkos
- National Institute of Child Health and Human Development, Rockville, MD

- Sally Longstaffe
- University of Manitoba, Winnipeg, MN

- Virginia Moyer
- University of Texas, Houston, TX

- Leonard Rappaport
- Children's Hospital Boston, Boston, MA

- Martin Stein
- University of California, San Diego, CA