# Appendix E: List of Excluded Studies

## Inappropriate Study Design

1 Abidari JM, Shortliffe LMD. Urinary incontinence in girls. Urol Clin North Am. 2002;29(3):661. [pmid: 12476529].
2 Ake A. Improving toilet-use (encopresis) in a nine-year-old male through full-cleanliness training and token reinforcement. Early Child Dev Care. 1993;86:123-30.
3 Anonymous. Healthy children. Toilet training: is your child ready? Health News 2000;18(3):8.
4 Anonymous. Preventing constipation and faecal incontinence in children. Prof Nurse 1988;4(3):146.
5 Anonymous. Stool holding: when your child holds back bowel movements and is not toilet trained. Contemp Pediatr 2004;21(4):81–2.
6 Anonymous. Toilet training: does an early start help? Child Health Alert 2003;21:5.
7 Anonymous. Toilet-training dolls. Pediatric Mental Health 1997;16(5):7.
8 Anonymous. Toilet training resistance: daytime wetting and soiling. Contemp Pediatr 2004;21(4):78–9.
9 Anonymous. Winning the toilet-training war. Patient Care 1988;22(16):161–2.
10 Anthony EJ. An experimental approach to the psychopathology of childhood: encopresis. Br J Med Psychol 1957;(30):146–75.
11 Ash LC. Toilet training retarded. Can Psychiatr Assoc J. 1977;22(4):194.
12 Ayllon T, Simon SJ, Wildman RW. Instructions and reinforcement in the elimination of encopresis: a case study. J Behav Ther Exp Psychiatry. 1975;6(3):235-8.
13 Azrin NH. On toilet training the severely and profoundly retarded. Journal of Research & Training. 1973;1(1):9-13.
14 Azrin NH, Bugle C, O'Brien F. Behavioral engineering: two apparatuses for toilet training retarded children. J Appl Behav Anal. 1971;4(3):249-53. [pmid: 16795301]. [pmcid: 1310698].
15 Azrin NH, Sneed TJ, Foxx RM. Dry-bed training: rapid elimination of childhood enuresis. Behav Res Ther. 1974;12(3):147-56. [pmid: 4429525].
16 Bach R, Moylan JJ. Parents administer behavior therapy for inappropriate urination and encopresis: a case study. J Behav Ther Exp Psychiatry. 1975;6(3):239-41.
17 Bainbridge N, Myles BS. The use of priming to introduce toilet training to a child with autism. Focus Autism Other Dev Disabl. 1999;14(2):106-9.
18 Baird M. Characteristic interaction patterns in families of encopretic children. Bull Menninger Clin. 1974;38(2):144-53. [pmid: 4433937].
19 Baker S, Mercer M. Toilet training your child. Good Housekeeping. 1986;203(3):92.
20 Bakker E, van Gool J, van Sprundel M, et al. Risk factors for recurrent urinary tract infection in 4,332 Belgian schoolchildren aged between 10 and 14 years. Eur J Pediatr. 2004;163(45):234-8. [pmid: 14986116].
21 Barba WP. Toilet Training. JAMA. 1964;188(10):943-8.
22 Barmann BC, Katz RC, O'Brien F, et al. Treating irregular enuresis in developmentally disabled persons: a study in the use of overcorrection. Behav Modif. 1981;5(3):336-46.
23 Barnitt RE. Aids for the multi-handicapped child. Physiotherapy. 1971;57(9):418-24. [pmid: 4255505].
24 Bartholomew TH. Neurogenic voiding: function and dysfunction. Urol Clin North Am. 1985;12(1):67-73. [pmid: 3976095].
25 Baysoy G, Aydogmus T, Akin D, et al. Re: the micturition habits and prevalence of daytime urinary incontinence in Japanese primary school children. J Urol. 2004;172(3):1198-9. [pmid: 15311077].
26 Bemporad JR, Kresch RA, Asnes R, et al. Chronic neurotic encopresis as a paradigm of a multifactorial psychiatric disorder. J Nerv Ment Dis. 1978;166(7):472-9. [pmid: 670958].
27 Benjamin LS, Serdahely W, Geppert TV. Night training through parents' implicit use of operant conditioning. Child Dev. 1971;42(3):963-6. [pmid: 5121106].
28 Benninga MA, Taminiau JA. Diagnosis and treatment efficacy of functional non-retentive fecal soiling in childhood. J Pediatr Gastroenterol Nutr. 2001;32(Suppl 1):S42-3. [pmid: 11321422].
29 Bentsen D, Braun JW. Controlling fecal incontinence with sensory retraining managed by advanced practice nurses. Clin Nurse Spec. 1996;10(4):171-5. [pmid: 8900792].
30 Berk LB, Friman PC. Epidemiologic aspects of toilet training. Clin Pediatr. 1990;29(5):278-82.
31 Berkowitz BP, Graziano AM. Training parents as behavior therapists: a review. Behav Res Ther. 1972;10(4):297-317. [pmid: 4564856].
32 Berry R, Dearden R, Perkins E, et al. Behavioural principles: a multi-disciplinary approach to the management of severely mentally handicapped children. Nurs Times. 1978;74(32):1327-9. [pmid: 248728].
33 Bettison S. Toilet training the retarded: an analysis of the stages of development and procedures for designing programs. Aust J Ment Retard. 1978;5(3):95-100.
34 Bettison S. The problem of toilet training and the retarded. Aust Psychol. 1981;16(2):295-6.
35 Bettison S. Behavioral-approaches to toilet training for retarded persons. Int Rev Res Ment Retard. 1986;14:319-50.
36 Bettison S, Davison D, Taylor P, et al. The long-term effects of a toilet training programme for the retarded: a pilot study. Aust J Ment Retard. 1976;4(4):28-35.
37 Bloom DA, Park JM, Koo HP. Comments on pediatric elimination dysfunctions: the Whorf hypothesis, the elimination interview, the guarding reflex and nocturnal enuresis. Eur Urol. 1998;33(Suppl 3):20-4. [pmid: 9599732].
38 Boelens H, van den Broek S, Beishuizen J. Using a pants alarm for the treatment of day wetting: problems with compliance. Psychol Rep. 2003;93(3):1073-6. [pmid: 14765572].
39 Boon FF, Singh NN. A model for the treatment of encopresis. Behav Modif. 1991;15(3):355-71. [pmid: 1953624].
40 Bornstein PH, Balleweg BJ, McLellarn RW, et al. The ‘bathroom game’: a systematic program for the elimination of encopretic behavior. J Behav Ther Exp Psychiatry. 1983;14(1):67-71. [pmid: 6863555].
41 Brayden RM, Poole SR. Common behavioral problems in infants and children. Prim Care. 1995;22(1):81-97. [pmid: 7777639].
42 Brazelton TB, Christophersen ER, Frauman AC, et al. Instruction, timeliness, and medical influences affecting toilet training. Pediatrics. 1999;103(6):1353-8. [pmid: 10353953].
43 Bromley I. Urinary incontinence associated with organic nervous disorders. Physiotherapy. 1973;59(11):360-3. [pmid: 4794142].
44 Brooks RC, Copen RM, Cox DJ, et al. Review of the treatment literature for encopresis, functional constipation, and stool-toileting refusal. Ann Behav Med. 2000;22(3):260-7. [pmid: 11211851].
45 Brown RM, Brown NL. The increase and control of verbal signals in the bladder training of a seventeen-month-old child: a case study. J Child Psychol Psychiatry. 1974;15(2):105-9. [pmid: 4443375].
46 Bryant GA. When spinal cord injury affects the bowel. RN. 2000;63(2):26-9. [pmid: 10745881].
47 Burgio KL. Current perspectives on management of urgency using bladder and behavioral training. J Am Acad Nurse Pract. 2004;16(10 Suppl):4-7. [pmid: 15543926].
48 Burnett C, Wilkins G. Managing children with constipation: a community perspective. J Fam Health Care. 2002;12(5):127-32. [pmid: 12449063].
49 Butler JF. Toilet training a child with spina bifida. J Behav Ther Exp Psychiatry. 1976;7(1):63-5.
50 Butler JF. Treatment of encopresis by overcorrection. Psychol Rep. 1977;40(2):639-46. [pmid: 859984].
51 Buxbaum E, Sodergren SS. A disturbance of elimination and motor development: the mother's role in the development of the infant. Psychoanal Study Child. 1977;32:195-214. [pmid: 72391].
52 Cahill CA. Imipramine in nocturnal enuresis. Am J Dis Child. 1967;114(2):215. [pmid: 4951551].
53 Canales L. Maternal attitudes concerning toilet training [letter]. J Pediatr. 1974;85(4):586-7. [pmid: 4443876].
54 Carpenter SP. Development of a young man with Prader-Willi syndrome and secondary functional encopresis. Can J Psychiatry. 1989;34(2):123-7. [pmid: 2706603].
55 Carr J. Bedwetting: a new approach to treatment in a mentally handicapped boy. Child Care Health Dev. 1987;13(4):239-45. [pmid: 2959390].
56 Casale AJ. Functional voiding disorders of childhood. J Ky Med Assoc. 1993;91(5):184-91. [pmid: 8509685].
57 Castiglia PT. Encopresis. J Pediatr Health Care. 1987;1(6):335-7. [pmid: 3694411].
58 Castledine G. Case 26: tying a client to a toilet. Client with learning disabilities who died after being tied to a toilet. Br J Nurs. 2000;9(9):536. [pmid: 11904886].
59 Chopra HD. Treatment of encopresis in a mongol with operant conditioning. Indian Journal of Mental Retardation. 1973;6(1):43-6.
60 Christiano D. Potty time: are you getting ready to ditch diapers? Parents 2003;78(4):128–30, 134.
61 Christophersen ER. Behavioral pediatrics. Am Fam Physician. 1978;17(3):134-9. [pmid: 629193].
62 Christophersen ER. Incorporating behavioral pediatrics into primary care. Pediatr Clin North Am. 1982;29(2):261-96. [pmid: 7070865].
63 Christophersen ER. Toileting problems in children. Pediatr Ann. 1991;20(5):240-4. [pmid: 1896226].
64 Christophersen ER. The case for evidence-based toilet training. Arch Pediatr Adolesc Med. 2003;157(12):1153-4. [pmid: 14662563].
65 Christophersen ER, Rapoff MA. Enuresis treatment. Issues Compr Pediatr Nurs. 1978;2(6):34-52. [pmid: 249310].
66 Christophersen ER, Rapoff MA. Toileting problems in children. In: Walker CE, Roberts MC, eds. Handbook of clinical child psychology. Oxford, England: John Wiley & Sons; 1992:399–411.
67 Cicero FR, Pfadt A. Investigation of a reinforcement-based toilet training procedure for children with autism. Res Dev Disabil. 2002;23(5):319-31. [pmid: 12401483].
68 Clancy HR, Short J. Infantile autism: a problem of communication. Australian Occupational Therapy Journal 1968;15(3):Jul-20.
69 Clayden GS. Constipation and soiling in childhood. Br Med J. 1976;1(6008):515-7. [pmid: 1252825]. [pmcid: 1638847].
70 Clel CC. Toilet training to independence. Am J Ment Defic. 1983;88(3):341.
71 Clifford T. Toilet learning: anticipatory guidance with a child-oriented approach. J Paediatr Child Health. 2000;5(6):333-5.
72 Coffman S. Description of a nursing diagnosis: alteration in bowel elimination related to neurogenic bowel in children with myelomeningocele. Issues Compr Pediatr Nurs. 1986;9(3):179-91. [pmid: 3635503].
73 Cook E. Assessing continence needs in children. Nurs Stand. 1999;13(38):48-52. [pmid: 10497473].
74 Cooper ZR, Rose S. Fecal incontinence: a clinical approach. Mt Sinai J Med. 2000;67(2):96-105. [pmid: 10747364].
75 Corday RJ. Toilet training and ‘the terrible two's’. Comments on the prevention and management of behavior problems at this age. Clin Pediatr. 1967;6(1):41-6.
76 Corey JR, Dorry GW. A necessary modification of ‘a transistorized signal-package for toilet training of infants’. J Exp Child Psychol. 1972;13(1):248. [pmid: 5059955].
77 Coulthard M, Vernon SJ. Response to: a method comparison study to assess the reliability of urine collection pads as a means of obtaining urine specimens from non-toilet-trained children for microbiological examination by M. Farrell, K. Devine, G. Lancaster and B. Judd (2002) J Adv Nurs 37, 387–393. J Adv Nurs. 2002;39(2):199-200. [pmid: 12100664].
78 Cox LV. The Maryland School for the Blind summer day school program for pre-school multi-handicapped blind children. International Journal for the Education of the Blind. 1968;18(4):97-9.
79 Craig E. One, two, three...: the story of Matt, a feral child. New York: McGraw-Hill; 1978.
80 Crowley AA. A comprehensive strategy for managing encopresis. Am J Matern Child Nurs. 1984;9(6):395-400.
81 Dalrymple NJ, Angrist MH. Toilet training a sixteen year old with autism in a natural setting. British Journal of Mental Subnormality. 1988;34(2):117-30.
82 Davis H, Mitchell WS, Marks F. A behavioural programme for the modification of encopresis. Child Care Health Dev. 1976;2(5):273-82. [pmid: 991398].
83 Dayan M. Toilet training retarded children: a state residential institution. Ment Retard. 1964;133:116-7. [pmid: 14143144].
84 De Paepe H, Renson C, Hoebeke P, et al. The role of pelvic-floor therapy in the treatment of lower urinary tract dysfunctions in children. Scand J Urol Nephrol. 2002;36(4):260-7. [pmid: 12201917].
85 deVries MW, deVries MR. Cultural relativity of toilet training readiness: a perspective from East Africa. Pediatrics. 1977;60(2):170-7. [pmid: 887331].
86 Di Lorenzo C, Benninga MA. Pathophysiology of pediatric fecal incontinence. Gastroenterology. 2004;126(1 Suppl 1):S33-40. [pmid: 14978636].
87 Dische S. Childhood enuresis. A family problem. Practitioner. 1978;221(1323):323-30. [pmid: 733703].
88 Dixon J, Smith PS. Symposium on teaching-methods for severely subnormal.3. Use of a pants alarm in daytime toilet training. British Journal of Mental Subnormality. 1976;22(42):20-5.
89 Dixon JW, Saudargas RA. Toilet training, cueing, praise, and self-cleaning in the treatment of classroom encopresis: a case study. Journal of School Psychology. 1980;18(2):135-40.
90 Doleys DM, Dolce JJ. Toilet training and enuresis. Pediatr Clin North Am. 1982;29(2):297-313. [pmid: 6461836].
91 Doleys DM, McWhorter AQ, Williams SC, et al. Encopresis: its treatment and relation to nocturnal enuresis. Behav Ther. 1977;8(1):77-82.
92 Doughty D. A physiologic approach to bowel training. J Wound Ostomy Continence Nurs. 1996;23(1):46-56. [pmid: 8704850].
93 Duldner JE, Buerk E, Davis JB, et al. Blue water. Clin Pediatr. 1994;33(4):253-5.
94 Dunlap G. Continuity of treatment: toilet training in multiple community settings. J Assoc Pers Sev Handicaps. 1984;9(2):134-41.
95 Dworkin PH. The preschool child: developmental themes and clinical issues. Curr Probl Pediatr. 1988;18(2):73-134. [pmid: 3365985].
96 Edwards-Beckett J, King H. The impact of spinal pathology on bowel control in children. Rehabil Nurs. 1996;21(6):292-7. [pmid: 9087097].
97 Enfield C. Enuresis. Med J Aust. 1976;2(24):908-10. [pmid: 1018668].
98 Epstein LH, McCoy JF. Bladder and bowel control in Hirschsprung's disease. J Behav Ther Exp Psychiatry. 1977;8(1):97-9.
99 Anderson D, McCoy D. Ten years later: toilet training in the post-Azrin-and-Foxx era. J Assoc Pers Sev Handicaps. 1982;7(2):71-9.
100 Faigin H. Social behavior of young children in the Kibbutz. J Abnorm Soc Psychol 1958; (56):117–29.
101 Fischer P. Early toilet training. J Fam Pract 1990;30(3):262, 360.
102 Fleisher DR. Diagnosis and treatment of disorders of defecation in children. Pediatr Ann. 1976;5(11):700-22. [pmid: 980548].
103 Fleisher DR. Understanding toilet training difficulties. Pediatrics. 2004;113(6):1809-10. [pmid: 15173510].
104 Fong LD, Ryan S, Miller PJ, et al. Consumer-based approaches used in the development of an adaptive toileting system for children with positioning problems. Phys Occup Ther Pediatr. 2002;22(1):24-5.
105 Foxx JAN. Toilet training the retarded - rapid program for day and nighttime independent toileting. Am J Ment Defic. 1974;79(2):233.
106 Frauman AC, Bron DH. Toilet training for the child with chronic illness. Pediatr Nurs. 1996;22(6):469-72. [pmid: 9087083].
107 Friman PC. A preventive context for enuresis. Pediatr Clin North Am. 1986;33(4):871-86. [pmid: 3737260].
108 Friman PC, Vollmer D. Successful use of the nocturnal urine alarm for diurnal enuresis. J Appl Behav Anal. 1995;28(1):89-90. [pmid: 7706154]. [pmcid: 1279792].
109 Fritz GK, Armbrust J. Enuresis and encopresis. Psychiatr Clin North Am. 1982;5(2):283-96. [pmid: 6750570].
110 Furman L. Epidemiologic aspects of toilet training. Clin Pediatr. 1990;29(9):546-7.
111 Gersh MJ. Early toilet training. Pediatrics. 1978;61(4):674. [pmid: 662503].
112 Glazener CM, Peto RE, Evans JH. Effects of interventions for the treatment of nocturnal enuresis in children. Qual Saf Health Care. 2003;12(5):390-4. [pmid: 14532374]. [pmcid: 1743766].
113 Gleeson RM. Bowel continence for the child with a neurogenic bowel. Rehabil Nurs. 1990;15(6):319-21. [pmid: 2236885].
114 Godding EW. Physiological yardsticks for bowel function and the rehabilitation of the constipated bowel. Pharmacology. 1980;20(Suppl 1):88-103. [pmid: 6246549].
115 Gorski PA. Toilet training guidelines: clinicians - the role of the clinician in toilet training. Pediatrics. 1999;103(6):1364-6. [pmid: 10353956].
116 Gorski PA. Toilet training guidelines: day care providers - the role of the day care provider in toilet training. Pediatrics. 1999;103(6):1367-8. [pmid: 10353957].
117 Gorski PA. Toilet training guidelines: parents - the role of the parents in toilet training. Pediatrics. 1999;103(6):1362-3. [pmid: 10353955].
118 Gray JE. Letter: plumbing and bowel habit. Lancet. 1975;2(7925):127. [pmid: 49716].
119 Greene AR. Computers, doctors, and toilet training. MedGenMed. 2000;2(6):E5. [pmid: 11335855].
120 Greenfield SP, Wan J. The relationship between dysfunctional voiding and congenital vesicoureteral reflux. Curr Opin Urol. 2000;10(6):607-10. [pmid: 11148733].
121 Hagopian LP, Fisher W, Piazza CC, et al. A water-prompting procedure for the treatment of urinary incontinence. J Appl Behav Anal. 1993;26(4):473-4. [pmid: 8307833]. [pmcid: 1297874].
122 Education and Resources for Improving Childhood Continence. Toilet training. Br J Nurs 2004;13(17):1025.
123 Harris A. Toilet training children with learning difficulties: what the literature tells us. Br J Nurs. 2004;13(13):773-7. [pmid: 15284658].
124 Hellstrom AL. Influence of potty training habits on dysfunctional bladder in children. Lancet. 2000;356(9244):1787. [pmid: 11117908].
125 Heyward E. Generalisation of toileting skills of a mentally handicapped boy. Behavioural Psychotherapy. 1988;16(2):102-7.
126 Hignell C. Elimination: a time and a place. Community Outlook 1982;197–204.
127 Holaday B. Changing views of infant care 1914-1980. Pediatr Nurs. 1981;7(1):21-5. [pmid: 7008008].
128 Horner MM, McClellan MA. Toilet training: ready or not?. Pediatr Nurs. 1981;7(1):15-8. [pmid: 6906650].
129 Howe AC, Walker CE. Behavioral management of toilet training, enuresis, and encopresis. Pediatr Clin North Am. 1992;39(3):413-32. [pmid: 1574352].
130 Huschka M. The child's response to coercive bowel training. Psychosom Med. 1942;4(3):301-8.
131 Issenman RM, Filmer RB, Gorski PA. A review of bowel and bladder control development in children: how gastrointestinal and urologic conditions relate to problems in toilet training. Pediatrics. 1999;103(6):1346-52. [pmid: 10353952].
132 Jelliffe DB, Bennett FJ. Aspects of child rearing in Africa. J Trop Pediatr Environ Child Health. 1972;18(1):25-43. [pmid: 4261852].
133 Johnson M. Nocturnal enuresis. Urol Nurs. 1998;18(4):259-73. [pmid: 9873352].
134 Jones DS. Training in cleanliness. Psychoanal Rev 1956;(43):448–53.
135 Kaefer M, Keating MA, Adams MC, et al. Posterior urethral valves, pressure pop-offs and bladder function. J Urol. 1995;154(2):708-11. [pmid: 7609159].
136 Katz J. Enuresis and encopresis. Med J Aust. 1972;1(3):127-30. [pmid: 5060474].
137 Keeler CC. Incontinence: toilet training a child with special needs. Exceptional Parent. 2000;30(10):82-6.
138 Kimmel HD. Toilet training in less than a day - how to do it. J Behav Ther Exp Psychiatry. 1974;5(1):113.
139 Kinservik MA, Friedhoff MM. Control issues in toilet training. Pediatr Nurs. 2000;26(3):267-72. [pmid: 12026390].
140 Klauser AG, Muller-Lissner SA. How effective is nonlaxative treatment of constipation?. Pharmacology. 1993;47(Suppl 1):256-60. [pmid: 8234439].
141 Koff SA. Evaluation and management of voiding disorders in children. Urol Clin North Am. 1988;15(4):769-75. [pmid: 3055626].
142 Kohler M, Barolin GS. Rehabilitation measures in the urological excretory system. Eurorehab 1996; (4):211–18.
143 Kuhn BR, Marcus BA, Pitner SL. Treatment guidelines for primary nonretentive encopresis and stool toileting refusal. Am Fam Physician. 2184;59(8):2171-8. [pmid: 10221303].
144 Lal H, Lindsley OR. Therapy of chronic constipation in a young child by rearranging social contingencies. Behav Res Ther. 1968;6(4):484-5. [pmid: 5714992].
145 Lance WD, Koch AC. Parents as teachers: self-help for young handicapped children. Ment Retard. 1973;11(3):3-4. [pmid: 4274341].
146 Lancioni GE, Van Bergen I, Furniss F. Urine alarms and prompts for fostering daytime urinary continence in a student with multiple disabilities: a replication study. Percept Mot Skills. 2002;94(3):867-70. [pmid: 12081292].
147 Lancioni GE, Duker PC, Klaase M, et al. Promoting self-initiated toileting in children with severe developmental disabilities. Scand J Behav Ther. 1994;23(34):113-9.
148 Leibold S, Ekmark E, Adams RC. Decision-making for a successful bowel continence program. Eur J Pediatr Surg. 2000;10(Suppl 1):26-30. [pmid: 11214828].
149 Lennard-Jones JE. Clinical management of constipation. Pharmacology. 1993;47(Suppl 1):216-23. [pmid: 8234432].
150 Levine MD. Encopresis: its potentiation, evaluation, and alleviation. Pediatr Clin North Am. 1982;29(2):315-30. [pmid: 7070866].
151 Levine MN, Elliot CB. Toilet training for profoundly retarded with a limited staff. Ment Retard. 1970;8(3):48-50. [pmid: 5537586].
152 Levowitz HJ, Goldstein G. Encopresis in adolescence: two case studies. Adolescence. 1979;14(54):297-311. [pmid: 484313].
153 Litrownik AJ. A method for home training an incontinent child. J Behav Ther Exp Psychiatry. 1974;5(1):77-80.
154 Loening-Baucke V. Management of chronic constipation in infants and toddlers. Am Fam Physician. 403;49(2):397-400. [pmid: 8304261].
155 Loening-Baucke V. Functional constipation. Semin Pediatr Surg. 1995;4(1):26-34. [pmid: 7728505].
156 Loening-Baucke V. Encopresis and soiling. Pediatr Clin North Am. 1996;43(1):279-98. [pmid: 8596685].
157 Lowenthal B. Teaching basic adaptive skills to young children with disabilities. ECDC. 1996;115(1):77-84.
158 Lozoff B. United States toilet training exceptional in cross-cultural analysis. Pediatr Res. 1980;14(4):435.
159 Luiselli JK. Case report: an attendant-administered contingency management programme for the treatment of a toileting phobia. J Ment Defic Res. 1977;21(4):283-8. [pmid: 604502].
160 Luiselli JK. Toilet training children with sensory impairments in a residential school setting. Behavioral Interventions. 1994;9(2):105-14.
161 Luiselli JK. A case study evaluation of a transfer-of-stimulus control toilet training procedure for a child with pervasive developmental disorder. Focus Autism Other Dev Disabl. 1996;11(3):158-62.
162 Luiselli JK. A transfer of stimulus control procedure applicable to toilet training programs for children with developmental disabilities. Child & Family Behavior Therapy. 1996;18(2):29-34.
163 Luiselli JK. Teaching toilet skills in a public school setting to a child with pervasive developmental disorder. J Behav Ther Exp Psychiatry. 1997;28(2):163-8. [pmid: 9194013].
164 Luiselli JK. Commentary on urine alarms and prompts for fostering daytime urinary continence in a student with multiple disabilities: a replication study by Lancioni, Van Bergen, and Furniss. Percept Mot Skills. 2002;94(3):1301-2. [pmid: 12186252].
165 Luiselli JK, Reisman J, Helfen CS, et al. Toilet training in the classroom: an adaptation of Azrin and Foxx's Rapid Toilet Training procedures. Behav Eng. 1979;5(3):89-93.
166 Lutzker JR, Lamazor EA. Behavioral pediatrics: research, treatment, recommendations. Prog Behav Modif. 1985;19:217-53. [pmid: 4022824].
167 Luxem M, Christophersen E. Behavioral toilet training in early childhood: research, practice, and implications. J Dev Behav Pediatr. 1994;15(5):370-8. [pmid: 7868706].
168 MacCalman DR. Background to child development patterns in the United Kingdom. In: Soddy K ed. Mental health and infant development: papers and discussions. Vol. 2. Great Britain: Routledge; 1956. p. 63–70.
169 Magill JT. Control-related beliefs, self-toileting, and therapeutic outcome in children with encopresis. New Hampshire: Antioch University. In: ProQuest Digital Dissertations [database on the Internet][cited 2006 Jun 12]. Available from: www.proquest.com/; Publication No. AAT 9510010.).
170 Maizels M, Firlit CF. Guide to the history in enuretic children. Am Fam Physician. 1986;33(4):205-9. [pmid: 3962838].
171 Maizels M, Ghi K, Keating B, et al. Diagnosis and treatment for children who cannot control urination. Curr Probl Pediatr. 1993;23(10):402-50. [pmid: 8287678].
172 Maizels M, Rosenbaum D. Successful treatment of nocturnal enuresis: a practical approach. Prim Care. 1985;12(4):621-35. [pmid: 3909174].
173 Malem H, Knapp MS, Hiller EJ. Electronic bed-wetting alarm and toilet trainer. Br Med J (Clin Res Ed). 1982;285(6334):22.
174 Maloney CM, Cafiero M. Achieving bladder control. Treatment in the primary care setting. Adv Nurse Pract. 2002;10(5):73-8. [pmid: 12420535].
175 Manson G, Read J. A low cost portable enuresis alarm. J Med Eng Technol. 1979;3(2):83-4. [pmid: 551994].
176 Marshall GR. Toilet training of an autistic eight-year-old through conditioning therapy: a case report. Behav Res Ther. 1966;4(3):242-5. [pmid: 5946545].
177 Martin MM. What do you think? In regard to bladder management. SCI Nurs. 1991;8(2):55. [pmid: 2047838].
178 Matson JL. Some practical considerations for using the Foxx and Azrin rapid method of toilet training. Psychol Rep. 1975;37(2):350.
179 Matson JL. Simple correction for treating an autistic boy's encopresis. Psychol Rep. 1977;41(3):802. [pmid: 594263].
180 McGraw MB. Neural maturation as exemplified in achievement of bladder control. J Pediatr 1940; (16):580–90.
181 Mead D. Chronic constipation and soiling. Nurs Mirror. 1983;157(3):25-6. [pmid: 6554734].
182 Michel RS. Toilet training. Pediatr Rev. 1999;20(7):240-5. [pmid: 10393225].
183 Monsen RB. Giving children control and toilet training. J Pediatr Nurs. 2001;16(5):375-6. [pmid: 11598870].
184 Moreton J. Encopresis is not a problem in traveling families. Prof Nurse. 1989;4(10):506. [pmid: 2771978].
185 Morris D. The hazards in toilet training. Nurs Mirror. 1978;147(11):26-7. [pmid: 250039].
186 Mowrer OH. Enuresis: the beginning work - what really happened. J Hist Behav Sci. 1980;16(1):25-30. [pmid: 6987294].
187 Murdock LL. Soiling: an ambivalent response to growing-up. Matern Child Nurs J. 1978;7(1):47-9. [pmid: 247122].
188 Murphy MA. Toilet training...when and how. Pediatr Nurs. 1975;1(6):22-7.
189 Murray ME. Behavioral management in pediatrics. Applications of operant learning theory to problem behaviors of children. Clin Pediatr. 1976;15(5):465-70.
190 Nicolau R, Toro J, Perez PC. Behavioral treatment of a case of psychogenic urinary retention. J Behav Ther Exp Psychiatry. 1991;22(1):63-8. [pmid: 1918394].
191 Northmore D. Toilet training. New Statesman & Society. 1990;3(132):30.
192 Novick KK. Issues in the analysis of a preschool girl. Psychoanal Study Child. 1974;29:319-40. [pmid: 4445405].
193 Opolot JA. Child rearing and child care in Uganda. J Soc Psychol. 1978;106(1):123-4.
194 Parker G. Incontinence services for the disabled child: the provision of information and advice. Part 2. Health Visit. 1984;57(3):86-8. [pmid: 6230335].
195 Patel DR, Pratt HD. Encopresis. Indian J Pediatr. 1999;66(3):439-46. [pmid: 10798091].
196 Polaha J, Warzak WJ, Dittmer-Mcmahon K. Toilet training in primary care: current practice and recommendations from behavioral pediatrics. J Dev Behav Pediatr. 2002;23(6):424-9. [pmid: 12476072].
197 Porter A. Early non-coercive toilet training. Community Pract. 2001;74(4):161-2.
198 Post AR, Kirkpatrick MA. Toilet training for a young boy with pervasive developmental disorder. Behavioral Interventions. 2004;19(1):45-50.
199 Pratt R. The nursing care of acute spinal paraplegia. 5: bowel management. Nurs Times. 1971;67(2):638-9. [pmid: 5577630].
200 Pumroy DK, Pumroy SS. Systematic observation and reinforcement technique in toilet training. Psychol Rep. 1965;16(2):467-71. [pmid: 14285853].
201 Racusin RJ. Brief psychodynamic psychotherapy with young children. J Am Acad Child Adolesc Psychiatry. 2000;39(6):791-3. [pmid: 10846315].
202 Rappaport LA, Levine MD. The prevention of constipation and encopresis: a developmental model and approach. Pediatr Clin North Am. 1986;33(4):859-69. [pmid: 3737259].
203 Raps MA. Incontinent children discover hope at Camp Oakhurst. Camping Magazine. 1991;63(3):34-8.
204 Ravindranathan S. On toilet training. Pediatrics. 1978;61(4):674. [pmid: 662504].
205 Reaume VT. Toilet training as a prerequisite for admission to a cerebral palsy preschool. Rehabil Lit. 1964;25:110-2. [pmid: 14137896].
206 Reece RM. Enuresis. Am Fam Physician. 1973;8(4):109-11. [pmid: 4793091].
207 Reeler AP. A simple behavioural approach for the management of childhood encopresis. Cent Afr J Med. 1982;28(4):81-4. [pmid: 7127444].
208 Reid S. Helping children with enuresis and encopresis. Interview by Teresa O'Connor. Nursing New Zealand. 2003;9(7):21. [pmid: 15484542].
209 Reimers TM. A biobehavioral approach toward managing encopresis. Behav Modif. 1996;20(4):469-79. [pmid: 8875816].
210 Reinhart JB. The physician's approach to bowel training. J Dev Behav Pediatr. 1981;2(2):61-3. [pmid: 7263869].
211 Rentfrow RK, Rentfrow DK. Studies related to toilet training of the mentally retarded. Am J Occup Ther. 1969;23(5):425-30. [pmid: 4898818].
212 Ricciardi JN, Luiselli JK. Behavioral intervention to eliminate socially mediated urinary incontinence in a child with autism. Child & Family Behavior Therapy. 2003;25(4):53-63.
213 Richards CG. Ready, steady, hiss. Arch Dis Child. 1991;66(1):172. [pmid: 1994853].
214 Richardson KC, Brown MR, Masiulis B, et al. Biofeedback therapy for managing bowel incontinence caused by meningomyelocele. Am J Matern Child Nurs. 1985;10(6):388-92.
215 Richmond G. Shaping bladder and bowel continence in developmentally retarded preschool children. J Autism Dev Disord. 1983;13(2):197-204. [pmid: 6863213].
216 Robson I. Overcoming nocturnal enuresis in a 16-year-old with mental handicap: an alternative to the dry bed approach. Behavioural Psychotherapy. 1988;16(2):115-21.
217 Robson WL, Leung AK. Advising parents on toilet training. Am Fam Physician. 1991;44(4):1263-6. [pmid: 1927841].
218 Robson WL, Leung AK. Re: behavioral therapy for primary nocturnal enuresis. J Urol. 2004;172(4):1546-7. [pmid: 15371895].
219 Rogers J. Solving the enigma: toilet training children with learning disabilities. Br J Nurs 2002;11(14):958,960,962 passim.
220 Rogers J. Cognitive bladder training in the community. Paediatr Nurs. 1996;8(8):18-20. [pmid: 9052196].
221 Rogers J. Promoting continence: the child with special needs. Nurs Stand. 1998;12(34):47-52. [pmid: 9687716].
222 Rogers J. The causes and management of constipation in children. Community Nurse. 2000;6(3):39-40. [pmid: 12778506].
223 Rogers J. Enuresis: sharing new research and practice. Prof Care Mother Child. 2000;10(1):23-4. [pmid: 11013570].
224 Rogers J. Fast-track toilet training. Nurs Times. 2001;97(40):53-4. [pmid: 11949362].
225 Rogers J. Managing daytime and night-time enuresis in children. Nurs Stand. 2002;16(32):45-52.
226 Rogers J. Toilet training: lessons to be learnt from the past?. Nurs Times. 2002;98(43):56-7. [pmid: 12432733].
227 Rubin G. Constipation. Clin Evid 2002;(8):313–8.
228 Rubin G. Constipation in children. Clin Evid 2003;(10):369–74.
229 Rugolotto S, Sun M. Toilet training. Pediatrics. 2004;113(1):180-1. [pmid: 14702482].
230 Rushton HG. Wetting and functional voiding disorders. Urol Clin North Am. 1995;22(1):75-93. [pmid: 7855962].
231 Sackett CK. Spina bifida. Part 3. Implications for bladder and bowel management. Urol Nurs. 1993;13(4):104-6. [pmid: 8290995].
232 Sapala S, Mead J. Pediatric management problems (toilet training). Pediatr Nurs. 1980;6(4):31. [pmid: 6900982].
233 Schmitt BD. Seven deadly sins of childhood: advising parents about difficult developmental phases. Child Abuse Negl. 1987;11(3):421-32. [pmid: 3479226].
234 Schor EL. Evidence-based toilet training. Arch Pediatr Adolesc Med. 2004;158(6):600-1. [pmid: 15184230].
235 Scott V. A biofeedback approach to encopresis in Hirschsprung's disease. Behavioural & Cognitive Psychotherapy. 1996;24(1):83-90.
236 Shaikh N. Time to get on the potty: are constipation and stool toileting refusal causing delayed toilet training?. J Pediatr. 2004;145(1):12-3. [pmid: 15238899].
237 Sharma A. Enuresis (bed wetting). J Indian Med Assoc. 1991;89(1):21-2. [pmid: 2051041].
238 Shaw WJ. Toilet training: what do parents know, anyway?. J Pediatr Psychol. 1976;4(1):4-6.
239 Shillitoe R, Reed S. Enuresis. Dry at night. Community Outlook 1986;Mar 12:20–3.
240 Showers J. Behaviour management cards as a method of anticipatory guidance for parents. Child Care Health Dev. 1989;15(6):401-15. [pmid: 2620444].
241 Simonds JF. Enuresis. A brief survey of current thinking with respect to pathogenesis and management. Clin Pediatr. 1977;16(1):79-82.
242 Sines D. Incontinence: helping people with mental handicap. Nurs Times. 1983;79(33):52-5. [pmid: 6555733].
243 Singh NN. Toilet training a severely retarded nonverbal child. Aust J Ment Retard. 1976;4(1):15-8.
244 Skolnik D. I did it my way. Parents. 2003;78(1):107-8.
245 Smeets PM, Lancioni GE, Ball TS, et al. Shaping self-initiated toileting in infants. J Appl Behav Anal. 1985;18(4):303-8. [pmid: 4086412]. [pmcid: 1308025].
246 Smith DA. Overactive bladder. Strategies for better recognition and management. Adv Nurse Pract. 2004;12(3):26-33. [pmid: 15038182].
247 Smith KH. American Academy of Pediatrics guide to toilet training. Libr J. 2003;128(5):109.
248 Smith L, Smith P, Lee SK. Behavioural treatment of urinary incontinence and encopresis in children with learning disabilities: transfer of stimulus control. Dev Med Child Neurol. 2000;42(4):276-9. [pmid: 10795568].
249 Smith LJ, Bainbridge G. An intensive toilet training programme for a boy with a profound mental handicap living in the community. Ment Handicap. 1991;19(4):146-50.
250 Smith LJ, Franchetti B, McCoull K, et al. A behavioural approach to retraining bowel function after long-standing constipation and faecal impaction in people with learning disabilities. Dev Med Child Neurol. 1994;36(1):41-9. [pmid: 8132113].
251 Smith PS. The development of urinary continence the mentally handicapped. Newcastle upon Tyne: University of Newcastle upon Tyne; 1979.
252 Smith PS. Questions mothers ask about toilet training. Nursing 1980; (18):800–1.
253 Smith PS, Britton PG. Comparison of different methods of toilet training severely and profoundly mentally-handicapped children. Bull Br Psychol Soc. 1978;31:189.
254 Smith PS, Wong H. Changes in bladder function during toilet training of mentally-handicapped children. Bull Br Psychol Soc. 1980;33:209.
255 Song AY, Song RH, Grant PA. Toilet training in the school and its transfer in the living unit. J Behav Ther Exp Psychiatry. 1976;7(3):281-4.
256 Spock B, Bergen M. Parents' fear of conflict: toilet training. Pediatrics. 1964;34:112-6. [pmid: 14181971].
257 Stadler AC, Gorski PA, Brazelton TB. Toilet training methods, clinical interventions, and recommendations. Pediatrics. 1999;103:30.
258 Stadtler AC, Gorski PA, Brazelton TB. Toilet training methods, clinical interventions, and recommendations. American Academy of Pediatrics. Pediatrics. 1999;103(6):1359-68. [pmid: 10353954].
259 Stanley R. Treatment of continence in people with learning disabilities. Br J Nurs. 1996;5(8):492-8. [pmid: 8788463].
260 Stein MT, Alagiri M, Kohen DP. Diurnal and nocturnal enuresis in a 6 year old. J Dev Behav Pediatr. 1998;19(2):105-8. [pmid: 9584940].
261 Stein MT, Barbaresi WJ, Benuck I. An opportunity for office-based research. J Dev Behav Pediatr. 2001;22(1):35-9. [pmid: 11265921].
262 Stenhouse G. Toilet training in children. N Z Med J. 1988;101(842):150-1. [pmid: 3353038].
263 Stephens JA, Silber DL. Parental expectations vs. outcome in toilet training. Pediatrics. 1974;54(4):493-5. [pmid: 4414983].
264 Sterba E. The psychoanalytic study of the child. New York: International Universities Press;1975. Analysis of psychogenic constipation in a two-year-old child. 1949;227–52.
265 Stewart MA. Treatment of bedwetting. JAMA. 1975;232(3):281-3. [pmid: 1173122].
266 Stuecher U. Tommy: a treatment study of an autistic child. Arlington, VA: Council for Exceptional Children; 1972.
267 Sugar E. Bladder control through biofeedback. Am J Nurs. 1983;83(8):1152-4. [pmid: 6554036].
268 Sun M, Rugolotto S. Assisted infant toilet training in a Western family setting. J Dev Behav Pediatr. 2004;25(2):99-101. [pmid: 15083131].
269 Swaffield J. Continence. Social skills for the mentally handicapped. Nurs Times. 1985;81(14):77-9. [pmid: 3846217].
270 Taichert LC. Childhood encopresis: a neurodevelopmental-family approach to management. Calif Med. 1971;115(2):11-8. [pmid: 5563813].
271 Tarbox RS, Williams WL, Friman PC. Extended diaper wearing: effects on continence in and out of the diaper. J Appl Behav Anal. 2004;37(1):97-100. [pmid: 15154222]. [pmcid: 1284484].
272 Taylor S, Cipani E, Clardy A. A stimulus control technique for improving the efficacy of an established toilet training program. J Behav Ther Exp Psychiatry. 1994;25(2):155-60. [pmid: 7983227].
273 Trombini G. Assertion of self-motivational activity in children with respect to eating and toilet training. Prax Kinderpsychol Kinderpsychiatr. 1970;19(1):1-10. [pmid: 5510805].
274 Trott MC. Application of Foxx and Azrin toilet training for the retarded in a school program. Educ Train Ment Retard. 1977;12(4):336-8.
275 Turner AF. Childhood continence problems. Prof Nurse. 1987;2(4):119-21. [pmid: 3644335].
276 van Gool JD, Kuitjen RH, Donckerwolcke RA, et al. Bladder-sphincter dysfunction, urinary infection and vesico-ureteral reflux with special reference to cognitive bladder training. Contrib Nephrol. 1984;39:190-210. [pmid: 6744871].
277 Van Gool JD, Van Wijk AA, de Jong TP. The urge syndrome in children. Acta Urol Belg. 1989;57(2):559-62. [pmid: 2763933].
278 Van Wagenen R, Keith M, Everett E. A transistorized signal-package for toilet training of infants. J Exp Child Psychol. 1966;3(3):312-4.
279 Van Wagenen R. Toilet training retarded - Foxx, RM and Azrin, NH. Behav Ther. 1974;5(2):280-2.
280 Ve Walle J, Theunis M, Renson C, et al. Commercial television bladder dysfunction. Acta Urol Belg. 1995;63(2):105-11. [pmid: 7785531].
281 von Gontard A. Elimination disorders in childhood. How to make children dry and clean. MMW Fortschritte Der Medizin. 2003;145(2728):26-30. [pmid: 14587184].
282 Walker CE, Werstlein R. Use of relaxation procedures in the treatment of toilet phobia in a 4-yr-old child. Behavior Therapist. 1980;3(3):17-8.
283 Walker S. A positive approach. Nurs Times. 1991;87(11):21. [pmid: 2006104].
284 Waszak LC. Nursing interventions with children experiencing elimination difficulties. Psychiatric and Mental Health Nursing With Children and Adolescents. Gaithersburg, MD: Aspen Publishers; 1992. p. 183–98.
285 Watson LS. Applications of behavior-shaping devices to training severely and profoundly mentally retarded children in an institutional setting. Ment Retard. 1968;6(6):21-3. [pmid: 5705586].
286 Watson LS. Toilet training - help for the delayed learner. Am J Ment Defic. 1979;84(1):106.
287 Waye MF, Melnyr WT. Toilet training of a blind retarded boy by operant conditioning. J Behav Ther Exp Psychiatry. 1973;4(3):267-8.
288 Weaver A, Dobson P. Home and dry - some toilet training tips to give parents. J Fam Health Care. 1966;14(3):64. [pmid: 15341372].
289 Wehman P, Bates P. Education curriculum for severely and profoundly handicapped persons: a review. Rehabil Lit. 1978;39(1):2-14. [pmid: 345379].
290 Weintraub DH. Causes of encopresis. Pediatrics. 1991;88(4):877. [pmid: 1896306].
291 Whitehead N. Childhood encopresis - a clinical psychologist's approach. Health Visit. 1983;56(9):335-6. [pmid: 6555183].
292 Williams L. Infant potty training: a gentle and primeval method adapted to modern living. Libr J. 2000;125(12):130.
293 Willingham WK, Marsh C. The tyranny of the diaper. Individual Psychologist. 1978;15(1):20-6.
294 Wilson B. Toilet training the mentally handicapped child. Dev Med Child Neurol. 1980;22(2):225-9. [pmid: 7380122].
295 Wilson M. Generic habit-training program. Focus on Autistic Behavior. 1995;10(2):1-8.
296 Wishart MC, Bidder RT. Enuresis: present trends in treatment. Health Visit. 1981;54(12):532-3. [pmid: 6915029].
297 Wolf M. Application of operant conditioning procedures to the behavior problems of an autistic child: a follow-up and extension. Behav Res Ther. 1967;5(2):103-11. [pmid: 6025711].
298 Woodmansey AC. Emotion and the motions: an inquiry into the causes and prevention of functional disorders of defecation. Br J Med Psychol. 1967;40(3):207-23. [pmid: 6059779].
299 Woods PA, Guest EM. Toilet training the severely retarded: the importance of evaluation. Nurs Times. 1980;76(18):53-6. [pmid: 6900286].
300 Yonovitz A, Michaels R. Electronic toilet-training device. J Appl Behav Anal. 1976;9(2):140.
301 Yonovitz A, Michaels R. Durable, efficient, and economical electronic toilet-training devices for use with retarded children. Behavior Research Methods & Instrumentation. 1977;9(4):356-8.
302 Younger JB, Hughes LS. No-fault management of encopresis. Pediatr Nurs. 1983;9(3):185-7. [pmid: 6552502].
303 Zickler CF, Richardson V. Achieving continence in children with neurogenic bowel and bladder. J Pediatr Health Care. 2004;18(6):276-83. [pmid: 15523417].

## No Toilet Training Intervention

1 Self-directed learning... access and use the appropriate toilet facilities. Nursing & Residential Care 2000;2(1):46–8.
2 Abramson HA. Intractable asthma: conflict of period of toilet training. J Psychol 1961;(52):223–9.
3 Adams MC, Brock JW, Pope JC, et al. Ureterocystoplasty: is it necessary to detubularize the distal ureter?. J Urol. 1998;160(3):851-3. [pmid: 9720574].
4 Adler S. Developmental patterns as a function of ethnicity. J Commun Disord. 1973;6(3):184-92. [pmid: 4776555].
5 Agargun MY, Cilli AS, Sener S, et al. The prevalence of parasomnias in preadolescent school-aged children: a Turkish sample. Sleep. 2004;27(4):701-5. [pmid: 15283005].
6 Agarwal S, Verma T. Development of independency among children by urban & rural mothers. Perspectives in Psychological Researches. 1985;8(2):44-8.
7 Akhtar J, Brohi AR, Aziz A. Pattern and development of bowel control in children. J Coll Physicians Surg Pak 1999;(5):209–10.
8 Akis N, Irgil E, Aytekin N. Enuresis and the effective factors—a case-control study. Scand J Urol Nephrol. 2002;36(3):199-203. [pmid: 12201935].
9 Al-Harbi SM, Needlman RD, Khan AS, et al. Intensive behavioral therapy for primary enuresis. Saudi Med J. 2004;25(7):934-40. [pmid: 15235703].
10 Allen C. Management of constipation in children. Community Nurse. 1998;4(2):39. [pmid: 9555343].
11 Alper TG, Blane HT, Abrams BK. Reactions of middle and lower class children to finger paints as a function of class differences in childtraining practices. J Abnorm Soc Psychol 1955; (51):439–48.
12 Amendola S, De Angelis P, Dall'oglio L, et al. Combined approach to functional constipation in children. J Pediatr Surg. 2003;38(5):819-23. [pmid: 12720201].
13 Angliss VE. Habilitation of upper-limb-deficient children. Am J Occup Ther. 1974;28(7):407-14. [pmid: 4841655].
14 Austin A. Maternal attitudes and the development of learning disabilities in black children. Smith Coll Stud Soc Work. 1970;40(3):198-210.
15 Awad GA. An outpatient treatment program for young children with pervasive developmental disorder. Am J Psychother. 1995;49(1):28-46. [pmid: 7762697].
16 Bakker E, van Gool J, Wyndaele JJ. Results of a questionnaire evaluating different aspects of personal and familial situation, and the methods of potty-training in two groups of children with a different outcome of bladder control. Scand J Urol Nephrol. 2001;35(5):370-6. [pmid: 11771863].
17 Bakker E, Wyndaele JJ. Changes in the toilet training of children during the last 60 years: the cause of an increase in lower urinary tract dysfunction?. BJU Int. 2000;86(3):248-52. [pmid: 10930924].
18 Banerjee K, Curtis E, de San Lazaro C, et al. Low prevalence of genital candidiasis in children. Eur J Clin Microbiol Infect Dis. 2004;23(9):696-8. [pmid: 15316856].
19 Barbour RF, Beedell CJ. The follow-up of a child guidance clinic population. Br J Psychiatry 1955;(101):794–809.
20 Barsch RH. Rearing practices of parents of children with cerebral palsy: toilet training. Cereb Palsy Rev. 1962;23(5):12-6.
21 Bartkowski DP. Current diagnosis and management of urinary tract infections in infants and children. Compr Ther. 2003;29:102-7. [pmid: 14606339].
22 Bell B, Miller W. Child-rearing practices reported by schoolchildren in Bavaria. J Soc Psychol. 1982;117(1):13-8.
23 Belman AB. Urinary tract infection, wetting, and constipation. Pediatrics. 1998;102(1):158. [pmid: 9714643].
24 Bemporad JR, Pfeifer CM, Gibbs L, et al. Characteristics of encopretic patients and their families. J Am Acad Child Psychiatry. 1971;10(2):272-92. [pmid: 5113190].
25 Bergan ME. Parental attitudes toward toilet training. Soc Casework. 1964;45(6):346-50.
26 Bernard-Bonnin AC, Haley N, Belanger S, et al. Parental and patient perceptions about encopresis and its treatment. J Dev Behav Pediatr. 1993;14(6):397-400. [pmid: 8126233].
27 Bernstein A. Some relations between techniques of feeding and training during infancy and certain behavior in childhood. Genet Psychol Monogr 1955; (51):3–44.
28 Berquist WE. Biofeedback therapy for anorectal disorders in children. Semin Pediatr Surg. 1995;4(1):48-53. [pmid: 7728508].
29 Blair A. Patterns of infant care in Lesotho. Diss Abstr Int 1987:3168.
30 Bloom DA, Seeley WW, Ritchey ML, et al. Toilet habits and continence in children: an opportunity sampling in search of normal parameters.[erratum appears in J Urol 1993 Dec;150(6):1924]. J Urol. 1993;149(5):1087-90. [pmid: 8483218].
31 Blum NJ, Taubman B. During toilet training, constipation occurs prior to stool toileting refusal. J Dev Behav Pediatr. 2002;23(5):402.
32 Blum NJ, Taubman B, Nemeth N. Earlier initiation of toilet training leads to earlier completion. Pediatr Res. 2002;51(4):23A.
33 Blum NJ, Taubman B, Osborne ML. Behavioral characteristics of children with stool toileting refusal. Pediatrics. 1997;99(1):50-3. [pmid: 8989337].
34 Blumberg RS. Naturally occurring toilet training practices. Diss Abstr Int 1985:1353.
35 Bollard J. A 2-year follow-up of bedwetters treated by dry-bed training and standard conditioning. Behav Res Ther. 1982;20(6):571-80. [pmid: 7159353].
36 Borer JG, Bauer SB, Peters CA, et al. A single-system ectopic ureter draining an ectopic dysplastic kidney: delayed diagnosis in the young female with continuous urinary incontinence. Br J Urol. 1998;81(3):474-8. [pmid: 9523673].
37 Borowitz SM, Cox DJ, Sutphen JL. Differences in toileting habits between children with chronic encopresis, asymptomatic siblings, and asymptomatic nonsiblings. J Dev Behav Pediatr. 1999;20(3):145-9. [pmid: 10393070].
38 Borowitz SM, Cox DJ, Tam A, et al. Precipitants of constipation during early childhood. J Am Board Fam Pract. 2003;16(3):213-8. [pmid: 12755248].
39 Bostock J, Shackleton MG. Enuresis and toilet training. Med J Aust. 1951;2(4):110-3. [pmid: 14874716].
40 Brauch DW. Therapeutic procedures as part of the educative process. J Consult Psychol 1940; (4):165–72.
41 Bryan DP. An investigation of the adaptations and retentions of Nigerian child-rearing practices made by selected Nigerian parents residing temporarily in the Washington, D.C., metropolitan area. Diss Abstr Int 1980:996.
42 Buchanan A. The treatment and management of soiling children (toilet training). Diss Abstr Int 1990:4614.
43 Butler RJ, Brewin CR, Forsythe WI. A comparison of two approaches to the treatment of nocturnal enuresis and the prediction of effectiveness using pre-treatment variables. J Child Psychol Psychiatry. 1988;29(4):501-9. [pmid: 3215921].
44 Canty TG. Modified Duhamel procedure for treatment of Hirschsprung's disease in infancy and childhood: review of 41 consecutive cases. J Pediatr Surg. 1982;17(6):773-8. [pmid: 6761416].
45 Carrico C, Lebowitz RL. Incontinence due to an infrasphincteric ectopic ureter: why the delay in diagnosis and what the radiologist can do about it. Pediatr Radiol. 1998;28(12):942-9. [pmid: 9880638].
46 Chen CC, Lin CL, Lu WT, et al. Anorectal function and endopelvic dissection in patients with repaired imperforate anus. Pediatr Surg Int. 1998;13:133-7. [pmid: 9563025].
47 Chess ST, Alexer BH. Characteristics of the individual child's behavioral responses to the environment. Am J Orthopsychiatry 1959;791–802.
48 Christmanson L, Lisper HO. Parent behaviors related to bed-wetting and toilet-training as etiological factors in primary enuresis. Scand J Behav Ther. 1982;11(1):29-37.
49 Chu C. A study of the effects of maternal employment for the preschool children in Taiwan. Yan Jiu Bao Gao 1970;12–3:80–100.
50 Cocchi R. Toilet habits in Downs: a survey on 492 subjects. Ital J Intellective Impairment 1996;9(1):13–25, 75–87.
51 Cocchi R. Toilet habits in drugs treated Downs: a survey on 209 subjects. Ital J Intellective Impairment. 1997;10(1):13-7.
52 Cohen TB. Prediction of under-achievement in kindergarten children. Arch Gen Psychiatry. 1963;9(5):444-50. [pmid: 14077226].
53 Comings DE, Comings BG. A controlled study of Tourette syndrome. VI. Early development, sleep problems, allergies, and handedness. Am J Hum Genet. 1987;41(5):822-38. [pmid: 3479017]. [pmcid: 1684348].
54 Cooper CS, Abousally CT, Austin JC, et al. Do public schools teach voiding dysfunction? Results of an elementary school teacher survey. J Urol. 2003;170(3):956-8. [pmid: 12913750].
55 Cooper DG. Detrusor action in children with myelomeningocele. Arch Dis Child. 1968;43(230):427-32. [pmid: 5661872]. [pmcid: 2020001].
56 Couchells SM, Johnson SB, Carter R, et al. Behavioral and environmental characteristics of treated and untreated enuretic children and matched nonenuretic controls. J Pediatr. 1981;99(5):812-6. [pmid: 7299564].
57 Cox DJ, Ritterb LM, Quillian W, et al. Assessment of behavioral mechanisms maintaining encopresis: Virginia Encopresis-Constipation Apperception Test. J Pediatr Psychol. 2003;28(6):375-82. [pmid: 12904449].
58 Cox DJ, Sutphen J, Borowitz S, et al. Contribution of behavior therapy and biofeedback to laxative therapy in the treatment of pediatric encopresis. Ann Behav Med. 1998;20(2):70-6. [pmid: 9989311].
59 Cox DJ, Sutphen J, Ling W, et al. Additive benefits of laxative, toilet training, and biofeedback therapies in the treatment of pediatric encopresis. J Pediatr Psychol. 1996;21(5):659-70. [pmid: 8936895].
60 Croudace TJ, Jarvelin MR, Wadsworth ME, et al. Developmental typology of trajectories to nighttime bladder control: epidemiologic application of longitudinal latent class analysis. Am J Epidemiol. 2003;157(9):834-42. [pmid: 12727677].
61 Cucchiara S, Coremans G, Staiano A, et al. Gastrointestinal transit time and anorectal manometry in children with fecal soiling. J Pediatr Gastroenterol Nutr. 1984;3(4):545-50. [pmid: 6481564].
62 Cunningham C, Taylor HG, Minich NM, et al. Constipation in very-low-birth-weight children at 10 to 14 years of age. J Pediatr Gastroenterol Nutr. 2001;33(1):23-7. [pmid: 11479403].
63 D'Amato E, Yoshida RK. Parental needs: an educational life cycle perspective. J Early Interv. 1991;15(3):246-54.
64 Dahl J, Lindquist BL, Tysk C, et al. Behavioral medicine treatment in chronic constipation with paradoxical anal sphincter contraction. Dis Colon Rectum. 1991;34(9):769-76. [pmid: 1914742].
65 Danziger K. Parental demands and social class in Java, Indonesia. J Soc Psychol 1960;75–86.
66 Davis A, Havighurst RJ. Social class and color differences in child-rearing. Am Sociol Rev 1946; (11):698–710.
67 De Paepe H, Hoebeke P, Renson C, et al. Pelvic-floor therapy in girls with recurrent urinary tract infections and dysfunctional voiding. Br J Urol. 1998;81(Suppl 3):109-13. [pmid: 9634033].
68 Dimson SB. Toilet training and enuresis. Brookhaven Symp Biol. 1959;5153:666-70.
69 Dolva AS, Coster W, Lilja M. Functional performance in children with Down syndrome. Am J Occup Ther. 2004;58(6):621-9. [pmid: 15568546].
70 Doran J, Lister A. Toilet training: meeting the needs of children and parents. Community Pract. 1998;71(5):179-80.
71 Drabman R, Spitalnik R, Hagamen MB, et al. The five-two program: an integrated approach to treating severely disturbed children. Hosp Community Psychiatry. 1973;24(1):33-6. [pmid: 4704625].
72 Duker PC, Averink M, Melein L. Response restriction as a method to establish diurnal bladder control. Am J Ment Retard. 2001;106(3):209-15. [pmid: 11389663].
73 Edwards SD, Van der Spuy HI. Hypnotherapy as a treatment for enuresis. Journal of Child Psychology and Psychiatry. 1985;26(1):161-70. [pmid: 3972929].
74 Eisen AR, Silverman WK. Treatment of an adolescent with bowel movement phobia using self-control therapy. J Behav Ther Exp Psychiatry. 1991;22(1):45-51. [pmid: 1918392].
75 El-Sherbiny MT. Tubularized incised plate repair of distal hypospadias in toilet-trained children: should a stent be left?. BJU Int. 2003;92(9):1003-5. [pmid: 14632864].
76 Etele-Hainz A, Artens E, Marberger M. Therapy concept in enuretic children. Eur Urol. 1998;33(Suppl 3):49-52. [pmid: 9599739].
77 Eyman RK. Effects of treatment programs on the acquisition of basic skills. Am J Ment Defic. 1975;79(5):573-82. [pmid: 1121986].
78 Fahmy MA, Ezzelarab S. Outcome of submucosal injection of different sclerosing materials for rectal prolapse in children. Pediatr Surg Int. 2004;20(5):353-6. [pmid: 15168050].
79 Farrell M, Devine K, Lancaster G, et al. A method comparison study to assess the reliability of urine collection pads as a means of obtaining urine specimens from non-toilet-trained children for microbiological examination. J Adv Nurs. 2002;37(4):387-93. [pmid: 11872109].
80 Fielding D. Factors associated with drop-out, relapse and failure in the conditioning treatment of nocturnal enuresis. Behavioural Psychotherapy. 1985;13(3):174-85.
81 Fishman L, Rappaport L, Cousineau D, et al. Early constipation and toilet training in children with encopresis. J Pediatr Gastroenterol Nutr. 2002;34(4):385-8. [pmid: 11930094].
82 Fishman L, Rappaport L, Schonwald A, et al. Trends in referral to a single encopresis clinic over 20 years. Pediatrics. 2003;111(5):e604-7. [pmid: 12728118].
83 Ford J. Continence - targets and rewards. Nurs Times. 1998;94(6):61-4. [pmid: 9528579].
84 Foreman DM, Thambirajah MS. Conduct disorder, enuresis and specific developmental delays in two types of encopresis: a case-note study of 63 boys. Eur Child Adolesc Psychiatry. 1996;5(1):33-7. [pmid: 9117537].
85 Freedman AL, Johnson MP, Smith CA, et al. Long-term outcome in children after antenatal intervention for obstructive uropathies. Lancet. 1999;354(9176):374-7. [pmid: 10437866].
86 Fritz GK, Ers TF. Enuresis: the clinical application of an etiologically based classification system. Child Psychiatry Hum Dev. 1979;10(2):103-13. [pmid: 527389].
87 Fuchs N, Rogers. Play therapy at home. Merrill-Palmer Quarterly 1957;(3):89–95.
88 Garber M, Perry M, Szawlowski L. Analysis of the parent outreach program. Journal on Developmental Disabilities. 1994;3(1):74-85.
89 Garfield A, Shakespeare R. A psychological and developmental study of mentally retarded children with cerebral palsy. Dev Med Child Neurol. 1964;6(5):485-94. [pmid: 14215226].
90 Gassman DJ. Prediction of toileting skills acquisition in the profoundly mentally retarded. Diss Abstr Int 1985:1683.
91 Geleerd ER. Mothering, feeding and toilet training in infants. Bull Menninger Clin 1944;(8):178–84.
92 Graziottin A, Chiozza ML. Nocturnal enuresis: social aspects and treatment perspectives in Italy - a preliminary report. Scand J Urol Nephrol Suppl. 1994;163:21-8. [pmid: 7878381].
93 Gumus B, Vurgun N, Lekili M, et al. Prevalence of nocturnal enuresis and accompanying factors in children aged 7–11 years in Turkey. Acta Paediatr. 1999;88(12):1369-72. [pmid: 10626524].
94 Gustafson R. Conditioning treatment of children's bedwetting: a follow-up and predictive study. Psychol Rep. 1993;72(3):923-30. [pmid: 8332696].
95 Guteilus MF, Kirsch AD, MacDonald S, et al. Controlled study of child health supervision: behavioral results. Pediatrics. 1977;60(3):294-304. [pmid: 896359].
96 Hackett L, Hackett R. Child-rearing practices and psychiatric disorder in Gujarati and British children. Br J Soc Work. 1994;24(2):191-202.
97 Hackett R, Hackett L, Bhakta P, et al. Enuresis and encopresis in a south Indian population of children. Child Care Health Dev. 2001;27(1):35-46. [pmid: 11136340].
98 Hammouda HM, El-Ghoneimi A, Bagli DJ, et al. Tubularized incised plate repair: functional outcome after intermediate followup. J Urol. 2003;169(1):331-3. [pmid: 12478185].
99 Hammouda HM, Kotb H. Complete primary repair of bladder exstrophy: initial experience with 33 cases. J Urol. 2004;172(4):1441-4. [pmid: 15371864].
100 Harjai MM, Puri B, Vincent PJ, et al. Fecal incontinence after posterior sagittal anorectoplasty - Follow up of 2 years. Armed Forces Med J India. 2003;59(3):194-6.
101 Hauck MR. Factors influencing toileting behaviors in toddlers. Milwaukee: University of Wisconsin-Milwaukee;1988.
102 Havighurst RJ, Davis A. A comparison of the Chicago and Harvard studies of social class differences in child rearing. Am Sociol Rev 1955;(20):438–42.
103 Hein HA, Beerends JJ. Who should accept primary responsibility for the encopretic child? A successful pediatric program based on dietary control, bowel training, and family counseling. Clin Pediatr. 1978;17(1):67-70.
104 Hetherington EM, Brackbill Y. Etiology and covariation of obstinacy, orderliness, and parsimony in young children. Child Dev. 1963;34(4):919-43. [pmid: 14082909].
105 Hindley CB. Some differences in infant feeding and elimination training in five European longitudinal samples. J Child Psychol Psychiatry. 1965;6(34):179-201.
106 Hindley CB. Growing up in five countries: a comparison of data on weaning, elimination training, age of walking and IQ in relation to social class from European longitudinal studies. Dev Med Child Neurol. 1968;10(6):715-24. [pmid: 5715649].
107 Hinman A, Dickey LB. Breath-holding spells. AMA Am J Dis Child 1956; (91):23–33.
108 Hinman F Jr. Nonneurogenic neurogenic bladder (the Hinman syndrome) - 15 years later. J Urol. 1986;136(4):769-77. [pmid: 3761428].
109 Hinman F Jr, Baumann FW. Complications of vesicoureteral operations from incoordination of micturition. J Urol. 1976;116(5):638-43. [pmid: 978818].
110 HiraSing RA, van Leerdam FJ, Bolk-Bennink LF, et al. Effect of dry bed training on behavioural problems in enuretic children. Acta Paediatr. 2002;91(8):960-4. [pmid: 12222722].
111 Hoebeke P, Vande Walle J, Theunis M, et al. Outpatient pelvic-floor therapy in girls with daytime incontinence and dysfunctional voiding. Urology. 1996;48(6):923-7. [pmid: 8973679].
112 Holmdahl G, Sillen U, Hellstrom AL, et al. Does treatment with clean intermittent catheterization in boys with posterior urethral valves affect bladder and renal function?. J Urol. 2003;170(4):1681-5. [pmid: 14501691].
113 Holverstott-Cockrell K. The role of symbolic modeling, rule governed behavior and positive reinforcement in the form of bibliotherapy to eliminate diurnal enuresis in young non-handicapped children. Ypsilanti: Eastern Michigan University; 1997.
114 Holway AR. Early self-regulation of infants and later behavior in play interviews. Am J Orthopsychiatry 1949;(19):612–23.
115 Horn IB, Brenner R, Cheng TL. Beliefs about initiation of toilet training - Are there sets or racial differences?. Pediatr Res. 2004;55(4):85A. [pmid: 14561786].
116 Houts AC, Mellon MW, Whelan JP. Use of dietary fiber and stimulus control to treat retentive encopresis: a multiple baseline investigation. J Pediatr Psychol. 1988;13(3):435-45. [pmid: 2848942].
117 Isohanni M, Jones PB, Moilanen K, et al. Early developmental milestones in adult schizophrenia and other psychoses. A 31-year follow-up of the northern Finland 1966 birth cohort. Schizophr Res. 2001;52(12):1-19. [pmid: 11595387].
118 Javid PJ, Barnhart DC, Hirschl RB, et al. Immediate and long-term results of surgical management of low imperforate anus in girls. J Pediatr Surg. 1998;33(2):198-203. [pmid: 9498386].
119 Jenak R, Ludwikowski B, Gonzalez R. Total urogenital sinus mobilization: a modified perineal approach for feminizing genitoplasty and urogenital sinus repair. J Urol. 2001;165(6):2347-9. [pmid: 11371975].
120 Joshi MC, Daharwal A. Child rearing practices and personality of Satnaamee children. Indian Psychol Rev. 1977;15(1):7-12.
121 Joshi MC, Tiwari J. Personality development of children in relation to child-rearing practices among socio-economic classes. Indian Psychol Rev. 1977;14(4):5-16.
122 Karr C, Wesley F. Comparison of German and U.S. child-rearing practices. Child Dev. 1966;37(3):715-23. [pmid: 5970588].
123 Kawauchi A, Tanaka Y, Yamao Y, et al. Follow-up study of bedwetting from 3 to 5 years of age. Urology. 2001;58(5):772-6. [pmid: 11711360].
124 Kempe A, Dempsey C, Poole SR. Introduction of a recorded health information line into a pediatric practice. Arch Pediatr Adolesc Med. 1999;153(6):604-10. [pmid: 10357301].
125 Keshtgar AS, Ward HC, Clayden GS, et al. Role of anal dilatation in treatment of idiopathic constipation in children: long-term follow-up of a double-blind randomized controlled study. Pediatr Surg Int. 2005;21(2):100-5. [pmid: 15662516].
126 Kierman CC, Wright EC. Behavior modification with the severely mentally handicapped. The F6 Project - a preliminary report. Proc R Soc Med. 1973;66(11):1137-40. [pmid: 4777039]. [pmcid: 1645229].
127 Kigo CN, Ndung'u JM. Bowel function following primary repair of anorectal malformations at Kenyatta National Hospital. East Afr Med J. 2002;79(3):124-7. [pmid: 12389955].
128 Klackenberg G. Expectations and reality concerning toilet training. Acta Paediatr Scand. 1965;54(6):616.
129 Klackenberg G. Nocturnal enuresis in a longitudinal perspective. A primary problem of maturity and/or a secondary environmental reaction?. Acta Paediatr Scand. 1981;70(4):453-7. [pmid: 7315288].
130 Klatskin EH. Shifts in child care practices in three social classes under an infant care program of flexible methodology. Am J Orthopsychiatry 1952;(22):52–61.
131 Koff SA, Murtagh D. The uninhibited bladder in children: effect of treatment on vesicoureteral reflux resolution. Contrib Nephrol. 1984;39:211-20. [pmid: 6744872].
132 Kolvin I, Taunch J, Currah J, et al. Enuresis: a descriptive analysis and a controlled trial. Dev Med Child Neurol. 1972;14(6):715-26. [pmid: 4643436].
133 Kurita H. Variables relating to the mental development of children with infantile autism. Jpn J Psychiatry Neurol. 1986;40(2):161-8. [pmid: 2431182].
134 Lal R, Bhatnagar V, Agarwala S, et al. Urodynamic evaluation in boys treated for posterior urethral valves. Pediatr Surg Int. 1999;15(56):358-62. [pmid: 10415286].
135 Largo RH, Molinari L, von Siebenthal K, et al. Does a profound change in toilet-training affect development of bowel and bladder control?. Dev Med Child Neurol. 1996;38(12):1106-16. [pmid: 8973296].
136 Largo RH, Molinari L, von Siebenthal K, et al. Development of bladder and bowel control: significance of prematurity, perinatal risk factors, psychomotor development and gender. Eur J Pediatr. 1999;158(2):115-22. [pmid: 10048607].
137 Largo RH, Stutzle W. Longitudinal study of bowel and bladder control by day and at night in the first six years of life. II: the role of potty training and the child's initiative. Dev Med Child Neurol. 1977;19(5):607-13. [pmid: 913901].
138 Lee SL, Rowell S, Greenholz SK. Therapeutic cecostomy tubes in infants with imperforate anus and caudal agenesis. J Pediatr Surg. 2002;37(3):345-7. [pmid: 11877645].
139 Levine MD, Bakow H. Children with encopresis: a study of treatment outcome. Pediatrics. 1976;58(6):845-52. [pmid: 995511].
140 Lewis G, Rudolph CD. Practical approach to defecation disorders in children. Pediatr Ann. 1997;26(4):260-8. [pmid: 9114445].
141 Liebman WM. Disorders of defecation in children: evaluation and management. Postgrad Med. 110;66(2):105-8. [pmid: 450820].
142 Liu X, Sun Z, Uchiyama M, et al. Attaining nocturnal urinary control, nocturnal enuresis, and behavioral problems in Chinese children aged 6 through 16 years. J Am Acad Child Adolesc Psychiatry. 2000;39(12):1557-64. [pmid: 11128334].
143 Loening-Baucke V. Constipation in early childhood: patient characteristics, treatment, and longterm follow up. Gut. 1993;34(10):1400-4. [pmid: 8244110]. [pmcid: 1374550].
144 Loening-Baucke V. Toilet tales: stool toileting refusal, encopresis, and fecal incontinence. J Wound Ostomy Continence Nurs. 1998;25(6):304-13. [pmid: 9919146].
145 Loening-Baucke VA. Abnormal rectoanal function in children recovered from chronic constipation and encopresis. Gastroenterology. 1984;87(6):1299-304. [pmid: 6092198].
146 Lohmann W, Eyman RK, Lask E. Toilet Training. Am J Ment Defic. 1967;71(4):551-7. [pmid: 6033111].
147 Ludwikowski B, Oesch HI, Gonzalez R. Total urogenital sinus mobilization: expanded applications. BJU Int. 1999;83(7):820-2. [pmid: 10368205].
148 Luxem MC, Christophersen ER, Purvis PC, et al. Behavioral-medical treatment of pediatric toileting refusal. Kansas: University of Kansas; 1994. In: ProQuest Digital Dissertations [database on the Internet][cited 2006 Jun 12]. Available from: www.proquest.com/; Publication No. AAT 9528389.
149 Luxem MC, Christophersen ER, Purvis PC, et al. Behavioral-medical treatment of pediatric toileting refusal. J Dev Behav Pediatr. 1997;18(1):34-41. [pmid: 9055148].
150 Mahoney K. Frequency and quantity of nocturnal urinary emissions after diurnal toilet training and after training to restrain reflex voiding in children. [dissertation]. Arizona: Arizona State University; 1973. In: ProQuest Digital Dissertations [database on the Internet][cited 2006 Jun 12]. Available from: www.proquest.com/; Publication No. AAT 7321892.
151 Malone CA. The drifters. Children of disorganized lower-class families. Guideposts derived from normal development. Int Psychiatry Clin. 1967;4(4):85-103. [pmid: 5592745].
152 Margolies R. Family concept factors mediating dysfunction in families with an encopretic child (typology)[dissertation]. New York: Fordham University; 1984. In: ProQuest Digital Dissertations [database on the Internet][cited 2006 Jun 12]. Available from: www.proquest.com/; Publication No. AAT 8506347.
153 Martin JA, King DR, Maccoby EE, et al. Secular trends and individual differences in toilet-training progress. J Pediatr Psychol. 1984;9(4):457-67. [pmid: 6520660].
154 McClell DC, Pilon DA. Sources of adult motives in patterns of parent behavior in early childhood. J Pers Soc Psychol. 1983;44(3):564-74.
155 Mell F, McClain M, Reece R. The sudden infant death syndrome. Siblings and their place in the family. Annals of the New York Academy of Sciences. Vol. 533 1988;533:129–31.
156 Menolascino FJ. Changing developmental perspectives in Down's syndrome. Child Psychiatry & Human Development. 1974;4(4):205-15. [pmid: 4278025].
157 Mingin GC, Hinds A, Nguyen HT, et al. Children with a febrile urinary tract infection and a negative radiologic workup: factors predictive of recurrence. Urology. 2004;63(3):562-5. [pmid: 15028458].
158 Nauck B. Intergenerational relationships in families from Turkey and Germany. An extension of the ‘Value of Children’ approach to educational attitudes and socialization practices. Eur Sociol Rev. 1989;5(3):251-74.
159 Nijman RJ. Role of antimuscarinics in the treatment of nonneurogenic daytime urinary incontinence in children. Urology. 2004;63(3 Suppl 1):45-50. [pmid: 15013652].
160 Ninio A. The naive theory of the infant and other maternal attitudes in two subgroups in Israel. Child Dev. 1979;50(4):976-80. [pmid: 535448].
161 Norton C. Incontinence can be prevented at all ages. Prof Nurse. 1988;4(1):22-6. [pmid: 3200868].
162 O H, Yoshimura I, Wakabayashi S. Effects of age on adaptive behavior levels and academic skill levels in autistic and mentally retarded children. J Autism Dev Disord. 1980;10(2):173-84. [pmid: 6927685].
163 O'Moore M. Living with autism. Irish J Psychol. 1978;4(1):33-52.
164 Ojha H, Pramanick M. Religio-cultural variation in childrearing practices. Psychol Stud. 1992;37(1):65-72.
165 Okamoto GA, Sousa J, Telzrow RW, et al. Toileting skills in children with myelomeningocele: rates of learning. Arch Phys Med Rehabil. 1984;65(4):182-5. [pmid: 6712436].
166 Olson LM, Inkelas M, Halfon N, et al. Overview of the content of health supervision for young children: reports from parents and pediatricians. Pediatrics. 2004;113(6):1907-16. [pmid: 15173461].
167 Oppel WC, Harper PA, Rider RV. The age of attaining bladder control. Pediatrics. 1968;42(4):614-26. [pmid: 5681280].
168 Ottenbacher K, Malter R, Weckwerth L. A toilet seat arrangement for children with neuromotor dysfunction. Am J Occup Ther. 1979;33(3):193. [pmid: 474335].
169 Pachter LM, Dworkin PH. Maternal expectations about normal child development in 4 cultural groups. Arch Pediatr Adolesc Med. 1997;151(11):1144-50. [pmid: 9369877].
170 Parker AL. Reinforcement: one teacher's experiences and experiments with multiply handicapped blind children. New Outlook for the Blind. 1971;65(3):97-9.
171 Pathania R, Chaudhary N. Toilet training practices among mothers of Chandigarh City. Indian Journal of Behaviour. 1993;17(3):1-4.
172 Pathania R, Chaudhary N. Relationship of toilet training and weaning practices to personality of children. J Hum Ecol. 1997;8(4):297-9.
173 Pattaras JG, Rushton HG, Majd M. The role of ^99m^technetium dimercapto-succinic acid renal scans in the evaluation of occult ectopic ureters in girls with paradoxical incontinence. J Urol. 1999;162(3):821-5. [pmid: 10458388].
174 Pensabene L, Nurko S. Management of fecal incontinence in children without functional fecal retention. Curr Treat Options Gastroenterol. 2004;7(5):381-90. [pmid: 15345209].
175 Piyasil V, Udomsup J. Enuresis in children 5–15 years at Queen Sirikit National Institute of Child Health. J Med Assoc Thai. 2002;85(1):11-5. [pmid: 12075710].
176 Quisumbing LR. Child-rearing practices in the Cebuano extended family. Philipp Sociol Rev. 1964;12(01-Feb):109-14.
177 Rasromani KH, Kamath BM. Current experience with Boley's endorectal pull-through. Bahrain Medical Bulletin. 1990;12(1):25-7.
178 Rhodes C. Effective management of daytime wetting. Paediatr Nurs. 2000;12(2):14-7. [pmid: 11220839].
179 Rintala RJ, Lindahl HG, Rasanen M. Do children with repaired low anorectal malformations have normal bowel function?. J Pediatr Surg. 1997;32(6):823-6. [pmid: 9200078].
180 Rockney RM, McQuade WH, Days AL. The plain abdominal roentgenogram in the management of encopresis. Arch Pediatr Adolesc Med. 1995;149(6):623-7. [pmid: 7767416].
181 Rogers J. Transforming children's lives. Interview by Alison Moore. Nurs Stand. 1997;12(135):30-1. [pmid: 9482977].
182 Rogers J. Continence - lessons in control. Nurs Times. 1998;94(6):66-8. [pmid: 9528580].
183 Ronen T, Abraham Y. Retention control training in the treatment of younger versus older enuretic children. Nurs Res. 1996;45(2):78-82. [pmid: 8604368].
184 Ross JH, Kay R. Pediatric urinary tract infection and reflux. Am Fam Physician. 1999;59(6):1472-8. [pmid: 10193590].
185 Rubin G. Constipation. Clin Evid 2002;(7):292–6.
186 Samuel M, Capps S. Staged proximal hypospadias repair: modified thiersch duplay with midline incision in urethral plate followed by Mathieu urethroplasty. J Pediatr Surg. 2002;37(1):104-7. [pmid: 11781997].
187 Samuel M, Capps S, Worth A. Proximal hypospadias. Comparative evaluation of staged urethroplasty (modified Thiersch Duplay followed by Mathieu) and single stage on-lay island flap repair. Eur Urol. 2001;40(4):463-8. [pmid: 11713404].
188 Samuel M, Capps S, Worthy A. Distal hypospadias: which repair?. BJU Int. 2002;90(1):88-91. [pmid: 12081777].
189 Sarica K, Erbagci A, Yagci F, et al. Multidisciplinary evaluation of occult spinal dysraphism in 47 children. Scand J Urol Nephrol. 2003;37(4):329-34. [pmid: 12944192].
190 Schonwald A, Sherritt L, Stadtler A, et al. Factors associated with difficult toilet training. Pediatrics. 2004;113(6):1753-7. [pmid: 15173502].
191 Schum TR, Kolb TM, McAuliffe TL, et al. Sequential acquisition of toilet-training skills: a descriptive study of gender and age differences in normal children. Pediatrics. 2002;109(3):E48. [pmid: 11875176].
192 Schum TR, McAuliffe TL, Simms MD, et al. Factors associated with toilet training in the 1990s. Ambul Pediatr. 2001;1(2):79-86. [pmid: 11888377].
193 Sears R, Maccoby E, Levin H. Patterns of child rearing. New York: Harper & Row;1957.
194 Seim HC. Toilet training in first children. J Fam Pract. 1989;29(6):633-6. [pmid: 2592922].
195 Shaikh N, Hoberman A, Wise B, et al. Dysfunctional elimination syndrome: is it related to urinary tract infection or vesicoureteral reflux diagnosed early in life?. Pediatrics. 2003;112(5):1134-7. [pmid: 14595058].
196 Shankar KR, Vishwanath N, Rickwood AM. Outcome of patients with prenatally detected duplex system ureterocele; natural history of those managed expectantly. J Urol. 2001;165(4):1226-8. [pmid: 11257689].
197 Shatkin JP. Atomoxetine for the treatment of pediatric nocturnal enuresis. J Child Adolesc Psychopharmacol. 2004;14(3):443-7. [pmid: 15650501].
198 Shaw J. Continence in cerebral palsy. Health Visit. 1990;63(9):301-2. [pmid: 2211140].
199 Sillen U. Bladder function in healthy neonates and its development during infancy. J Urol. 2001;166(6):2376-81. [pmid: 11696790].
200 Snodgrass W. The impact of treated dysfunctional voiding on the nonsurgical management of vesicoureteral reflux. J Urol. 1998;160(5):1823-5. [pmid: 9783967].
201 Spiller HA, Winter ML, Weber JA, et al. Skin breakdown and blisters from senna-containing laxatives in young children. Ann Pharmacother. 2003;37(5):636-9. [pmid: 12708936].
202 Stadtler AC. Preventing encopresis. Pediatr Nurs. 1989;15(3):282-4. [pmid: 2734045].
203 Stadtler AC, Burke P. A group treatment approach to failure to toilet train: the case of Max. Clin Excell Nurse Pract. 1998;2(2):83-7. [pmid: 10451268].
204 Stanford A, Upperman JS, Boyle P, et al. Long-term follow-up of patients with necrotizing enterocolitis. J Pediatr Surg. 2002;37(7):1048-50. [pmid: 12077769].
205 Stanley R. Treatment of continence in people with learning disabilities. Br J Nurs. 1997;6(1):12-4. [pmid: 9015995].
206 Stark M. Assessment and management of the care of children with nocturnal enuresis: guidelines for primary care. Nurse Pract Forum. 1994;5(3):170-6. [pmid: 7950497].
207 Stehbens JA. Comparison of MMPI scores of mothers of enuretic and control children. J Clin Psychol. 1970;26(4):496. [pmid: 4397717].
208 Stehbens JA, Silber DL. Parental expectations in toilet training. Pediatrics. 1971;48(3):451-4. [pmid: 5094347].
209 Stein MT, Graziano A, Howard B, et al. Maria: stubborn, willful, and always full of energy. J Dev Behav Pediatr. 1996;17(4):262-6. [pmid: 8856524].
210 Stoneking BJ, Brock JW, Pope JC, et al. Early evolution of bladder emptying after myelomeningocele closure. Urology. 2001;58(5):767-71. [pmid: 11711357].
211 Takahashi E. Investigation of the age of release from the diaper environment. Pediatrician. 1987;14(Suppl 1):48-52. [pmid: 3601831].
212 Taubman B, Buzby M. Overflow encopresis and stool toileting refusal during toilet training: a prospective study on the effect of therapeutic efficacy. J Pediatr. 1997;131(5):768-71. [pmid: 9403665].
213 Tavormina JB, Henggeler SW, Gayton WF. Age trends in parental assessments of the behavior problems of their retarded children. Ment Retard. 1976;14(1):38-9. [pmid: 1250150].
214 Treffert DA, McAndrew JB, Dreifuerst P. An inpatient treatment program and outcome for 57 autistic and schizophrenic children. J Autism Child Schizophr. 1973;3(2):138-53. [pmid: 4800387].
215 Treharne DA. Parental recall of children's early development. Eur J Disord Commun. 1992;27(3):221-30. [pmid: 1306388].
216 Umphress A, Murphy S, Nickols J, et al. Adolescent enuresis. A sociological study of family interaction. Arch Gen Psychiatry. 1970;22(3):237-44. [pmid: 5413272].
217 Unal F, Pehlivanturk B. Comorbid psychiatric disorders in 201 cases of encopresis. Turk J Pediatr. 2004;46(4):350-3. [pmid: 15641270].
218 van der Plas RN, Benninga MA, Buller HA, et al. Biofeedback training in treatment of childhood constipation: a randomised controlled study. Lancet. 1996;348(9030):776-80. [pmid: 8813983].
219 van der Plas RN, Benninga MA, Taminiau JA, et al. Treatment of defaecation problems in children: the role of education, demystification and toilet training. Eur J Pediatr. 1997;156(9):689-92. [pmid: 9296531].
220 van der Werff JF, Boeve E, Brusse CA, et al. Urodynamic evaluation of hypospadias repair. J Urol. 1997;157(4):1344-6. [pmid: 9120936].
221 van Ginkel R, Buller HA, Boeckxstaens GE, et al. The effect of anorectal manometry on the outcome of treatment in severe childhood constipation: a randomized, controlled trial. Pediatrics. 2001;108(1):E9. [pmid: 11433088].
222 Vijverberg MA, Elzinga-Plomp A, Messer AP, et al. Bladder rehabilitation, the effect of a cognitive training programme on urge incontinence. Eur Urol. 1997;31(1):68-72. [pmid: 9032538].
223 von Wendt L, Simila S, Niskanen P, et al. Development of bowel and bladder control in the mentally retarded. Dev Med Child Neurol. 1990;32(6):515-8. [pmid: 2365145].
224 Vvik IH, Odegaard B. Practical and emotional aspects of soiling in children with anorectal anomalies. Possibilities for prevention and early intervention. Z Kinderchir. 1981;33(4):321-9. [pmid: 7324575].
225 Wahl NG, Castilla MA, Lewis-Abney K. Prevalence of Gardnerella vaginalis in prepubertal males. Arch Pediatr Adolesc Med. 1998;152(11):1095-9. [pmid: 9811287].
226 Wainwright S, Frisby M. Behaviour therapy with the mentally handicapped. Nurs Times. 1979;75(29):1234-6. [pmid: 257441].
227 Wakefield MA, Woodbridge C, Steward J, et al. A treatment programme for faecal incontinence. Dev Med Child Neurol. 1984;26(5):613-6. [pmid: 6510562].
228 Weiss JM, Dykhuizen RF, Sargent CR, et al. Urinary tract infection in girls. I. A computerized analysis of urethral stenosis. J Urol. 1968;100(4):513-9. [pmid: 5692304].
229 White JJ, Suzuki H, el-Shafie M, et al. A physiologic rationale for the management of neurologic rectal incontinence in children. Pediatrics. 1972;49(6):888-93. [pmid: 4557410].
230 Whiteley P. Developmental, behavioural and somatic factors in pervasive developmental disorders: preliminary analysis. Child Care Health Dev. 2004;30(1):5-11. [pmid: 14678306].
231 Wilkinson AG. Percutaneous direct radionuclide cystography in children: description of technique and early experience. Pediatr Radiol. 2002;32(7):511-7. [pmid: 12107585].
232 Williams CL, Doleys DM, Ciminero AR. A two-year follow-up of enuretic children treated with dry bed training. J Behav Ther Exp Psychiatry. 1978;9(3):285-6.
233 Wolffenbuttel KP, Kok DJ, van Mastrigt R, et al. Measurement of urinary flow rate using ultrasound in young boys and infants. J Urol. 2001;166(3):1058-61. [pmid: 11490299].
234 Worobey J. Development milestones related to feeding status: evidence from the Child Health Supplement to the 1981 National Health interview survey. J Hum Nutr Diet. 1992;5(6):363-9.
235 Wu WJ, Chiang PH, Huang CH. Retroperitoneal laparoscopic nephrectomy in the treatment of incontinence from ectopic ureter with renal hypoplasia in the child - a case report. Kaohsiung J Med Sci. 2001;17(12):626-9. [pmid: 12168497].
236 Young GC. The treatment of childhood encopresis by conditioned gastro-ilea reflex training. Behav Res Ther. 1973;11(4):499-503. [pmid: 4777645].
237 Zerin JM, Chen E, Ritchey ML, et al. Bladder capacity as measured at voiding cystourethrography in children: relationship to toilet training and frequency of micturition. Radiology. 1993;187(3):803-6. [pmid: 8497634].

## Foreign Language

1 Annell E. Diaper-requested defecation: a special form of encopresis?. Scand J Behav Ther. 1993;21(3):141-50.
2 Anonymous. Clinical conference: speech, motor activities and toilet training in a patient with neuro-Behcet's syndrome. Kangogaku Zasshi 1974;38(4):440–3.
3 Artner K, Castell R. Therapy of encopretic children on a ward for psychosomatic diseases. Prax Kinderpsychol Kinderpsychiatr. 1979;28(4):119-32. [pmid: 471924].
4 Badachi Y, Pietrera P, Liard A, et al. Vesicoureteric reflux and functional voiding dysfunction in children. J Radiol. 2002;83(12):1823-7. [pmid: 12511837].
5 Britten D. Treatment of neurogenic bladder urination disorders due to traumatic paraplegia. Z Urol Nephrol. 1974;67(9):697-702. [pmid: 4466204].
6 Buzelin JM, Bouchot O, Glemain P. Achieving urinary continence. Rev Prat. 1991;41(23):2279-81. [pmid: 1792486].
7 Casolari E. Treatment of continence abnormalities in children with oxybutinin chloride and toilet training. Medicina-Rivista Della Enciclopedia Medica Italiana. 1984;4(1):79-80.
8 Comas VA, Polanco AI. Case-control study of risk factors associated with constipation. The FREI Study. Anales De Pediatria. 2005;62(4):340-5. [pmid: 15826563].
9 Cracco A, Belloli GP, Ronconi GF. Sound alarms and conditioning therapy in the treatment of childhood enuresis: a study of 180 cases. Pediatr Med Chir. 1984;6(5):681-9. [pmid: 6535133].
10 Cucchiara S, Devizia B, Staiano A, et al. Treatment of chronic functional constipation in children by administration of vegetable fiber (Dicoman 5). Minerva Pediatr. 1989;41(3):147-52. [pmid: 2546032].
11 David E. History of water. Rev Infirm. 1989;39(20):35-7. [pmid: 2485949].
12 Delaisi de Parseval G, Lallemand S. Psychoanalytic comments on some ethnological observations of the Mossi population. Perspectives Psychiatriques. 1976;14(59):371-87.
13 Duker PC. Determinants of diurnal bladder control with institutionalized mentally retarded individuals. Am J Ment Defic. 1983;87(6):606-10. [pmid: 6683467].
14 Fallstrom K, Aronson M. The effect of early psychological training of mentally retarded children. Nord Psykiatr Tidsskr. 1972;26(8):467-73.
15 Festen C. Constipation in children. Ned Tijdschr Geneeskd. 1977;121(47):1873-5. [pmid: 917141].
16 Flavigny H. Interpersonal relationships in a gypsy community in the Paris district. Rev Neuropsychiatr Infant. 1972;20(1):63-80.
17 Florin I, Tunner W. Principles of operant conditioning in the treatment of severely retarded children. Prax Kinderpsychol Kinderpsychiatr. 1970;19(7):253-9. [pmid: 5511621].
18 Gauthier Y, Drapeau P, Leclaire F, et al. The diagnosis and ego function of child encopretics. Can Psychiatr Assoc J. 1970;15(3):265-77. [pmid: 4193561].
19 Groen-Prakken J. Toilet training and enuresis. Ned Tijdschr Geneeskd. 1970;114(42):1723-8. [pmid: 5506429].
20 Hara K, Nishimura B, Watamaki T, et al. Classification in young children with Down's syndrome. Japanese Journal of Special Education. 1997;34(4):63-8.
21 Hartmann H, Krane R, Becker B. Toilet training and treatment of enuresis by instruments: discussion and presentation of a new instrument. Z Kinder Jugenpsychiatr. 1981;9(2):152-9.
22 Hashimoto S, Imanaka K, Tsugawa T, et al. Psychogenic megacolon: report of two cases. Rinsho Hoshasen. 1980;25(11):1231-4. [pmid: 7452937].
23 Hellstrom AL, Sillen U. Early potty training advantageous in bladder dysfunction. Decreases the risk of urinary infection. Lakartidningen. 2001;98(2829):3216-9. [pmid: 11496810].
24 Herold S, Hoj G. Nursing care. New and easy warning apparatus in continence training. Sygeplejersken. 1984;84(38):4-9. [pmid: 6570626].
25 Herzka HS. Development of cleanliness and ‘psychogenic’ enuresis. Ther Umsch. 1972;29(12):730-4. [pmid: 4639114].
26 Heymans HS, Benninga MA, de Groot I, et al. Constipation in childhood; evaluation of a diagnostic-therapeutic protocol. Ned Tijdschr Geneeskd. 1993;137(14):721-4. [pmid: 8474548].
27 Hindley CB. Comparison of longitudinal data from five European samples: methods and results. Enfance 1967; (2):141–55.
28 Hirai N. Therapy with children who show anorexia or resist toilet training. Jpn J Child Psychiatry 1960; (1):397–402.
29 Hirasing RA, Reus H. Dry bed training in nocturnal enuresis. Ned Tijdschr Geneeskd. 1991;135(38):1750-3. [pmid: 1922531].
30 Hoang-Bohm J, Junemann KP, Kohrmann KU, et al. Biofeedback training for children with wet episodes. Aktuelle Urologie. 1999;30(2):118-22.
31 Hoffmann G. Incontinence and toilet training. Krankenpflege (Frankf). 241;45(4):222-4. [pmid: 1903475].
32 Hohlweg-Majert P, Berger J, Thorn V. A comparative follow up study about intellectual and motoric development of premature births at three to eight years of life. Geburtshilfe Frauenheilkd. 1978;38(8):598-605. [pmid: 567159].
33 Horstmanshoff BE, Regterschot GJ, Nieuwenhuis EE, et al. Bladder control in 1–4 year old children in the Eindhoven and Kempen region (The Netherlands) in 1996 and 1966. Ned Tijdschr Geneeskd. 2003;147(1):27-31. [pmid: 12564295].
34 Inoue U. Bedside nursing. Assistance of a child with cerebral palsy in toilet training. Kangogaku Zasshi. 1977;41(4):376-9. [pmid: 403344].
35 Isogai K, Kurahashi H, Osuga K, et al. A survey of the environment of children who were found to have difficulty in toilet training at the health examination at age 3. Hokenfu Zasshi. 1987;43(12):1084-8. [pmid: 3444140].
36 Ito T, Hiraishi A. Assistance of children with Down's syndrome at mealtime and toilet training. Kango Gijutsu. 1974;20(2):57-64. [pmid: 4274893].
37 Kaffman M. Unconscious enuresis among kibbutz children. Harefuah 1962;(63):251–3.
38 Kawakami K, Yamashiro Y. Acute urinary retention apparently due to severe constipation in a seven-year old boy: a case report. Nishinihon Journal of Urology. 1997;59(6):530-2.
39 Kelm KI. Incontinence is no fate. 14th Meeting of the Gesellschaft fuer Inkontinenzhilfe e.V. GIH. Mainz DMW Deutsche Medizinische Wochenschrift. 2003;128(8):359-60.
40 Kikuchi R, Meijin K, Onami T. Bedside nursing: toilet training of children with cerebral palsy and mental retardation. Kangogaku Zasshi. 1974;38(7):745-8. [pmid: 4216671].
41 Knolker U. Obsessive-compulsive disorders in children and adolescents: pathogenetic aspects in the context of family background. Z Kinder Jugenpsychiatr. 1983;11(4):317-27.
42 Koltai JL, Ohama K, Hofmann-von Kap-herr S, et al. Optical-acoustical analogous biofeedback conditioning in the treatment of fecal incontinence in childhood. Z Kinderchir. 1984;39(6):389-91. [pmid: 6524092].
43 Labar P. Nocturnal enuresis in children and specific conditioning. Rev Med Liege. 1969;24(11):458-60. [pmid: 5401861].
44 Largo RH, Gianciaruso M, Prader A. Development of intestinal and bladder control from birth until the 18th year of age. Longitudinal study. Schweizerische Medizinische Wochenschrift/Journal Suisse de Medecine. 1978;108(5):155-60.
45 Le Bourhis C. Role of the nurse faced with sphincter and genital problems in children with spina bifida. Soins Gynecol Obstet Pueric Pediatr 1983;(25–26):55–63.
46 Lezine I. Child-rearing problems of the young premature. Enfance. 1958;3(56):213-43.
47 Luciano MC, Gomex IC. Field study of parental opinion regarding development of sphincter control. Boletin De Psicologia (Spain). 1994;42(3):55-73.
48 Maffei HV, Moreira FL, Kissimoto M, et al. Clinical and alimentary history of children attending a pediatric gastroenterology outpatient clinic with functional chronic constipation and its possible complications. J Pediatr (Rio J). 1994;70(5):280-6. [pmid: 14688850].
49 Magerotte G. Sphincter control training of the mentally retarded. Operant behavioral approach. Neuropsychiatr Enfance Adolesc. 1983;31(7):309-17. [pmid: 6621830].
50 Mala E. Enuresis from the viewpoint of the pediatric psychiatrist. Cesk Psychiatr. 1995;91(3):152-61. [pmid: 7553948].
51 Marugan de Miguelsanz JM, Lapena Lopez de AS, Rodriguez Fernandez LM, et al. An epidemiological analysis of the sequence of bladder control and nocturnal enuresis prevalence in the children of the province of Leon. An Esp Pediatr. 1996;44(6):561-7. [pmid: 8849099].
52 Matthaei R. The treatment of obsessive-compulsive neurotic micturition and defecation in childhood: a case of behavior therapy. Z Kinder Jugenpsychiatr. 1976;4(2):141-8.
53 Mattsson S, Stenberg A, Hellstrom AL, et al. The pediatrician's approach to bed-wetting. A survey shows that hospital clinics adhere to current recommendations. Lakartidningen. 2003;100(2627):2300-2. [pmid: 12872377].
54 Mayor CA, Guignard JP. Enuresis: its history and folklore. Rev Med Suisse Romande. 1985;105(11):969-76. [pmid: 3911338].
55 Mencia SV, Alonso GE. Fecal incontinence due to hemiplegia. Rev Enferm. 1997;20(232):63-5.
56 Messer AP, de Jong TP. Dry bed training and diagnosis in nocturnal enuresis. Ned Tijdschr Geneeskd. 1991;135(38):1724-5. [pmid: 1922525].
57 Minella R, Alagna M, Franco MT, et al. Treatment of functional chronic constipation with lactitol. Riv Ital Pediatr. 1993;19(1):77-81.
58 Miura M. Parental participation in an individualized toilet training program for Down's syndrome children. Jpn J Spec Educ. 1997;34(5):9-15.
59 Muto T, Karaiwa M, Okada T, et al. Toileting management procedure with functional assessment based on intensive home-delivery support: case study of a boy with pervasive developmental disorder. Jpn J Spec Educ. 2000;38(2):31-42.
60 Muus I. Nursing - cross-professional functions with toileting. Sygeplejersken. 1997;97(49):26-7. [pmid: 9444252].
61 Oetliker O, Bay R, Guignard JP, et al. Enuresis in childhood: what should one know? What should one do?. Schweizerische Medizinische Wochenschrift/Journal Suisse de Medecine. 1993;123(45):2156-64.
62 Qu JC. Care of patients with neurological diseases. Study of toilet training for the toddler. Hu Li Za Zhi. 1978;25(1):46-50. [pmid: 249755].
63 Ravaud JF. Excretory behavior: symptomatology. Soins Psychiatr 1980;(4):31–5.
64 Rick HR, Friedrich W. Encopresis among temporary stationary treated children. Prax Kinderpsychol Kinderpsychiatr. 1978;27(4):109-16. [pmid: 683948].
65 Stalder G. Bed-wetting. Schweizerische Medizinische Wochenschrift/Journal Suisse de Medecine. 1978;108(5):153-5.
66 van Ginkel R, Buller HA, Heymans HS, et al. Functional childhood gastrointestinal disorders. III. Constipation and solitary encopresis; diagnostic work-up and therapy. Ned Tijdschr Geneeskd. 2003;147(26):1267-71. [pmid: 12861667].
67 Vidailhet C. Clinical study. Neuropsychiatr Enfance Adolesc. 1983;31(4):197-200.
68 Voss F. Micturition behavior and urinary tract infection in girls. 2. Reduction in incidence of recurrence following normalization of micturition behavior. Kinderarztl Prax. 1990;58(5):233-9. [pmid: 2376937].
69 Voss F. Voiding delay and urinary tract infection in girls. 6. Training to modify voiding delay. Kinderarztl Prax. 1990;58(9):475-80. [pmid: 2287157].
70 Wintermeyer P, Wirth S. Chronic obstipation (severe constipation) in infants and small children. Padiatrische Praxis. 2005;66(1):59-70.
71 Wunderle C. Treatment of patients with encopresis in the hospital - using pedagogic principles. Kinderkrankenschwester. 1999;18(3):96-8. [pmid: 10446534].
72 Yamanishi T, Igarashi T, Murakami S, et al. A comparative study of the effects of drug therapy and bladder training therapy. Hinyokika Kiyo. 1988;34(1):102-6. [pmid: 3376789].
73 Zaltsman Y, Yulevich L. A new method of treating encopresis. Harefuah. 1991;121(56):156-9. [pmid: 1937249].
74 Zoller G, Zappel H, Ringert RH. Ektopic ureter - a not considered cause of persisting enuresis in girls. Klin Padiatr. 2001;213(6):314-6. [pmid: 11713707].

## Incorrect Study Population

1 Averink M, Melein L, Duker PC. Establishing diurnal bladder control with the response restriction method: extended study on its effectiveness. Res Dev Disabil. 2005;26(2):143-51. [pmid: 15590245].
2 Azrin NH, Foxx RM. A rapid method of toilet training the institutionalized retarded. J Appl Behav Anal. 1971;4(2):89-99. [pmid: 16795291]. [pmcid: 1310676].
3 Azrin NH, Sneed TJ, Foxx RM. Dry bed: a rapid method of eliminating bedwetting (enuresis) of the retarded. Behav Res Ther. 1973;11(4):427-34. [pmid: 4777639].
4 Baumeister A, Klosowski R. An attempt to group toilet train severely retarded patients. Ment Retard. 1965;3(6):24-6. [pmid: 5848847].
5 Beloff H. The structure and origin of the anal character. Genet Psychol Monogr 1957; (55):141–72.
6 Borowitz SM, Cox DJ, Sutphen JL, et al. Treatment of childhood encopresis: a randomized trial comparing three treatment protocols. J Pediatr Gastroenterol Nutr. 2002;34(4):378-84. [pmid: 11930093].
7 Bradley M, Ferris W, Barr O. Continence promotion in adults with learning disabilities. Nurs Times. 1995;91(39):38-9. [pmid: 7567555].
8 Carlson SS, Asnes RS. Maternal expectations and attitudes toward toilet training: a comparison between clinic mothers and private practice mothers. J Pediatr. 1974;84(1):148-51. [pmid: 12119939].
9 Cummings LL. Parent training: a program for parents of two- and three-year-olds. Diss Abstr Int 2001;61(7-A).
10 Dalrymple NJ, Ruble LA. Toilet training and behaviors of people with autism: parent views. J Autism Dev Disord. 1992;22(2):265-75. [pmid: 1624408].
11 De Paepe H, Renson C, Van Laecke E, et al. Pelvic-floor therapy and toilet training in young children with dysfunctional voiding and obstipation. BJU Int. 2000;85(7):889-93. [pmid: 10792172].
12 Duker PC, Dekkers M. Development of diurnal bladder control in severely and profoundly mentally handicapped residents. J Intellect Disabil Res. 1992;36:177-81. [pmid: 1591501].
13 Ellis NR. Toilet training the severely defective patient: an S-R reinforcement analysis. Am J Ment Defic. 1963;68(1):98-103.
14 Ers KT. Toilet (re)training. Contemp Longterm Care. 1946;23(4):41-2.
15 Feldman MA, Case L, Garrick M, et al. Teaching child-care skills to mothers with developmental disabilities. J Appl Behav Anal. 1992;25(1):205-15. [pmid: 1582966]. [pmcid: 1279667].
16 Foster P. Behavioral treatment of urinary incontinence: a complementary approach. Ostomy Wound Manage. 1968;44(6):62-6. [pmid: 9739279].
17 Hamilton JW. Preoedipal factors in a case of fetishism. Bull Menninger Clin. 1978;42(5):439-44. [pmid: 719215].
18 Hartie A, Black D. A dry bed is the objective. Nurs Times. 1975;71(47):1874-6. [pmid: 1196965].
19 Hauck MR. Mothers' descriptions of the toilet-training process: a phenomenologic study. J Pediatr Nurs. 1991;6(2):80-6. [pmid: 2019969].
20 Jirovec MM, Jenkins J, Isenberg M, et al. Urine control theory derived from Roy's conceptual framework. Nurs Sci Q. 1999;12(3):251-5. [pmid: 11847672].
21 Jirovec MM, Templin T. Predicting success using individualized scheduled toileting for memory-impaired elders at home. Res Nurs Health. 2001;24(1):1-8. [pmid: 11260580].
22 Judkins JD. Overcorrection procedures with the institutionalized retarded: an evaluative review. Mental Retardation Bulletin. 1976;4(2):98-110.
23 Kunz PR. Religious influences on parental discipline and achievement demands. Marriage Fam Livin. 1963;25(2):224-5.
24 Lloyd EE. Bowel stimulator for quadriplegic patients: a follow up survey. Rehabil Nurs. 1983;8(3):30-1. [pmid: 6552694].
25 Miles B, Cochrane G. Continence. All under control...incontinence...effectiveness of group therapy. Nurs Times 1988;84(31):62, 65.
26 Newman DK. What's new: the AHCPR guideline update on urinary incontinence. Ostomy Wound Manage. 1952;42(10):46-50. [pmid: 9016151].
27 Newman DK. New treatment options for overactive bladder and incontinence. Director. 2002;10(3):74-6. [pmid: 12116753].
28 Opolot JA. Ethnicity and child-rearing practices in Uganda. J Soc Psychol. 1982;116(2):155-62.
29 Passman RH. Automatic device for toilet training. Behav Res Ther. 1975;13(4):215-20.
30 Putnam C. Why it pays pike to be toilet trained. New Scientist. 1995;146(1976):17.
31 Ritblatt SN, Obegi AD, Hammons BS, et al. Parents' and child care professionals' toilet training attitudes and practices: a comparative analysis. JRCE. 2003;17(2):133-46.
32 Ritterb LM, Cox DJ, Walker LS, et al. An Internet intervention as adjunctive therapy for pediatric encopresis. J Consult Clin Psychol. 2003;71(5):910-7. [pmid: 14516239].
33 Schuster MA, Duan N, Regalado M, et al. Anticipatory guidance: what information do parents receive? What information do they want?. Arch Pediatr Adolesc Med. 2000;154(12):1191-8. [pmid: 11115301].
34 Sells-Love D, Rinaldi LM, Mclaughlin TF. Toilet training an adolescent with severe mental retardation in the classroom: a case study. J Dev Phys Disabil. 2002;14(2):111-8.
35 Shultz JM. Urinary incontinence. Solving a secret problem. Nursing (Lond). 2003;Suppl 5–6:9-10.
36 Siegel RK. Stimulus selection and tracking during urination: autoshaping directed behavior with toilet targets. J Appl Behav Anal. 1977;10(2):255-65. [pmid: 885828]. [pmcid: 1311176].
37 Smith LJ. A behavioural approach to the treatment of non-retentive encopresis in adults with learning disabilities. J Intellect Disabil Res. 1996;40:130-9. [pmid: 8731470].
38 Stark LJ, Opipari LC, Donaldson DL, et al. Evaluation of a standard protocol for retentive encopresis: a replication. J Pediatr Psychol. 1997;22(5):619-33. [pmid: 9383926].
39 Torres SA, Holley JA, DeVera J, et al. Maximizing care outcomes of a patient with impaired bladder function: a PI project in a rehabilitation unit. J Nurs Care Qual. 1998;12(6):64-9. [pmid: 9682573].
40 Wilder DA, Higbee TS, Williams WL, et al. A simplified method of toilet training adults in residential settings. J Behav Ther Exp Psychiatry. 1997;28(3):241-6. [pmid: 9327303].
41 Williams FE, Sloop EW. Success with a shortened Foxx-Azrin toilet training program. Educ Train Ment Retard. 1978;13(4):399-402.
42 Yeager BA, Huttly SR, Bartolini R, et al. Defecation practices of young children in a Peruvian shanty town. Soc Sci Med. 1999;49(4):531-41. [pmid: 10414812].
43 Yilmaz O, Kavukcu S, Kasap B, et al. Comparison of trained and untrained dog urines. Pediatr Nephrol. 2003;18(12):1309-10. [pmid: 14586674].

## Inadequate Data or Outcome Not Reported

1 Abramovitch IB, Abramovitch HH. Enuresis in cross-cultural perspective: a comparison of training for elimination control in three Israeli ethnic groups. J Soc Psychol. 1989;129(1):47-56. [pmid: 2733401].
2 Cox DR. Child rearing and child care in Ethiopia. J Soc Psychol. 1971;85(1):3-5.
3 Ryback D, Sers AL, Lorentz J, et al. Child-rearing practices reported by students in six cultures. J Soc Psychol. 1980;110(2):153-62.
4 Smith PS, Wong H. Changes in bladder function during toilet training of mentally handicapped children. Behav Res Sev Dev Disabil. 1981;2(2):137-55.