# Appendix D: Evidence Tables

Table D-1 Description of included studies (observational studies)

Author-Year | Location | Toilet Training Method 1 | Toilet Training Method 2 | Description of Children | Source of Children
Healthy Children
Bakker 2002 | Belgium | Other: increased prompting and encouraged the child to try later | Other: less prompting and encouraged child to push or strain | Healthy | School
Brazelton 1962 | United States | Child-oriented | | Healthy | Clinical practice
Butler 1976 | United States | Azrin and Foxx | | Healthy | Community
Foxx 1973 | United States | Azrin and Foxx | | Healthy | Community and clinic practice
Kaffman 1972 | Israel | Child-oriented | | Healthy | Community
Taubman 1997 | United States | Child-oriented | | Healthy | Clinical practice
Mentally Handicapped Children
Ando 1977 | Japan | Operant conditioning | | Mentally handicapped: autism | Special care facility
Colwell 1973 | United States | Operant conditioning | | Mentally handicapped: severely and profoundly | Special care facility
Connolly 1976 | Ireland | Operant conditioning | Control | Mentally handicapped: NR | Special care facility
Didden 2001 | Netherlands | Modified Azrin and Foxx | | Mentally handicapped: Angelman syndrome ± epilepsy | Clinical practice
Giles 1966 | United States | Operant conditioning | | Mentally handicapped: severely | Special care facility
Holverstott-Cockrell 2002 | United States | Azrin and Foxx | | Mentally and physically handicapped: NR | School
Kimbrell 1967 | United States | Operant conditioning | Control | Mentally handicapped: severely and profoundly | Special care facility
Lancioni 1980 | Netherlands | Modified Azrin and Foxx | | Mentally handicapped: severely (deaf and blind) | Special care facility
Lancioni 1981a | Netherlands and Italy | Other: increased liquids, regular toilet cues, reinforment, and potties in the room | Other: increased liquids, regular toilet cues, and reinforcement | Mentally handicapped: autism, hearing impairment, or profoundly handicapped | Special care facility
Lancioni 1981b | Netherlands and Italy | Other: increased liquids, regular toilet cues, positive reinforcement, potties in room | Other: increased liquids, regular toilet cues, and positive reinforcement | Mentally handicapped: autism, hearing impairment, or profoundly handicapped | Special care facility
Mahoney 1971 | United States | Operant conditioning | | Healthy and mentally handicapped | Clinical practice
Smith 1977 | United Kingdom | Azrin and Foxx | | Mentally handicapped: NR | NR
Spencer 1968 | United States | Operant conditioning | | Mentally handicapped: severely and profoundly | Special care facility
Tierney 1973 | United Kingdom | Operant conditioning | Control | Mentally handicapped: NR | Special care facility
Van Wagenen 1969 | United States | Operant conditioning | | Mentally handicapped: virtually no speech skills | Special care facility
Physically Handicapped Children
Forsythe 1970 | United Kingdom | Other: if regular toileting is unsuccessful, daily enemas, then enema and suppository, and then enemas and oral purgative | | Physically handicapped: spina bifida | Special care facility
King 1994 | United States | Other: patient/family education and reflex-triggered bowel evacuation | | Physically handicapped: spina bifida | Clinical practice
Sullivan-Bolyai 1984 | United States | Other: stool - diaper/insert care, infrequent enemas to disimpact, low-level enemas, suppositories, digital stimulations, bladder - diaper/insert care, penile collectors, urinary diversion, and either timed bladder emptying (± medication) or clean intermittent catherization (± medication) | | Physically handicapped: spina bifida | Clinical practice
van Kuyk 2000a | Netherlands | Other: teach adequate defecation behavior including an adequate straining technique | | Physically handicapped: anal atresia | Clinical practice
van Kuyk 2000b | Netherlands | Other: teach bowel self-control, training of optimal defecation skills, toilet behavior | | Physically handicapped: Hirschprung's disease | Clinical practice

NR indicates not reported

Table D-2 Demographics of included children (observational studies)

Author-Year | No. of Children who Completed the study | MaleN (%) | Chronological Age (months) | Developmental or Social Age (months) | Baseline Bladder Function | Baseline Bowel Function
Healthy Children
Bakker 2002 | 4332 | 2215/4332 | 138 (6.7)* | NR | Incontinent: 100% | Incontinent: 100%
| | (51)
Brazelton 1962 | 1170 | 672/1170 | ˜24 | NR | NR | NR
| | (57)
Butler 1976 | 49 | 26/49 | 69% <25 | NR | Mean frequency of accidents: 6.03 (n=32) | Mean frequency accidents: 1.32 (n=32)
| | (53)
Foxx 1973 | 34 | 22/34 | 25 (20–36)^†^ | NR | Mean accidents/day: 6 | NR
| | (65)
Kaffman 1972 | 1376 | 721/1376 | 15–26 | NR | Incontinent: 100% | NR
| | (52) | (range)
Taubman 1997 | 482 | 255/482 | NR | NR | NR | NR
| | (53)
Mentally Handicapped Children
Ando 1977 | 5 | 5/5 | 86.4 (13.2)* | NR | NR | NR
| | (100)
Colwell 1973 | 47 | 30/47 | 108 (32.4)* | 16.7 (6.2)* | NR | NR
| | (64)
Connolly 1976 | 13 | NR | 84.8 | NR | Wettings/wk: 57 | Soiling/wk: 12
| | | (mean)
Didden 2001 | 6 | NR | 132 (72–228)^†^ | NR | Frequency of incorrect toileting: 1.7 (1.76)* | NR
Giles 1966 | 5 | 5/5 | 122.4 (56.4)* | 21.2 (5.4)* | NR | Self directed toileting: 0%
| | (100)
Holverstott-Cockrell 2002 | 9 | 7/9 | 46.68 (10.2)* | NR | Accidents/day (type not specified): 1.64 (0–3)^†^ | Accidents/day (type not specified): 1.64 (0–3)^†^
| | (78)
Kimbrell 1967 | 40 | 0/40 | 139.5 (109.5–173.2)^†^ | 16.8 (10.8–24.8)^†^ | NR | NR
| | (0)
Lancioni 1980 | 9 | 3/9 | 171.6 (97.2–195.6)^†^ | NR | Independent toileting: 0% | NR
| | (33)
Lancioni 1981a | 5 | 3/5 | 150 (129.6–175.2)^†^ | NR | Accidents/day: 1.25 | NR
| | (60) | | | (range 0–3)^†^
Lancioni 1981b | 5 | 3/5 | 150 (129.6–175.2)^†^ | NR | NR | NR
| | (60)
Mahoney 1971 | 8 | 7/8 | 44.9 (29.1)* | NR | Urinate on floor or in pants during 5 1-hour sessions: 15.5 (6.02)* | NR
| | (88)
Smith 1977 | 13 | NR | 126 (48)* | 22.4 (5.5)* | Mean accidents/wk: 51.88 (2.59)* | NR
Spencer 1968 | 38 | 38/38 | 102 (48–144)^†^ | 18 (4–39)^†^ | NR | NR
| | (100)
Tierney 1973 | 36 | 28/36 | 138 (60–252)^†^ | 4.2–22.6 | NR | NR
| | (78) | | (range)
Van Wagenen 1969 | 8 | 5/9 | 6.1 (1.7)* | NR | Number who always urinated through cotton brief and on the floor: 7/9 | NR
| | (55)
Physically Handicapped Children
Forsythe 1970 | 47 | 28/47 | 24–120 | NR | NR | Chronic constipation: 100%
| | (60) | (range)
King 1994 | 35 | NR | 18–348 | NR | NR | Incontinent: 100%
| | | (range)
Sullivan-Bolyai 1984 | Stool training=225 | NR | 12–216 and older | NR | NR | NR
| Bladder training=215
van Kuyk 2000a | 43 | 27/43 | 108 (48.1)* | NR | NR | Modified 3-point Templeton Score
| | (63) | | | | (1=good, 2=fair, 3=poor): 2.7 (0.45) *
van Kuyk 2000b | 16 | 16/16 | 81.6 (45.6)* | NR | NR | Modified 3-point Templeton Score
| | (100) | | | | (1=good, 2=fair, 3=poor): 2.7 (0.48) *

NR indicates not reported; SD: standard deviation; wk: week

* mean, SD

† mean, range

Table D-3 Description of toilet training programs (observational studies)

Author-Year | Toilet Training Objective | Readiness Screening | Trainers | Toilet Training Methods | Description of Toilet Training Methods | Reinforcement | Definition of Toilet Trained
Healthy Children
Bakker 2002 | Bladder and bowel control anytime | NR | Parents | Other: NR | Other: increased prompting and encouraged the child to try again later when he could not void | Positive and punishment | NR
| | | | Other: NR | Other: less prompting and encouraged child to push or strain, make encouraging noises, or open a tap
Brazelton 1962 | Daytime and nighttime bladder control | No | Parents | Child-oriented: Brazelton 1962 | Child oriented: original child-orientated approach | NR | Absence of accidents under the usual stress
Butler 1976 | Daytime bladder and bowel control | NR | Parents | Azrin and Foxx: Azrin 1974 | Azrin and Foxx: toilet training in less than a day | NR | Daytime continence for bowel and bladder
Foxx 1973 | Self-directed daytime bladder and bowel control | Yes | Adult assistants | Azrin and Foxx: Azrin 1971; Azrin 1973 | Azrin and Foxx: provided an intensive learning experience that maximized the factors known to be important for learning, then faded out these factors once learning occurred | Positive and punishment | Toileted completely with no prompts
Kaffman 1972 | Daytime and nighttime bladder control | NR | Caregivers and parents | Child-oriented: NR | Child-oriented: begun at the discretion of the trained caregivers and assisted by at least 6 others. Readiness based on neuromuscular and intellectual development level and child's will for mastery and cooperation. Process geared to minimize conflict and reduce anxiety in presence of accidents or persistent failure | Positive | Dry during the day and night uninterruptedly for ≥ 2 mo by age 3.5 yr
Taubman 1997 | Self-directed daytime bowel and bladder control | No | Parent | Child-oriented: Brazelton 1962 | Child-oriented: began training at ~2 yr.unless the child independently demonstrated an interest at an early age, using a child-oriented approach, positive reinforcement, and patience. Parents were cautioned against using a coercive approach | Positive | Always used potty or toilet for urination and bowel movements
Mentally Handicapped Children
Ando 1977 | Self-directed daytime bladder control | NR | Caregivers | Operant conditioning: NR | Operant conditioning: positively reinforced with candy and praise; negatively reinforced with physical violence, removing wet pants, and taking them to the cleaning receptacle | Positive and punishment | Self-initiated elimination in toilet
Colwell 1973 | Prompted bladder and bowel control anytime | NR | Non-professional staff | Operant conditioning: NR | Operant conditioning: trained in self-help skills that include toileting; training was generally based on operant procedures | Positive | To bring toileting behavior under verbal control
Connolly 1976 | Daytime bowel and bladder control | NR | Caregivers | Operant conditioning: NR | Operant conditioning: verbally praised for accident-free occasions and successful toileting | Positive | Continued absence of wetting or soiling in periods between toileting
| | | | Control: NR | Control: toileted as before
Didden 2001 | Prompted bladder and bowel control anytime | NR | Caregivers | Modified Azrin and Foxx: Azrin 1971 | Modified Azrin and Foxx: modifications included establishing prompted toileting rather than self-initiated, no potty or pants alarms, time out from positive reinforcement was used immediately following restitutional over correction, positive practice was omitted due to participants' motor limitations, and fluid intake was restricted to 70 ml/h | Positive and punishment | Correct toileting in the toilet
Giles 1966 | Self-directed daytime bowel control | No | Attendants | Operant conditioning: Ellis 1963 | Operant conditioning: combination of methods using operant behavior modification | Positive and punishment | Self-directed bowel movements in toilet
Mentally Handicapped Children
Holverstott-Cockrell 2002 | Daytime bladder and bowel control | No | Parents, teachers, aides | Modified Azrin and Foxx: Holverstott-Cockrell 1997 | Modified Azrin and Foxx: training program involved the use of positive reinforcement, data collection, training pants, Big Kid coloring book, and dry pants checks | Positive | Urination or defecation in the toilet
Kimbrell 1967 | Prompted daytime bladder and bowel control | NR | Attendans | Operant conditioning: Ellis 1963; Roos 1965 | Operant conditioning: an operant conditioning program to improve behavior in several areas, including toileting | Positive | Significantly less laundry generation, decreased frequency in soiling, and increase in VSMS social maturity quotient
| | | | Control: NR | Control: usual care
Lancioni 1980 | Self-directed daytime bladder control | NR | Teachers, caregiver, psychologist | Modified Azrin and Foxx: Azrin 1971 | Modified Azrin and Foxx: used potty and pants alerts, increased liquids, food reduction, positive/negative reinforcement, limitation of environmental stimulation, and distance fading | Positive and punishment | Independent self-directed and executed urinary behavior without interruptions
Lancioni 1981a | Self-directed daytime bladder control | NR | Teachers, teacher assistants | Other: NR | Other: increased liquids, regular toilet cues, positive and negative rienforcment; 25 potties placed throughout the room that were phased out as child progressed | Positive and punishment | Directed to toilet, lowered pants, sat, voided, redressed, and returned unassisted
| | | | Other: NR | Other: increased liquids, regular toilet cues, positive and negative reinforcement
Lancioni 1981b | Self-directed daytime bladder control | NR | Teachers, teacher assistants | Other: NR | Other: increased liquids, regular toilet cues, and positive reinforcement; 25 potties placed throughout the room that were phased out as child progressed | Positive and punishment | Directed to toilet, lowered pants, sat, voided, redressed, and returned unassisted
| | | | Other: NR | Other: increased liquids, regular toilet cues, positive reinforcement
Mentally Handicapped Children
Mahoney 1971 | Prompted daytime bladder control | NR | Caregivers | Operant conditioning: NR | Operant conditioning: response to auditory signal | Positive and punishment | Independent performance of total toileting sequence (walk to commode, pull down pants, urinate, pull pants up) without signal or prompt
Smith 1977 | Daytime toilet training | NR | NR | Azrin and Foxx: Azrin 1973 | Azrin and Foxx: increased fluids, use of urine-sensitive equipment, combination of operant techniques | Positive and punishment | NR
Spencer 1968 | Daytime bladder and bowel control | NR | Attendants | Operant conditioning: NR | Operant conditioning: children placed on commode 3–7 times a day at usual voiding times Untrained subjects were rewarded for both sitting on the commode and again for voiding in it | Positive | NR
| | | | | Subjects who were incontinent <50% of the time were only rewarded for voiding in the commode
Tierney 1973 | Self-directed daytime bladder and bowel control | NR | Nurses | Operant conditioning: NR | Operant conditioning: all incontinence and toilet behavior was observed and recorded; all appropriate behavior was reinforced; all inappropriate behavior was ignored | Positive | Goes to toilet independently: removes clothing, sits on toilet, eliminated on toilet and otherwise continent
| | | | Control: NR | Control: toileted as before
Van Wagenen 1969 | Self-directed daytime bladder control | NR | Experimener | Operant conditioning: Van Wagenen 1966 | Operant conditioning: liquid was increased and child wore an auditory signal generator that sounded when the child voided. After the signal, the trainer said ‘no’, took child by hand to toilet and placed in appropriate position If the child continued to void, he wasrewarded. | Positive and punishment | Independent daytime bladder control and autonomous toileting without prompts
| | | | | If successful, the signal device was replaced with training pants and the child was taught to remove and replace them to void
Physically Handicapped Children
Forsythe 1970 | Daytime bowel control | NR | NR | Other: Deaver 1953 | Other: regular toileting post evening meal for 2 mo. If unsuccessful, daily enemas until empty then regular toileting resumed. If unsuccessful, enema plus daily suppository, and if still unsuccessful, enemas plus oral purgative | NR | NR
King 1994 | Daytime and nighttime bowel control | NR | Psychiatrist, family members, child | Other: NR | Other: patient/family education and a regular, consistently timed, reflex-triggered bowel evacuation | No | One or fewer accidents (defecations not on toilet at desired time) per mo (excluding episodic, spontaneously resolving, presumed viral diarrhea illnesses) with less than 40 minutes required for each stool elimination
Physically Handicapped Children
Sullivan-Bolyai 1984 | Self-directed and prompted bladder and bowel control anytime | NR | Parent/ guardian | Other: Chapman 1979 | Other: stool training method; < 3yr.1) timed, 2) suppository, 3)expansion enema, 4) diaper care; ( 4yr.1) timed with digital stimulation, 2) suppository, 3) xpansion enema, 4) untimed diaper or pant insert, 5) infrequent enema. | NR | Learn socially acceptable (independent or dependent) bowel and bladder management. Acceptable defined as lack of odor, presence of clear skin, free of rash and decubitus. Independent defined as totally capable of dressing, perineal cleansing, replacement and care of collection devices and transfers on and off toilet receptacle without reminders
| | | | | Bladder training method: < 6 yr.1) timed, 2) clean intermittent catheterization, 3) diaper/pant insert; ( 6yr.1) heat diversion, 2) timed, 3) clean intermittent catheterization, 4) diaper/pant insert, 5) penile collector OR Stool training included: diaper/insert care, infrequent enemas to disimpact, low-level enemas, suppositories, digital stimulations; Bladder training included diaper/insert care, penile collectors, urinary diversion, and timed bladder emptying ± medication, or clean intermittent catherization ± medication
van Kuyk 2000a | Daytime and nighttime bowel control | NR | Psychologist and/or parents and/or physiotherapist and/or surgeon | Other: van Kuyk 2000 | Other: behavioral program to teach children and their parents adequate defecation behavior including an adequate straining technique | No | NR
van Kuyk 2000b | Self-directed daytime and nighttime bowel control | No | Child, psychologist, parents | Other: NR | Other: teaching the child bowel self-control, training of optimal defecation skills and, subsequently, toilet behavior | Positive | Child achieves self control and extinguishes reactions of fear and aversion to defecation; aim for school aged child to have independent in bowel function

h indicates hour; ml: milliliters; mo: month; NR: not reported; VSMS: Vineland social maturity scale; yr: year

Table D-4 Description of the toilet training programs (trials)

Author-Year | Location | Toilet Training Intervention 1 | Toilet Training Intervention 2 | Toilet Training Intervention 3 | Description of Children | Source of Children
Healthy Children
Candelor 1977 | United States | Azrin and Foxx | Other: Spock's Baby and Childcare Handbook | | Healthy | Community
Matson 1977 | United States | Azrin and Foxx with supervision | Azrin and Foxx without supervision | | Healthy | Community
Taubman 2003 | United States | Child-oriented and handbook promoting praising defecation | Child-oriented | | Healthy | Clinical practice
Mentally Handicapped Children
Edgar 1975 | United States | Other: relaxation-tension exercise regimen | Other: played with toys, given individual attention, and placed on toilet | | Mentally handicapped: severely and profoundly | Special care facility
Hundziak 1965 | United States | Operant conditioning | Other: toileted several times a day, scolded for soiling, praised for successful toileting | Control | Mentally handicapped: severely | Special care facility
Hyams 1992 | United Kingdom | Individual-modified Azrin and Foxx | Group-modified Azrin and Foxx | Other: intensive individual training program where the child is prompted and rewarded for successful toileting | Mentally handicapped: severely and profoundly | Special care facility
Sadler 1977 | United States | Azrin& Foxx | Other: toileted on a schedule | Control | Mentally handicapped: severely and profoundly | Special care facility
Physcially Handicapped Children
van Kuyk 2001 | Netherlands | Operant conditioning | Other: standard medical treatment | | Physically handicapped: Hirschprung's | Community

Table D-5 Demographics of included children (trials)

Author-Year | No. of Children who Completed the Study | Male N (%) | Chronological Age (months) | Developmental or Social Age (months) | Baseline Bladder Function | Baseline Bowel Function
Healthy Children
Candelora 1977 | 71 | 44/71 | 26.11 (18–35)^†^ | NR | Mean accidents/day/child: | NR
| | (62) | | | 4.59
Matson 1977 | 9 | 7/10 | 20–26 | NR | NR | NR
| | (70) | (range)
Taubman 2003 | 381 | 197/381 | 17–19 | NR | Incontinent: 100% | Incontinent: 100%
| | (completed) | (range)
| | (52)
Mentally Handicapped Children
Edgar 1975 | 20 | NR | 48–144 | 19.5 (15–23)^†^ | NR | NR
| | | (range)
Hundziak 1965 | 26 | 26/26 | NR | 84–168 | NR | NR
| | (completed) | | (range)
| | (100)
Hyams 1992 | 14 | 5/15 | 135 (68–224)^†^ | 22.3 (11–26)^†^ | NR | NR
| | (33%)
Sadler | 14 | 11/14 | 84–144 | NR | Mean wets/child/day: | NR
1977 | | (79) | (range) | | 0.88–1.00
| | | | | (range of group means)
Physically Handicapped Children
van Kuyk 2001 | 25 | 21/27 | 62.4 (24–132)^†^ | NR | Parental judgment on Bowel Incontinence | % feces in toilet 36.5
| | (78) | | | Scale: 17.4 (7.6)* | (35.3)*

NR indicates not reported; SD: standard deviation

* mean, SD

† mean, range

Table D-6 Description of the toilet training programs (trials)

Author-Year | Toilet Training Objective | Readiness Screening | Toilet Trainers | Toilet Training Methods | Description of Toilet Training Methods | Reinforcement | Definition of Toilet Trained
Healthy Children
Candelora 1977 | Self-directed daytime bladder control | Yes | Parents | Azrin and Foxx: Azrin 1974 | Azrin and Foxx: toilet training in less than a day | NR | NR
| | | | Other: Spock 1986 | Other: baby and childcare handbook that describes developmental highlights, readiness indications, specific training procedures, and expected problems associated with bladder and bowel training
Matson 1977 | Daytime bladder control | Yes | Parents ± supervisors | Azrin and Foxx: Azrin 1974 | Azrin and Foxx: toilet training in less than a day with mothers supervised by an experienced trainer | NR | NR
| | | | Azrin and Foxx: Azrin 1974 | Azrin and Foxx: toilet training in less than a day with mothers unsupervised
Taubman 2003 | Self-directed daytime bladder and bowel control | NR | Parents | Child-oriented: AAP 1999; Stadtler 1999 | Other: received handout describing child-oriented approach to TT, increased praise for defecating in diaper before TT begins, and not using negative terms for stool or defecating | Positive | Child in underwear when awake with <4 bladder accidents/wk and ≤2 bowel accidents/wk
| | | | | Child oriented: received handout describing child-oriented approach to TT
Mentally Handicapped Children
Edgar 1975 | Self-directed and when prompted daytime bladder control | No | Caregivers | Other: Kephart 1969 | Other: all wore urinary training devices; experimental group: increased fluids followed by relaxation-tension exercise regimen 15 min later then placed on toilet (regeimen = massage, shaking, stretching) | Positive and punishment | Must have only 1 accident in 2 days occurring on the first day; showing self-initiating toileting
| | | | Other: NR | Other: all wore urinary alarm devices; controls played with toys, given individual attention, and placed on toilet
Hundziak 1965 | Daytime and nighttime bladder control | No | Caregivers | Operant conditioning: Ellis, 1963 | Operant conditioning: used a candy dispensing device to positively reward and reinforce eliminative responses | Positive | Voiding in toilet will increase; toileting habits learned will transfer to original living unit
| | | | Other: NR | Other: children taken to the bathroom several times a day, scolded for soiling and praised for successful use of bathroom facilities
| | | | Control: NR | Control: no organized routine was maintained to subject the children to a toilet training program
Hyams 1992 | Self-directed daytime bladder control | NR | Nurses | Modified Azrin and Foxx: Azrin 1971; Azrin 1973 | Modified Azrin and Foxx: intensive, individual regular potting training program where accidents resulted in a reprimand and timeout from reward for 10 minutes. All groups used pants and toilet alarms | Positive and punishment | NR
| | | | Modified Azrin and Foxx: NR | Modified Azrin and Fox: training procedures similar to above, but trained in a group
| | | | Other: Mahoney 1971; Van Wagenen 1969 | Other: intensive individual training program where the child is prompted and rewarded after successful toileting
Sadler 1977 | Daytime bladder control | NR | Staff | Azrin& Foxx: Azrin 1971; Azrin 1973 | Azrin and Foxx: over correction and repeated positive practice | Positive and punishment | Reducing number of accidental daytime wettings
| | | | Other: NR | Other: scheduling method where children are toileted 4 times a day
| | | | Control: NR | Control: no training
Physically Handicapped Children
van Kuyk 2001 | Daytime and nighttime bladder control | NR | Child, parents, psychologist, and physiotherapist | Operant conditioning: van Kuyk 2000 | Operant conditioning: biopsychosocial approach to extinguish defecation anxiety and avoidance behavior by teaching bowel self-control via optimal defecation skills and toilet behavior | Positive | NR
| | | | Other: NR | Other: put on a waiting list and received standard medical treatment consisting of laxatives, enemas, or bowel rinsing

NR indicates not reported; TT: toilet training; wk: week

Table D-7 Methodological quality of included studies (observational studies)

Author-Year | Study Design | Downs and Black Score | Data Collection | Data Collection Methods | Funding
Ando 1977 | Single cohort | 16 | Prospective | Clinical review | Government, foundation
Bakker 2002 | Multiple cohort | 21 | Retrospective | Questionnaire | NR
Brazelton 1962 | Single cohort | 13 | Retrospective | Chart review | NR
Butler 1976 | Single cohort | 11 | Prospective | Other | NR
Colwell 1973 | Single cohort | 22 | Unclear | Clinical review | NR
Connolly 1976 | Single cohort | 17 | NR | Clinical review | NR
Didden 2001 | Single cohort | 17 | Prospective | Clinical review | NR
Forsythe 1970 | Single cohort | 15 | Retrospective | NR | Industry
Foxx 1973 | Single cohort | 18 | Prospective | NR | Government
Giles 1966 | Single cohort | 15 | Prospective | NR | NR
Holverstott-Cockrell 2002 | Multiple cohort | 19 | Prospective | Questionnaire | NR
Kaffman 1972 | Single cohort | 16 | Retrospective | Other | NR
Kimbrell 1967 | Multiple cohort | 17 | Prospective | Clinical review | NR
King 1994 | Single cohort | 21 | Retrospective | Chart review | NR
Lancioni 1980 | Multiple cohort | 16 | Prospective | Clinical review | NR
Lancioni 1981a | Single cohort | 16 | Prospective | Other | Other
Lancioni 1981b | Single cohort | 16 | Prospective | Other | Other
Mahoney 1971 | Single cohort | 15 | NR | Clinical review | NR
Smith 1977 | Multiple cohort | 18 | Retrospective | Chart review | NR
Spencer 1968 | Single cohort | 18 | Prospective | Clinical review | NR
Sullivan-Bolyai 1984 | Single cohort | 18 | Retrospective | Clinical review | Foundation
Taubman 1997 | Single cohort | 20 | Prospective | Interview | NR
Tierney 1973 | Multiple cohort | 16 | Prospective | Clinical review | NR
van Kuyk 2000a | Single cohort | 22 | Retrospective | Chart review | NR
van Kuyk 2000b | Single cohort | 20 | Retrospective | Questionnaire | NR
Van Wagenen 1969 | Single cohort | 13 | Prospective | Clinical review | Other

NR indicates not reported

Table D-8

Author-Year | Jadad Score | Allocation Concealment | Data Collection Method | Funding Source
Candelora 1977 | 2 | Unclear | Questionnaire | NR
Edgar 1975 | 2 | Unclear | Clinical review | Government
Hundziak 1965 | 2 | Unclear | Clinical review | Government
Hyams 1992 | 2 | Unclear | Interview | NR
Matson 1977 | 2 | Unclear | Clinical review | Internal
Sadler 1977 | 2 | Unclear | Other | NR
Taubman 2003 | 2 | Unclear | Interview | Government
van Kuyk 2001 | 1 | Unclear | Clinical review | Government

NR indicates not reported

Table D-9 Outcomes and results of included studies (observational studies)

Author-Year | Toilet Training Method(s) | Study Design | Primary Outcome | Other Outcomes or Effect Modifiers | Results | Conclusions
Healthy children
Bakker 2002 | Other: Increased prompting v. less prompting | Retrospective cohort | Residual lower urinary tract symptoms (LUTS) at ≥10 yr | Comparisons based on sex, family structure, number of bedwetting-relatives, school performance, self-management, daily hygiene, age TT begun, parent attitudes | N=4332 | Data show significant differences between children with lasting problems with bladder control and those without.
| | | | | 928/4332 (21%) symptomatic at 10 to 14 yr. Symptom group v. control: significant difference in:; 1 Proportion female (62.1% v. 45.2%); 2 Fewer from stable first marriage (82% v. 86%); 3 Bedwetting relatives (37% v. 25%); 4 Poorer school performance (12% v. 8%); 5 Less ability to manage homework and appointments independently (73% v. 68%); 6 Less capacity to manage daily hygiene (37% v. 31%); 7 Began TT at older age (22% v. 32% began TT before 18 mo); 8 Parents in symptom group used less prompting, were more liberal, rewarded and punished more, and exerted more pressure if attempt to void failed | Beginning TT >18 mo and using certain methods to provoke voiding if attempt failed increased the risk of LUTS.
Brazelton 1962 | Child-oriented | Retrospective cohort | Age, day, and nighttime bladder continence | Comparisons based on sex | N=1170 | Day and nighttime training effected later in first child than subsequent siblings. Boys took longer to be night trained. A child-orientated program helps prevent residual symptoms.
| | | | | Day training achieved 1–2 mo later and nighttime 1–7 mo longer in 1st child
| | | | | 54.7% began TT at 24 mo
| | | | | 12.3% achieved bowel training first
| | | | | 8.2% bladder, and 79.5 % simultaneous training
| | | | | 80.7% daytime trained by average 28.5 mo and 80.3% night trained by 3 yr.Average age to complete all training was 33.3 mo; males took 2.3 mo longer to complete
| | | | | 1.4% had residual problems >5 yr
Healthy Children
Butler 1976 | Azrin and Foxx | Prospective cohort | Bowel and bladder accidents | Comparisons based on sex and age | N=49 | Males and all children >25 mo. trained faster. 20% stopped wetting at night. Some children reacted negatively to positive practice-sessions following an accident, and some parents found it difficult not to prompt at signs of self-initiation.
| | | | | End 1st intensive training session
| | | | | <25 mos: 25/34 (74%) success
| | | | | >25 mos: 14/15 (93%) success
| | | | | Mean intensive training time: all =4.5 hr (range 1.25–10)
| | | | | <25 mo.= 5.15 hr
| | | | | >25 mo.= 4.08 hr
| | | | | 2 wk post training: mean # accidents
| | | | | bladder ↓ 6.03 to 0.60/day (p<0.001)
| | | | | bowel ↓ 1.23 to 0.07/day
| | | | | 3 failures: 2 male, 1 female
| | | | | 8 wk post training: mean # accidents
| | | | | bladder = 0.58/day
| | | | | bowel = 0.11/day
| | | | | 2 failures: 1 male, 1 female
Foxx 1973 | Azrin and Foxx | Prospective cohort | Self toileting without reminders | Bowel and bladder accidents, training time | N=34 (results at 1–4 mos) | Virtually all healthy children >20 mo. were daytime TT in a few hours and 26–36 mo.old train faster. Nighttime dryness often resulted as well.
| | | | | 33/34 (97%) success | Children reacted favorably to trainer and early tantrums were short-lived.
| | | | | Mean no. accidents/day: pre-training / 1 day post- training / 4 mo. post training
| | | | | Bladder: ~6 / ~0.5 (↓of 97%) / ~0
| | | | | Mean training time: 3.9 hr (range 0.5–14)
| | | | | 26–36 mo. = 2.25 hr
| | | | | 20–25 mo. = 5 hr
| | | | | 1/34 regressed at 3 mo. followup
Kaffman 1972 | Child-oriented | Retrospective cohort | Enuresis | Comparisons by age and sex | N=1376 | Up to 6–7 yr, kibbutz raised children had higher incidence of enuresis and by > 10 yr, it was lower than non-kibbutz raised children. Regressive enuresis was rare.
| | | | | TT begun at 15–26 mo.
| | | | | Proportion enuretic:
| | | | | 4–15 yr: 13.9%; M/F = 14.9/12.8%
| | | | | 4–7 yr: 133/508 (26%); M/F = 13/13%
| | | | | 7–15 yr: 59/868 (7%) M/F = 5/2%
Healthy and Mentally Handicapped Children
Mahoney 1971 | Operant conditioning | Prospective cohort | Level of performance from 1–10 where Level 10 = independent toileting | Number of training hours | Healthy: n=3; MC n=5 | Complete toileting behavior includes complex chain of behaviors and other behaviors should be taught prior to elimination.
| | | | Number of trials | (results after 29 hrs of training)
| | | | | Healthy: 3/3 (100%) attained Level 10 over average of 29 hr and 118 trials.
| | | | | MC: 4/5 (80%) attained Level 10 over average 29 hrs and 262 trials
| | | | | 1 failure
Taubman 1997 | Child-orientated | Prospective cohort | Stool toileting refusal (STR) | Associated factors | N=482 | Two behaviors associated with STR may need intervention: withholding causing constipation and unsuccessful training by 42 mo.
| | | | | ≤ 3 yr: 292/482 (61%) trained
| | | | | 4 yr: 471/482 (98%) trained
| | | | | 22% experienced ≥ 1 mo of STR, 73% resolved without intervention
| | | | | STR significantly associated with presence of younger siblings, parental inability to set limits, and later age (>42 mo.) to complete TT
| | | | | Overall: 48% males and 30% females trained by 3 yr.(p=0.0004)
| | | | | 48% began TT < 24 mo.and 32% not trained until >3 yr
| | | | | 52% begun TT > 24 mo.and 46% not trained until > 3yr
| | | | | No association between age of TT with mother's work status, attending daycare, behavior scores, or presence of siblings
| | | | | STR group
| | | | | Age STR began: 73% between 24–36 mos
| | | | | Siblings: 33% had younger and 17% had older
| | | | | Behavior scores: ≤ 2 = 32% with STR, > 2 = 20% with STR
Physically Handicapped Children
Forsythe 1970 | Other: progressive intervention if unsuccessful bowel control | Prospective cohort | Independent bowel control | | N=47 | A combination of regular toileting, initial enemas, and Senokot was the most satisfactory to bowel train children with spina bifida. Dulcodos tablets were almost as effective in those >6 yr.
| | | | | Bowel control obtained: | Manual evacuation and repeated enemas were unsatisfactory due to social reasons and creating dependence on others.
| | | | | 1. Regular toileting (RT)
| | | | | 8/47 (17%) maintained >2 yr
| | | | | 8 others relapsed at 8–15 mo.
| | | | | 2. Enemas + RT
| | | | | 7/39 (18%) maintained >2 yr
| | | | | 2 others relapsed at 6–8 mo.
| | | | | 1 & 2 combined
| | | | | 15/47 (32%) success
| | | | | 10/47 (21%) temporary improvement
| | | | | 22/47 (47%) unchanged
| | | | | 3. Enemas + RT + suppositories
| | | | | Glycerin: 0/25 (0%) success
| | | | | Dulcolax: 3/25 (12%)
| | | | | Stopped dulcolax at 6 mo.
| | | | | Maintained for 2 yr.
| | | | | 18/25 (72%) relapsed 3 mo. after enemas stopped
| | | | | Micralax micro-enemas
| | | | | 2/22 (8%) success
| | | | | Stopped tx at 6 mo.
| | | | | Maintained >2 yr
| | | | | 20/25 (80%) unchanged
| | | | | 4. Enemas + RT + purgatives
| | | | | Dulcodos: 8/16 (50%)
| | | | | Maintained >9 mo.
| | | | | Senokot syrup: 15 /15 (100%)
| | | | | Maintained >6 mo.
King 1994 | Other: patient and family education and regular reflex-triggered bowel evacuation | Retrospective cohort | Bowel continence | Comparisons based on age, compliance, and reflexes present | N=35 | Continence more likely achieved if ≤ 6 yr, were compliant, and if had intact bulbocavernosus or anocutaneous reflex or both.
| | | | | Bowel continence ↑ from 0 to 54.3%
| | | | | 24/35 (68.6%) were compliant; 19/24 (79%) of these became continent
| | | | | Reflexes present
| | | | | Anocutaneous reflex: 8/8 (100%) with reflex became continent
| | | | | 10/25 (40%) without reflex did not
| | | | | Bulbocavernosus reflex: 13/19 (68%) with reflex became continent
| | | | | 5/14 (36%) without reflex did not
| | | | | Age
| | | | | ≤ 6 yr: 11/17 (65) became continent
| | | | | >6 yr: 8/18 (44%) became continent
Sullivan-Bolyai 1984 | Other: | Retrospective cohort | Dependent and independent toileting | Comparisons based on sex, IQ, and training method | N=525 | Individuals with higher-level lesions may experience delay in achieving successful skill.
| bowel training | | Socially acceptable and unacceptable toileting | | High lumbar/thoracic lesions: 80% became socially acceptable by 16–17 yr; 50% were dependent | Those with ileal diversions gained independence at a later age and experienced ammonia odor, persistent infection, recurrent obstruction, and renal stones. Penile collectors caused odor and penile ulcers.
| 1 untimed random collection with diaper or insert; 2 infrequent enema; 3 small rapid low level enema; 4 suppositories; 5 timed evacuation ± digital stimulation | | | | Low lumbar/sacral lesions: 80% became socially acceptable by 10–11yr 50% were dependent | Problems with CIC and timed voiding included leakage with Valsalva maneuver. A generalset of toilet training predictor guidelines can assist parents and children, avoid frustration, discouragement and psychological problems. Close clinic followup is required.
| bladder training | | | | All levels: 50% became socially acceptable between 7–9 yr 70% were dependent
| 1 diaper/pant insert + periodic cleansing.; 2 penile collector; 3 urinary diversion; 4 timed emptying ± medication; 5 clean intermittent catheterization (CIC) ± medication | | | | No differences based on age, sex, or time TT begun
| | | | | IQ <69: 1/30 successful
| | | | | Bowels:
| | | | | <3 yr: n=41
| | | | | Socially acceptable/dependent: 39/41 (95%)
| | | | | 7/41 (17%) timed evacuation
| | | | | 14/41 (35%) Bisacodyl suppository
| | | | | 3/41 (7%) expansion enema
| | | | | 15/41 (41%) diapers
| | | | | Socially unacceptable/dependent: 2/41 (5%)
| | | | | > 4 yr: n=184
| | | | | Socially acceptable/independent: 84/184 (46%)
| | | | | 55/184 (30%) timed evacuation
| | | | | 24/184 (13%) bisacodyl suppository
| | | | | 3/184 (2%) small expansion enemas
| | | | | 1/184 (.005%) diaper/pant insert
| | | | | 1/184 (.005%) infrequent enema
| | | | | Socially acceptable/dependent: 57/184 (31%)
| | | | | 18/184 (10%) timed evacuation
| | | | | (3/18 (17%) with digital stimulation)
| | | | | 24/184 (13%) bisacodyl suppository
| | | | | 12/184 (7%) expansion enemas
| | | | | 2/184 (1%) diaper/pant insert
| | | | | 1/184 (0.005%) infrequent enema
| | | | | Socially unacceptable/dependent: 23/184 (13%)
| | | | | Socially unacceptable/independent: 19/184 (10%)
| | | | | Bladder:
| | | | | < 6yr: n=57
| | | | | Socially acceptable/dependent: 45/57 (79%)
| | | | | 3/57 (5%) timed
| | | | | 10/57 (18%) CIC
| | | | | 32/57 (56%) diaper/pant insert
| | | | | Socially acceptable/independent: 1/57(2%)
| | | | | 1/57 (2%) CIC
| | | | | Socially unacceptable/dependent: 11/57 (19%)
| | | | | > 6 yr: n=158
| | | | | Socially acceptable/dependent: 52/158 (33%)
| | | | | 23/158 (15%) heat diversion
| | | | | 4/158 (3%) timed evacuation
| | | | | 12/158 (8%) CIC
| | | | | 2/158 (0.01%) diaper/pant insert
| | | | | 11/158 (7%) penile collectors
| | | | | Socially acceptable/independent: 55/158 (35%):
| | | | | 27/158 (17%) heat diversion
| | | | | 8/158 (5%) timed evacuation
| | | | | 10/158 (6%) CIC
| | | | | 1/158 (0.01%) diaper/pant insert
| | | | | 9/158 (6%) penile collectors
| | | | | Socially unacceptable/dependent: 36/158 (23%)
| | | | | Socially unacceptable/independent: 51/158 (32%)
van Kuyk, 2000a | Operant conditioning | Retrospective cohort | Bowel continence (Templeton and Wingspread scores) | Comparisons based on age | N=16 | Multidisciplinary intervention effective in treatment of constipation and incontinence in children with Hirschsprung's disease. The children improved in all aspects.
| | | Constipation Defecation behavior | | 14/16 (88%) achieved good continence 12/16 (75%) were clean
| | | | | 8/12 (67%) recovered from constipation
| | | | | Templeton score: ↓ from 2.7 ± 0.48 to 1.1 ± 0.34 (p=0.00)
| | | | | Wingspread score: ↓ from 3.5 ± 0.52 to 1.3 ± 0.60 (p=0.00)
| | | | | Constipation: ↓ from 1.8 ± 0.45 to 1.3 ± 0.45 (p=0.01)
| | | | | Defecation behavior: ↓ from 2.9 ± 0.34 to 1.1 ± 0.34 (p=0.00)
| | | | | No difference based on age
van Kuyk 2000b | Operant conditioning | Retrospective cohort | Feces in toilet | Comparisons based on age and high v. lower anal atresia | N=43 | The intervention was effective and there were no differences based on age. Both somatic and behavioral factors affect persistence of defecation problems, therefore treatment should include behavioral modification techniques.
| | | Number of days without soiling | | 17/43 (40%) achieved good continence
| | | Templeton score Wingspread score Constipation score | | 21/43 (49%) achieved fair continence
| | | Parental judgment incontinence scales | | 51% were clean
| | | | | 40% only staining
| | | | | 10/18 (55%) recovered from constipation
| | | | | Templeton score: ↓ from 2.7 ± 0.45 to 1.6 ± 0.59 (p=0.00)
| | | | | Wingspread score: ↓ from 3.4 ± 0.85 to 2.2 ± 0.80 (p=0.00)
| | | | | Constipation: ↓ from 1.5 ± 0.51 to 1.2 ± 0.41 (p=0.01)
| | | | | Defecation behavior: ↓ from 2.8 ± 0.39 to 1.4 ± 0.55 (p=0.00)
| | | | | Straining technique: ↓ from 2.5 ± 0.67 to 1.2 ± 0.43 (p=0.00)
| | | | | No difference based on age
Mentally Handicapped Children
Ando 1977 | Operant conditioning | Prospective cohort | Self-initiated elimination | | N=5 | One should not expect the same dramatic results in TT autistic children that have been shown in the profoundly retarded. Suggest a long baseline record of elimination and a long treatment period plus individual study to determine positive and negative reinforcers.
| | | | | 4/5 (80%) achieved improved self-initiated elimination (SIE):
| | | | | 1 improved SIE by 50% in 11 mos
| | | | | 1 improved SIE by 60% in 3 mos
| | | | | 1 improved SIE by 32% in 3 mos
| | | | | 1 improved SIE by 18% in 12 mos
| | | | | 1 made no progress
| | | | | None completely eliminated inappropriate urination
| | | | | Better result in those with some receptive language skills
Colwell 1973 | Operant conditioning | Prospective cohort | Toileting skills under verbal control (top score 18) | Dressing skills | N=47 | The majority made significant gains in toileting, dressing, and feeding skills and also improved mental age score.
| | | | Feeding skills | (results achieved in ~ 7.1 mos)
| | | | Mental age | Mean toileting score ↑ from 6.0 ± 4.7 to 10.0 ± 4.7 (p<0.001)
| | | | | 33/47 (70%) made gains
| | | | | 8/47 (17%) made no gains
| | | | | 3/47 (6%) regressed from baseline
Connolly 1976 | Operant conditioning | Prospective cohort | Wetting incidents | | N=9 | Positive use of operant conditioning can help toilet train the severely mentally handicapped.
| | | Soiling incidents | | (results at 7 wk followup)
| | | Successful toileting following accident free period | | Wetting accidents ↓ 14% and soiling accidents ↓ 25%
| | | | | 2/9 (22%) were successfully trained
| | | | | Successful toileting following accident free period periods continued to decrease
Didden 2001 | Azrin and Foxx (modified) | Prospective cohort | Accidents and correct toileting/day and at 2.5 yr.post training followup | Time spent training | N=6 | Azrin and Foxx TT significantly increased correct prompted toileting that was sustained at followup. It somewhat decreased accidents.
| | | | | (results at 2.5 yr.followup)
| | | | | Mean incorrect toileting/day ↓ from 1.65 ± 1.76 to 0.12 ± 0.29 at followup (p=0.07)
| | | | | Mean correct toileting/day ↑ from 0.80 ± 0.95 to 3.1 ± 1.57 (p=0.02)
| | | | | Mean TT time was 17.2 days (range 12–25) and 108 ± 31 hrs
Giles 1966 | Operant conditioning | Prospective cohort | Consistent self-initiated (SI) bowel and bladder elimination in the toilet | | N=5 | Operant conditioning can be an effective means of establishing self-care behavior in institutionalized retardates. Reinforcement must be tailored individually.
| | | | | 5/5 (100%) success
| | | | | Individual results:
| | | | | 1 achieved consistent SI bowel & urine elimination at 3 wks; night soiling ended at 5 wks
| | | | | 1 achieved consistent SI bowel & urine elimination at 7 wks
| | | | | 2 achieved consistent SI bowel & urine elimination at 8 wks
| | | | | 1 achieved consistent ‘other’ initiated bowel elimination at 3 wks; urine at 8 wks with some SI
Holverstott-Cockrell 2002 | Azrin and Foxx | Prospective cohort | Bowel and bladder successes and accidents | Intervention acceptability | N=10; 9 completed | Postprogram, there was a significant increase in successes and fewer accidents across all classrooms (4 children continued to have accidents). The intervention was highly acceptable but not carried out consistently by teachers (did not like dry pants checks and positive reinforcement for being dry) and, thus, possibly decreased effectiveness of the intervention. Only a few parents returned data indicating low parental participation
| Study takes place in 4 special education preschool classrooms in the same school district. Children attended 1/2 days. | | | Parent participation | (results at 6 wk)
| | | | | Classroom A: n=4
| | | | | Trend of successes ↑ from 0.6 (0–1) to 4.0 (0–8)/day, accidents ↓ from 2.2 (1–3) to 1.2 (0–3)/day
| | | | | Classroom B: n=2
| | | | | Trend of successes remained stable (from 2.4 (1–4) to 4.3 (1–8)/day), accidents ↓ from 1.1 (0–3) to 0.7 (0–3)/day)
| | | | | Classroom C: n=2
| | | | | Trend of successes remained stable (from 2.2 (1–3) to 3.2 (0–6)/day), accidents ↓ 1.2 (0–2) to 0.3 (0–2)/day)
| | | | | Classroom D: n=2
| | | | | Trend of successes ↑ from 0.07 (0–1) to 2.1 (0–4)/day, accidents ↓ from 1.5 (0–2) to 0.6 (0–2)/day
Kimbrell 1967 | Operant conditioning v. conventional group | Prospective cohort | Vineland social maturity scale (VSMS) scores (social age, social quotient) | Comparisons based on age Laundry use | N=40 | Improved scores on VSMS for social age and social quotient. Soiling decreased and laundry use was cut in half.
| | | Frequency of soiling | Change in social age and social maturation | (results at 7 mos)
| | | | | VSMS scores (post test)
| | | | | Social age: OC: ↑ 0.42 v. CG: ↑ 0.10 (p<0.05)
| | | | | Social quotient: OC ↑ 3.30 v. CG ↓ -0.15 (p=ns)
| | | | | Toilet Training: OC ↑ 4.10 v. CG ↑ 0.30 (p<0.001)
| | | | | No significant developmental gains
| | | | | No differences based on age
| | | | | Experimental group laundry use cut in half
Lancioni 1980 | Azrin and Foxx (modified) | Prospective cohort | Independent toileting for urination | Partially-independent, incomplete, and assisted toileting | N=9 | Comparisons based on age, sex, sensory condition, and degree of self-stimulation were not significant. Suggest punishment may or may not have played a useful role. Some achieved bowel control as well.
| | | | Urinary accidents | (results at 44 day followup)
| | | | Comparisons based on age, sex, sensory condition, and degree of self stimulation | 9/9 (100%) achieved daytime independence and accidents ↓ to zero
| | | | | Partial and incomplete toileting not present
| | | | | 1/9 (11%) continued to have occasional accidents
Lancioni 1981 | Other: Intervention A: 25 potties in training setting v. Intervention B: no potties displayed | Prospective cohort | Independent toileting | Partially-independent, incomplete, and assisted toileting Urinary accidents | N=5 | Intervention A: All increased independent toileting and decreased accidents while continuing normal programs unaltered. The immediate presence of potties may be crucial for developing independence.
| Punishment used | | | | (results at 60 day followup)
| | | | | Intervention A: 5/5 (100%) achieved independent toileting that continued at 60-day followup
| | | | | Mean successes:
| | | | | 6.8 actions/day
| | | | | 2 had no accidents
| | | | | 3 had the odd accident
| | | | | Intervention B was not effective: when switched to Intervention A with potties improvement began
Lancioni 1981 | Other: Intervention A: 25 potties in training setting v. Intervention B: no potties displayed | Prospective cohort | Independent toileting | Partially-independent, incomplete, and assisted toileting | N=4 | Intervention A: All increased independent toileting and decreased accidents; results continued at followup. Suggest punishment useful in those who have history of accidents, but not necessary in those who toilet when prompted or assisted.
| No punishment used | | | Urinary accidents | (results at 60 day followup)
| | | | | Intervention A: 4/4 (100%) achieved independent toileting that continued at 60-day followup
| | | | | Mean successes:
| | | | | 6.5 actions/day
| | | | | 1 accident occurred
| | | | | Intervention B was not effective: when switched to Intervention A with potties improvement began
Spencer 1973 | Operant conditioning | Prospective cohort | Index of bowel control | | N=38 | Operant conditioning can improve toileting behaviors in the profoundly retarded.
| | | | | (results at 6 wk)
| | | | | Accidents ↓ by 17%
| | | | | Spontaneous toileting ↑ 9%
| | | | | Those who had greater initial bowel control did not improve, those totally incontinent showed considerable progress
Smith 1977 | Azrin and Foxx | Retrospective cohort | Wetting accidents/wk | | N=8 | Significant drop in wetting accidents. Those <20 yr.trained faster; those with SA 2–2.5 yr.progressed faster than those with SA 1.5–2 yr.
| | | | | (results at 10 wk)
| | | | | Wetting accidents:
| | | | | Younger, low social age (SA):
| | | | | 2/5 (40%) averaged 1 accident/wk
| | | | | Younger, high SA: 3/3 (100%) zero accidents
Tierney 1973 | Operant conditioning v. control | Controlled clinical trial | Reduced incontinence | Soiled linen | N=36 | Operant conditioning led to improvement. A significant reduction in use of nappies, laundry and staff time to manage incontinence was attributed to operant conditioning. Also noticed general functional improvement among the operant conditioning group.
| | | Successful continence of urine and feces on 16-level scale where 16=independent | Staff workload | (results on 18 experimental patients at 30 day followup)
| | | | Number in nappies | OC: 14/18 (78%) improved and were removed from diapers
| | | | | 7/18 (39%) achieved level 4
| | | | | 5/18 (28%) achieved level 3
| | | | | 2/18 (11%) achieved level 2
| | | | | 6/18 (33%) achieved nocturnal continence
| | | | | 4/18 (22%) showed no improvement
| | | | | Behavior relating to ‘sitting’ levels (5–8) more easily achieved than behavior relating dressing (9–12) and ‘going to the toilet’ (13–16) levels
| | | | | Control: showed minimal improvement
Van Wagenen 1969 | Other: auditory signal followed by rapid forward moving series of training events | Prospective cohort | Criterion levels 1–6 where 6= self-initiated urination with no prompts | | N=9 | This procedure successfully trained the profoundly retarded subjects and the training transferred to other environments.
| | | | | (results at 19.5 hr to 22 days)
| | | | | 9/9 (100%) achieved level 6

CCT indicates controlled clinical trial; GTRP: group training regular potting; IIRP: intensive/individual regular potting; IITP: intensive/individual timed potting; mos: months; NS: not significant; OC: operant conditioning; RCT: randomized controlled trial; SCH: scheduled; STR: stool toileting refusal; TTLD: toilet training in less than a day

Table D-10 Outcomes and results of included studies (observational studies and trials)

Author-Year | Toilet Training Method(s) | Study Design | Primary Outcome | Other Outcomes or Effect Modifiers | Results | Conclusions
Healthy children
Candelora 1977 | Azrin and Foxx (TTLD) v. Dr. Spock | RCT | Mean bowel and bladder accidents/day | Successes | N=71 | The TTLD approach was significantly more effective: accidents decreased, successes increased, and there was significantly less morning wetness at pre and posttreatment. Both continued to improve at same rate on followup. Both encountered similar problems during training (refusal to comply, tantrums, loss of parental interest due to failure, and miscellaneous others). Parents found TTLD more helpful.
| | | | Wet or soiled mornings | (results at 3 wk)
| | | | | Mean accidents/day/child: post training/ followup
| | | | | TTLD: 2.28/1.59
| | | | | Dr. Spock: 3.02/2.50
| | | | | Mean successes /day/child: post training/ followup
| | | | | TTLD: 2.84/3.71
| | | | | Dr. Spock: 1.3/2.09
| | | | | Mean wet mornings: post training/ followup
| | | | | TTLD: 73/63
| | | | | Dr. Spock: 81/73
| | | | | Mean change from baseline in accidents (p=0.007)
| | | | | TTLD: 2.48
| | | | | Dr. Spock: 1.37
| | | | | Mean change from baseline in successes (p=0.003)
| | | | | TTLD: 2.50
| | | | | Dr. Spock: 1.12
| | | | | Mean difference in proportion of mornings children were wet (p=0.011)
| | | | | TTLD: 21%
| | | | | Dr. Spock: 6%
| | | | | Followup results for TTLD v. Dr. Spock were not significant
| | | | | 24–35 mo. performed better than 18–23 mos
Healthy Children
Matson 1977 | Azrin and Foxx (book + supervision) v. Azrin and Foxx (book only) | RCT | Number of accidents | Emotional side effects | N=10 | Training was more effective and emotional side effects (tantrums & avoidance) were more easily overcome for mothers and children in supervised group. Children <24 mo. took longer to train.
| | | | | (results at 10 wk)
| | | | | Book + supervision
| | | | | 4/5 (80%) trained in 5 sessions (4–18 hr)
| | | | | 1/5 (20%) continued to have accidents
| | | | | 1/5 (20%) dropped out
| | | | | Book
| | | | | 1/5 (20%) trained in 1.5 sessions (6 hr)
| | | | | 1/5 (20%) partially trained in 5 sessions (20 hr)
| | | | | 3/5 (60%) failures
| | | | | 3/10 (30%) of children trained also stopped nighttime wetting
Taubman 2003 | Child-orientated approach with handbook, pre-training praise and no negative terminology v. child-orientated approach with handbook | RCT | Stool toileting refusal (STR) | Hiding while defecating | N=381 | Intervention had no effect on (1) incidence of STR but shortened its duration therefore earlier completion of TT or (2) incidence of hiding while defecating.
| | | | Effect of age begun TT on duration | 381/381 (100%) trained by 3.5 ± 0.5 yr | Early initiation of TT correlated with longer duration but earlier completion, but was not associated with constipation, stool withholding, or STR.
| | | | Age at completion | During training: | Little benefit in intensive TT < 27 mo. STR proceeded by constipation, painful movements, and may be associated with late TT initiation. Hiding behavior was associated with STR, constipation, and stool withholding.
| | | | | Incidence STR (p>0.10)
| | | | | Handbook plus: 26%
| | | | | Handbook: 23%
| | | | | Duration STR (p=0.03)
| | | | | Handbook plus: 5.1 ± 3.2 mo.
| | | | | Handbook: 7.3 ± 6.0 mos
| | | | | Incidence stool withholding (p>0.10)
| | | | | Handbook plus: 55%
| | | | | Handbook 2: 52%
| | | | | Incidence of hiding (p>0.10)
| | | | | Handbook plus: 70%
| | | | | Handbook 68%
| | | | | Age TT completed
| | | | | Handbook plus: 43 ± 6.5 mos
| | | | | Handbook: 40 ± 6.4 mos
Mentally Handicapped Children
Edgar 1975 | Operant conditioning: relaxation-tension exercise regimen v. control | RCT | Frequency of accident | | N=20 | Operant conditioning is an adjunct to promoting appropriate behavior but self-initiation might be too stringent a criterion for severely/profoundly retarded. It worked well in those who showed a tendency to hold fluids and those who constantly dribbled with no control of muscles involved in urination
| | | Appropriate urination | | (results at 2 wks)
| | | | | Mean adjusted accident score/8hr (p<0.05)
| | | | | OC: 0.37
| | | | | Control: 2.13
| | | | | Mean adjusted appropriate score/8hrs (p<0.05)
| | | | | OC: 8.1
| | | | | Control: 3.9
| | | | | No change:
| | | | | OC: 2/10 (20%)
| | | | | Control: 8/10 (80%)
Hundziak 1965 | Operant conditioning v. conventional v. control | RCT | Use of toilet for bowel and bladder elimination | Transfer of behavior to other settings | N=29 | Operant conditioning showed significant increase in use of bathroom for bowel and bladder elimination. Conventional group showed no change and control group improved for urination only. Abilities were transferred to original living unit.
| | | | | (results at 27 days)
| | | | | Median (IQ range) difference pre/post scores for defecation in toilet
| | | | | OC: 1 (0,3) (p=0.032)
| | | | | Conventional: 0 (0, 0.5) (p=NS)
| | | | | Control: 0 (0,1) (p=NS)
| | | | | Median (IQ range) difference pre/post scores for urination in toilet
| | | | | OC: 9 (2,10) (p=0.016)
| | | | | Conventional: 1 (-0.5, 2.5) (p=NS) Control: 1 (0,3) (p=0.032)
| | | | | Control: 1 (0,3) (p=0.032)
Hyams 1992 | Intensive/individual regular potting (IIRP) v. group training regular potting (GTRP) v. Intensive/individual timed potting (IITP) | RCT | Decreased incontinence | Cost effectiveness Training time | N=15;5 / group | Intensive/individual regular training was the most successful and cost effective followed by timed training. GTRP was the least successful. Equipment was problematic and the prompt and fade procedure complex. On followup, there was complete independent toileting not maintained but prompting was considerably less than in pre-training.
| | | Increased independence | | (results at end training/10 yr.followup)
| | | | | Independent
| | | | | IIRP: 5/5 (100%) / 1/5 (20%)
| | | | | GTRP: 1/5 (20%) / 0 (0%)
| | | | | IITP: 4/5 (80%) / 0/5 (0%)
| | | | | No. of incontinent episodes/wk (% reduction from baseline) at 12 wk / 10 yr
| | | | | IIRP: 1 (99%) / 8 (88%)
| | | | | GTRP: 52 (39%) / 41 (52%)
| | | | | IITP: 23 (80%) / 30 (74%)
| | | | | Nurse training hours
| | | | | IIRP: 2330
| | | | | GTRP: 1260
| | | | | IITP: 2079
Sadler 1977 | Azrin and Foxx v. scheduled (SCH) v. control | RCT | Urine accidents/day | Staff preference | N=14 | Azrin and Foxx virtually ended daytime wetting in school setting with considerable generalization to the home. Azrin and Foxx required much more time and energy than the other programs. Scheduling somewhat reduced accidents.
| | | | Training time | (results at 3 mos/4 mos)
| | | | | Mean wets/day
| | | | | AF: ↓ from 1 to 0.20 / 0.11 (p<0.01)
| | | | | SCH: ↓ from 0.95 to 0.77 / 0.57
| | | | | Control: ↓ from 0.88 to 1.07 / 0.63
| | | | | Median time required in hours
| | | | | AF: 35
| | | | | SCH: 5.3
| | | | | Control: 2.9
Physically Handicapped Children
van Kuyk 2001 | Operant conditioning v. waiting list control | CCT | Bowel continence (Templeton, Wingspread, and constipation scores) | Comparisons based on age | N=27 | OC group exhibited significant change on all outcomes over waiting list group. Multidisciplinary behavioral intervention effective in treatment of constipation and incontinence in children with Hirschsprung's disease. There was no difference based on age. Success was maintained at followup.
| | | Feces in the toilet | | (results at 9 mo.)
| | | Days without soiling | | Templeton score (p<0.001)
| | | Scale parental judgment incontinence | | OC: 1.3 ± 0.4
| | | | | Waiting list: 2.2 ± 0.8
| | | | | Wingspread score (p<0.001)
| | | | | OC: 1.8 ± 0.6
| | | | | Waiting list: 2.9 ± 1.1
| | | | | Constipation (p<0.05)
| | | | | OC: 1.1 ± 0.4
| | | | | Waiting list: 1.7 ± 0.6
| | | | | Feces in the toilet (p<0.001)
| | | | | OC: 82.7%
| | | | | Waiting list: 40.2%
| | | | | Days without soiling (p<0.001)
| | | | | OC: 10.8 ± 3.0
| | | | | Waiting list: 5.9 ± 5.4
| | | | | Parental judgment incontinence scale (p<0.05)
| | | | | OC: 12.4 ± 5.2
| | | | | Waiting list: 16.4 ± 7.1