# Appendix C: Multiple Publications of Toilet Training Cohorts

During study screening and data extraction, several articles were identified in which it appeared that different outcomes or outcomes at followup were reported for the same cohort of children. We did not want either to exclude any relevant results or to over-represent results when the same outcome had been reported for a cohort in multiple publications. After critically reviewing the references to prior publications and cross-referencing patient demographics, the primary (usually the most recent) publication for these cohorts was identified. The cohorts and associated multiple publications are described below.

Linked References | Rationale
Taubman 2003a^1^*; Blum 2004a^2^; Taumban 2003b^3^; Blum 2003^4^; Blum 2004^5^ | Taubman et al. (2003a) examines 406 children who were randomized either to the child-oriented approach in combination with avoiding negative terminology to describe defecation and praising defecating in diapers or to the child-oriented approach alone. The incidence of stool toileting refusal is similar in both groups; however, the duration of stool toileting refusal is shorter among the intervention group. Blum et al. (2004a) explores factors related to the increasing age at which toilet training is successful among the same 406 children and data are analyzed as a prospective cohort study; Taubman et al. (2003) is referenced in Blum et al. (2004a). Taubman et al. (2003b) examines 408 children, comparing those who hide while defecating with those who do not, and the data are analyzed as a case-control study. Blum et al. (2003) determines the correlation between age at initiation and completion of toilet training and duration of toilet training among 406 children, and the data are analyzed as a prospective cohort study. Blum et al. (2004b) follows up 380 of 406 children, to compare those who develop stool toileting refusal with those who do not. The data are analyzed as a case-control study and Taubman (2003a) is referenced in Blum et al. (2004b). The reported baseline demographics of the individual studies are very similar.
Hyams 1992 ^6^*; Smith 1979^7^ | Smith et al. (1979) examines a cohort of 14 severely and profoundly mentally handicapped children who were toilet trained with individual intensive regular toileting, group intensive regular toileting, or individual timing toileting. Hyams et al. (1992) describes a 10-year followup of this cohort and references the original study conducted by Smith et al. (1979).
Van Wagenen 1969a^8^*; Van Wagenen 1969b^9^ | Van Wagenen et al. (1969a) describes nine profoundly mentally handicapped children who were toilet trained with a forward-moving series of toileting events. Van Wagenen et al. (1969b) examines what appear to be the same nine children; the data were presented at the 77^th^ Annual APA Convention.

* primary publication

## Reference List for Appendix C

1 Taubman B, Blum NJ, Nemeth N. Stool toileting refusal: a prospective intervention targeting parental behavior. Arch Pediatr Adolesc Med. 2003;157(12):1193-6. [pmid: 14662573].
2 Blum NJ, Taubman B, Nemeth N. Why is toilet training occurring at older ages? A study of factors associated with later training. J Pediatr. 2004;145(1):107-11. [pmid: 15238916].
3 Taubman B, Blum NJ, Nemeth N. Children who hide while defecating before they have completed toilet training: a prospective study. Arch Pediatr Adolesc Med. 2003;157(12):1190-2. [pmid: 14662572].
4 Blum NJ, Taubman B, Nemeth N. Relationship between age at initiation of toilet training and duration of training: a prospective study. Pediatrics. 2003;111(4):810-4. [pmid: 12671117].
5 Blum NJ, Taubman B, Nemeth N. During toilet training, constipation occurs before stool toileting refusal. Pediatrics. 2004;113(6):e520-2. [pmid: 15173531].
6 Hyams G, McCoull K, Smith PS, et al. Behavioural continence training in mental handicap: a 10-year follow-up study. J Intellect Disabil Res. 1992;36:551-8. [pmid: 1477492].
7 Smith PS. A comparison of different methods of toilet training the mentally handicapped. Behav Res Ther. 1979;17(1):33-43. [pmid: 109075].
8 Van Wagenen RK, Meyerson L, Kerr NJ, et al. Field trials of a new procedure for toilet training. J Exp Child Psychol. 1969;8(1):147-59. [pmid: 5804588].
9 Van Wagenen R, Keith ML, Kerr NJ, et al. Rapid toilet training: learning principles and prothesis. Proceedings of the Annual Convention of the American Psychological Association. 1969;4:781-2.