# Appendix B: Sample Forms

To see the Sample Forms, please select the link below. This link will take you to a PDF version of the forms.

Sample Forms