# Appendix A: Exact Search Strings

Table A-1 MEDLINE^®^—Ovid Version: rel10.2.0

1966 to May Week 4 2005
Searched June 2, 2005
Set # and Keyword Search
1 exp Toilet Training/; 2 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.; 3 or/1–2
Results: 753

Table A-2 OLDMEDLINE^®^—Ovid Version: rel10.2.0

1950 to 1965
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 8

Table A-3 MEDLINE^®^ In-Process & Other Non-Indexed Citations—Ovid Version: rel10.2.0

Searched June 1, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 7

Table A-4 EBM Reviews - Cochrane Central Register of Controlled Trials—Ovid Version: rel10.2.0

1950 to 2nd Quarter 2005
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 40

Table A-5 EMBASE—Ovid Version: rel10.2.0

1988 to 2005 Week 22
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 194

Table A-6 CINAHL^®^ (Cumulative Index to Nursing & Allied Health Literature)—Ovid Version: rel10.2.0

1982 to May Week 4 2005
Searched June 2, 2005
Set # and Keyword Search
1 exp Toilet Training/; 2 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.; 3 or/1–2
Results: 190

Table A-7 PsycINFO^®^—Ovid Version: rel10.2.0

1872 to May Week 4 2005
Searched June 2, 2005
Set # and Keyword Search
1 exp toilet training/; 2 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.; 3 or/1–2
Results: 437

Table A-8 ERIC^®^ (Educational Resources Information Center)—Ovid Version: rel10.2.0

1966 to July 2004
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.; 2 exp Toilet Training/; 3 or/1–2; 4 limit 3 to “audiovisual or non print materials”; 5 3; 6 limit 5 to (“guides for all non classroom use” or guides for classroom use, learner or guides for classroom use, teacher or guides, general); 7 3; 8 limit 7 to (“book or product reviews” or books or “collected works (general and serials)”); 9 3 not (4 or 6 or 8)
Results: 87

Table A-9 AMED (Allied and Complementary Medicine)—Ovid Version: rel10.2.0

1985 to May 2005
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 13

Table A-10 EBM Reviews Full Text - Cochrane Database of Systematic Reviews (CDSR), ACP Journal Club (ACPJC), Database of Abstracts of Reviews of Effects (DARE)—Ovid Version: rel10.2.0

CDSR: 2nd Quarter 2005; ACPJC: 1991 to March/April 2005; DARE: 2nd Quarter 2005
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.
Results: 9

Table A-11 HealthSTAR/Ovid Healthstar—Ovid Version: rel10.2.0

1975 to May 2005
Searched June 2, 2005
Set # and Keyword Search
1 ((toilet or potty) adj3 (train$ or learn$ or condition$ or teach$ or educat$ or behavior$ or behaviour$)).mp.; 2 limit 1 to nonmedline
Results: 1

Table A-12 Biological Abstracts—WebSPIRS from SilverPlatter^®^, Version 4.3

1969 to April 2005
Searched June 2, 2005
Set # and Keyword Search
1 (TOILET-TRAINING-AGE) or (TOILET-TRAINING-EATING) or (TOILET-TRAINING-ONSET) or (TOILET-TRAINING-PROCEDURES) or (TOILET-TRAINING-REGRESSION-SLEEP-PATTERN-CHANGE-FEEDING-HABIT-CHANGE-PEER-RELATIONSH) or (TOILET-TRAINING)
Results: 41

Table A-13 Sociological Abstracts—CSA Illumina

1963 to May 2005
Searched June 6, 2005
Set # and Keyword Search
1 Toilet train* or potty train*
Results: 23

Table A-14 Web of Science^®^ (Science Citation Index Expanded and Social Sciences Citation Index)—ISI Web of Knowledge

1900 to June 4, 2005
Searched June 6, 2005
Set # and Keyword Search
1 TS=(toilet train*) OR TS=(potty train*)
Results: 273
The Cited Reference Search feature in Web of Science was used to find articles that cited any of the following:
1 Bakker E, Van Gool JD, Van Sprundel M, et al. Results of a questionnaire evaluating the effects of different methods of toilet training on achieving bladder control. BJU International 2002;90(4):456–61.; 2 Blum NJ, Taubman B, Nemeth N. Relationship between age at initiation of toilet training and duration of training: a prospective study. Pediatrics 2003;111(4):810–4.; 3 Brazelton TB, Christophersen ER, Frauman AC et al. Instruction, timeliness, and medical influences affecting toilet training. Pediatrics 1999;103(6):1353–8.; 4 Issenman RM, Filmer RB, Gorski PA. A review of bowel and bladder control development in children: how gastrointestinal and urologic conditions relate to problems in toilet training. Pediatrics 1999;103(6):1346–52.; 5 Schum TR, Kolb TM, McAuliffe TL, et al. Sequential acquisition of toilet-training skills: a descriptive study of gender and age differences in normal children. Pediatrics 2002;109(3):E48.; 6 Stadtler AC, Gorski PA, Brazelton TB. Toilet training methods, clinical interventions, and recommendations. American Academy of Pediatrics. Pediatrics 1999;103(6):1359–68.; 7 Taubman B, Blum NJ, Nemeth N. Children who hide while defecating before they have completed toilet training: a prospective study. Arch Pediatr Adolesc Med 2003;157(12):1190–2.; 8 Taubman B, Blum NJ, Nemeth N. Stool toileting refusal: a prospective intervention targeting parental behavior. Arch Pediatr Adolesc Med 2003;157(12):1193–6.
Results: 32

Table A-15 Dissertation Abstracts—ProQuest^®^

1861 to May 2005
Searched June 6, 2005
Set # and Keyword Search
1 Toilet train* or toilet learn* or potty train*
Results: 36

Table A-16 NLM Gateway (U.S. National Library of Medicine)

1950 to June 6, 2005
Searched June 6, 2005
Set # and Keyword Search
1 Toilet Training[MESH] OR “toilet train*” or “potty train*”
Results: 0

Table A-17 OCLC ProceedingsFirst—OCLC FirstSearch

1993 to June 6, 2005
Searched June 6, 2005
Set # and Keyword Search
1 Toilet train* or toilet learn* or potty train*
Results: 1

Table A-18 OCLC PapersFirst—OCLC FirstSearch

1990 to June 7, 2005
Searched June 7, 2005
Set # and Keyword Search
1 Toilet train* or toilet learn* or potty train*
Results: 6

Table A-19 Index to Theses—Expert Information Ltd

1970 to May 19, 2005
Searched June 7, 2005
Set # and Keyword Search
1 Toilet train*
Results: 1

Table A-20 National Research Register's Projects Database—Update Software Ltd

2000 to March 2005
Searched June 10, 2005
Set # and Keyword Search
1 Toilet training (Medical Subject Heading)
Results: 3

Table A-21 American Academy of Pediatrics Web site (http://www.aap.org/ (http://http://www.aap.org/))

Searched June 7, 2005
Set # and Keyword Search
1 “toilet training”
Results: 2

Table A-22 Canadian Paediatric Society Web site (http://www.cps.ca/)

Searched June 7, 2005
Set # and Keyword Search
1 toilet training
Results: 1

Table A-23 Current Controlled Trials Web site (http://www.controlled-trials.com/)

Searched June 8, 2005
Set # and Keyword Search
1 toilet training
Results: 0

Table A-24 ClinicalTrials.gov Web site (http://clinicaltrials.gov/)

Searched June 8, 2005
Set # and Keyword Search
1 toilet training
Results: 0