# Appendixes

Appendix A: Exact Search Strings

Appendix B: Sample Forms

Appendix C: Multiple Publications of Toilet Training Cohorts

Appendix D: Evidence Tables

Appendix E: List of Excluded Studies

Appendix F: Technical Expert Panel and Peer Reviewers

Appendix G: Abbreviations

Appendix H: Toilet Training Methods