# List of Acronyms/Abbreviations

ACCE | Analytic validity, Clinical validity, Clinical utility and associated Ethical, legal and social implications
AHRQ | Agency for Healthcare Research and Quality
ASA | Allele-specific amplification
AS-PCR | Allele-specific polymerase chain reaction
AUC | Area under the curve
CDC | Centers for Disease Control and Prevention
CGI | Clinical Global Impressions Scale
CI | Confidence interval
CLIA | Clinical Laboratory Improvement Amendment
C_max_ | Maximum plasma concentration
CYP | Cytochrome P
DARE | Cochrane Database of Abstracts of Reviews of Effects
Del | Deletion (*5 allele)
DSM-IV | Diagnostic and Statistical Manual for Mental Disorders, 4^th^ edition
Dup | Duplication (more than a single gene copy)
EGAPP | Evaluation of Genomic Applications in Practice and Prevention
EM(s) | Extensive metabolizer(s)
FDA | U.S. Food and Drug Administration
GI | Gastrointestinal
HAM-D | Hamilton Rating Scale for Depression
IM(s) | Intermediate metabolizer(s)
MADRS | Montgomery-Åsberg Depression Rating Scale
MDD | Major depressive disorder
MeSH | Medical Subject Headings
NA | Not applicable
NR | Not reported
PCR | Polymerase chain reaction
PCR-RFLP | Polymerase chain reaction and restriction fragment length polymorphism
PM(s) | Poor metabolizer(s)
QLESQ | Quality of Life Enjoyment and Satisfaction Questionnaire
RT-PCR | Real-time polymerase chain reaction
SC | Single gene copy
SF-36 | Medical Outcomes Study 36-Item Short Form Health Survey
SNRI(s) | Serotonin/norepinephrine reuptake inhibitors
SSRI(s) | Selective serotonin reuptake inhibitor(s)
t_1/2_ | Terminal elimination half-life
TCA(s) | Tricyclic antidepressant(s)
UM(s) | Ultra-rapid metabolizer(s)
USPSTF | U.S. Preventive Services Task Force