# Listing of Included Studies (alphabetical)

Allgulander C, Nilsson B. A prospective study of 86 new patients with social anxiety disorder. Acta Psychiatr Scand. 2001;103(6):447-52. [pmid: 11401659].
Berle JO, Steen VM, Aamo TO, et al. Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry. 2004;65(9):1228-34. [pmid: 15367050].
Charlier C, Broly F, Lhermitte M, et al. Polymorphisms in the CYP 2D6 gene: association with plasma concentrations of fluoxetine and paroxetine. Ther Drug Monit. 2003;25(6):738-42. [pmid: 14639062].
Chen S, Chou WH, Blouin RA, et al. The cytochrome P450 2D6 (CYP2D6) enzyme polymorphism: screening costs and influence on clinical outcomes in psychiatry. Clin Pharmacol Ther. 1996;60(5):522-34. [pmid: 8941025].
Chou WH, Yan FX, Robbins-Weilert DK, et al. Comparison of two CYP2D6 genotyping methods and assessment of genotype-phenotype relationships. Clin Chem. 2003;49(4):542-51. [pmid: 12651805].
Eap CB, Bondolfi G, Zullino D, et al. Concentrations of the enantiomers of fluoxetine and norfluoxetine after multiple doses of fluoxetine in cytochrome P4502D6 poor and extensive metabolizers. J Clin Psychopharmacol. 2001;21(3):330-4. [pmid: 11386497].
Eriksson S, Berg LM, Wadelius M, et al. Cytochrome p450 genotyping by multiplexed real-time DNA sequencing with pyrosequencing technology. Assay Drug Dev Technol. 2002;1(1 Pt 1):49-59. [pmid: 15090156].
Gerstenberg G, Aoshima T, Fukasawa T, et al. Relationship between clinical effects of fluvoxamine and the steady-state plasma concentrations of fluvoxamine and its major metabolite fluvoxamino acid in Japanese depressed patients. Psychopharmacology (Berl). 2003;167(4):443-8. [pmid: 12682708].
Grasmader K, Verwohlt PL, Rietschel M, et al. Impact of polymorphisms of cytochrome-P450 isoenzymes 2C9, 2C19 and 2D6 on plasma concentrations and clinical effects of antidepressants in a naturalistic clinical setting. Eur J Clin Pharmacol. 2004;60(5):329-36. [pmid: 15168101].
Hersberger M, Marti-Jaun J, Rentsch K, et al. Rapid detection of the CYP2D6*3, CYP2D6*4, and CYP2D6*6 alleles by tetra-primer PCR and of the CYP2D6*5 allele by multiplex long PCR. Clin Chem. 2000;46(8 Pt 1):1072-7. [pmid: 10926885].
Kawanishi C, Lundgren S, Agren H, et al. Increased incidence of CYP2D6 gene duplication in patients with persistent mood disorders: ultrarapid metabolism of antidepressants as a cause of nonresponse. A pilot study. Eur J Clin Pharmacol. 2004;59(11):803-7. [pmid: 14652703].
Liu ZQ, Cheng ZN, Huang SL, et al. Effect of the CYP2C19 oxidation polymorphism on fluoxetine metabolism in Chinese healthy subjects. Br J Clin Pharmacol. 2001;52(1):96-9. [pmid: 11453896]. [pmcid: 2014504].
LLerena A, Dorado P, Berecz R, et al. Effect of CYP2D6 and CYP2C9 genotypes on fluoxetine and norfluoxetine plasma concentrations during steady-state conditions. Eur J Clin Pharmacol. 2004;59(12):869-73. [pmid: 14726986].
Mizugaki M, Hiratsuka M, Agatsuma Y, et al. Rapid detection of CYP2C18 genotypes by real-time fluorescence polymerase chain reaction. J Pharm Pharmacol. 2000;52(2):199-205. [pmid: 10714950].
Muller B, Zopf K, Bachofer J, et al. Optimized strategy for rapid cytochrome P450 2D6 genotyping by real-time long PCR. Clin Chem. 2003;49(10):1624-31. [pmid: 14500587].
Murphy GM Jr, Kremer C, Rodrigues HE, et al. Pharmacogenetics of antidepressant medication intolerance. Am J Psychiatry. 2003;160(10):1830-5. [pmid: 14514498].
Muthiah YD, Lee WL, Teh LK, et al. A simple multiplex PCR method for the concurrent detection of three CYP2C8 variants. Clin Chim Acta. 2004;349(12):191-8. [pmid: 15469873].
Neville M, Selzer R, Aizenstein B, Characterization of cytochrome P450 2D6 alleles using the Invader system. Biotechniques 2002;Suppl:34–8, 40–3.
Ohara K, Tanabu S, Ishibashi K, et al. CYP2D6*10 alleles do not determine plasma fluvoxamine concentration/dose ratio in Japanese subjects. Eur J Clin Pharmacol. 2003;58(10):659-61. [pmid: 12610741].
Ozdemir V, Tyndale RF, Reed K, et al. Paroxetine steady-state plasma concentration in relation to CYP2D6 genotype in extensive metabolizers. J Clin Psychopharmacol. 1999;19(5):472-5. [pmid: 10505591].
Rau T, Wohlleben G, Wuttke H, et al. CYP2D6 genotype: impact on adverse effects and nonresponse during treatment with antidepressants-a pilot study. Clin Pharmacol Ther. 2004;75(5):386-93. [pmid: 15116051].
Roberts RL, Mulder RT, Joyce PR, et al. No evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline. Hum Psychopharmacol. 2004;19(1):17-23. [pmid: 14716707].
Roche Molecular Systems, Inc. U.S. Food and Drug Administration 510(k) Substantial Equivalence Determination Decision Summary for Roche AmpliChip CYP450 microarray for identifying CYP2D6 genotype (510(k) Number k042259). December 2004. Available at: www.fda.gov/cdrh/reviews/k042259.pdf. Accessed 19 April 2006.
Roche Molecular Systems, Inc. U.S. Food and Drug Administration 510(k) Substantial Equivalence Determination Decision Summary for Roche AmpliChip CYP450 microarray for identifying CYP2C19 genotype (510(k) Number k043576). January 2005. Available at: www.fda.gov/cdrh/reviews/k043576.pdf. Accessed 19 April 2006.
Sawamura K, Suzuki Y, Someya T. Effects of dosage and CYP2D6-mutated allele on plasma concentration of paroxetine. Eur J Clin Pharmacol. 2004;60(8):553-7. [pmid: 15349705].
Schaeffeler E, Schwab M, Eichelbaum M, et al. CYP2D6 genotyping strategy based on gene copy number determination by TaqMan real-time PCR. Hum Mutat. 2003;22(6):476-85. [pmid: 14635107].
Scordo MG, Spina E, Dahl ML, et al. Influence of CYP2C9, 2C19 and 2D6 genetic polymorphisms on the steady-state plasma concentrations of the enantiomers of fluoxetine and norfluoxetine. Basic Clin Pharmacol Toxicol. 2005;97(5):296-301. [pmid: 16236141].
Soderback E, Zackrisson AL, Lindblom B, et al. Determination of CYP2D6 gene copy number by pyrosequencing. Clin Chem. 2005;51(3):522-31. [pmid: 15650034].
Stamer UM, Bayerer B, Wolf S, et al. Rapid and reliable method for cytochrome P450 2D6 genotyping. Clin Chem. 2002;48(9):1412-7. [pmid: 12194916].
Stedman CA, Begg EJ, Kennedy MA, et al. Cytochrome P450 2D6 genotype does not predict SSRI (fluoxetine or paroxetine) induced hyponatraemia. Hum Psychopharmacol. 2002;17(4):187-90. [pmid: 12404686].
Suzuki Y, Sawamura K, Someya T. Polymorphisms in the 5-hydroxytryptamine 2A receptor and cytochromeP4502d6 genes synergistically predict fluvoxamine-induced side effects in Japanese depressed patients. Neuropsychopharmacology. 2006;31(4):825-31. [pmid: 16205777].
Ueda M, Hirokane G, Morita S, et al. The impact of CYP2D6 genotypes on the plasma concentration of paroxetine in Japanese psychiatric patients. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(3):486-91. [pmid: 16423440].
Wang JH, Liu ZQ, Wang W, et al. Pharmacokinetics of sertraline in relation to genetic polymorphism of CYP2C19. Clin Pharmacol Ther. 2001;70(1):42-7. [pmid: 11452243].
Weise A, Grundler S, Zaumsegel D, et al. Development and evaluation of a rapid and reliable method for cytochrome P450 2C8 genotyping. Clin Lab. 2004;50(34):141-8. [pmid: 15074466].
Wu X, Zhou Y, Xu S. Detection of CYP I A1 polymorphisms with a colorimetric method based on mismatch hybridization. Clin Chim Acta. 2002;323(12):103-9. [pmid: 12135810].
Yoon YR, Cha IJ, Shon JH, et al. Relationship of paroxetine disposition to metoprolol metabolic ratio and CYP2D6*10 genotype of Korean subjects. Clin Pharmacol Ther. 2000;67(5):567-76. [pmid: 10824636].
Yu BN, Chen GL, He N, et al. Pharmacokinetics of citalopram in relation to genetic polymorphism of CYP2C19. Drug Metab Dispos. 2003;31(10):1255-9. [pmid: 12975335].