# Executive Summary

## Introduction

Major depressive disorder (MDD) is widely distributed in the population and is associated with substantial symptom severity and role impairment. It is the fourth leading cause of disease burden, accounting for 4.4 percent of total disability-adjusted life years in the year 2000, and it causes the largest amount of non-fatal burden, accounting for almost 12 percent of all total years lived with disability worldwide. In naturalistic studies of followup of depression, almost 60 percent of patients show either residual symptoms or no response to treatment at the end of 1 year.

Selective serotonin reuptake inhibitors (SSRIs) have become first-line drugs in the treatment of depression partly because of their better tolerability and relative safety in overdose compared with older tricyclic antidepressants. The response rate to SSRIs in short-term trials is approximately 50 to 60 percent. As with other antidepressants, a primary limitation of SSRIs is time to response, with most SSRIs showing a benefit only after 2 to 4 weeks of adequate dosing. In addition, even this class of drugs is associated with intolerable adverse effects necessitating discontinuation of medication in 12 to 15 percent of patients in short-term studies. Because of variable efficacy and tolerability among patients, SSRIs are usually titrated through a process of trial and error, potentially further lengthening the time to response.

The cytochrome P450 (CYP450) enzymes are an isoenzyme superfamily that catalyze the oxidation of many drugs and chemicals. The CYP450 enzymes - primarily CYP2D6, CYP2C19, and CYP2C9 - are involved in the metabolism of all of the SSRIs. Genetic polymorphisms have been identified for some of the CYP450 enzyme genes, with inactivating alleles that may decrease or eliminate enzyme activity, or multiple copies of functional genes that may increase enzyme activity. There has been increasing interest in the role of genetic polymorphisms of CYP450 enzymes in metabolism of SSRIs, and several tests are now available to test for CYP450 polymorphisms. A significant recent development was the approval by the U.S. Food and Drug Administration (FDA) of the Roche AmpliChip^®^ CYP450 Test for this purpose. This product delivers the results of testing for CYP2D6 and CYP2C19 polymorphisms in the form of “predicted phenotypes” - poor metabolizers (PMs), intermediate metabolizers (IMs), extensive metabolizers (EMs), and ultra-rapid metabolizers (UMs). The availability of these tests has brought the field of pharmacogenetics to the threshold of influencing clinical practice.

The Agency for Healthcare Research and Quality (AHRQ), on behalf of the Centers for Disease Control and Prevention (CDC) Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Project, requested the development of the present evidence report, which will be used to inform the EGAPP Working Group's formulation of evidence-based recommendations.

A team of investigators at the Duke Evidence-based Practice Center comprised of experienced investigators in health policy, psychiatry, and pharmacogenetics, developed the report, which provides a clear view of the current state of the science in CYP450 polymorphism testing in depression, and - where research is now insufficient for policy decisionmaking - proposes a list of rational research priorities.

## Methods

Working with AHRQ, the CDC, and members of the project's technical expert panel, we developed the following key research questions:

- Question 1: Does testing for CYP450 polymorphisms in adults entering SSRI treatment for non-psychotic depression lead to improvement in outcomes, or are testing results useful in medical, personal, or public health decisionmaking? (overarching question)
- Question 2: What is the analytic validity of tests that identify key CYP450 polymorphisms?
- Question 3a: How well do particular CYP450 genotypes predict metabolism of particular SSRIs? Do factors such as race/ethnicity, diet, or other medications, affect this association?
- Question 3b: How well does CYP450 testing predict drug efficacy? Do factors such as race/ethnicity, diet, or other medications, affect this association?
- Question 3c: How well does CYP450 testing predict adverse drug reactions? Do factors such as race/ethnicity, diet, or other medications, affect this association?
- Question 4a: Does CYP450 testing influence depression management decisions by patients and providers in ways that could improve or worsen outcomes?
- Question 4b: Does the identification of the CYP450 genotypes in adults entering SSRI treatment for non-psychotic depression lead to improved clinical outcomes compared to not testing?
- Question 4c: Are the testing results useful in medical, personal or public health decisionmaking?
- Question 5: What are the harms associated with testing for CYP450 polymorphisms and subsequent management options?

We also developed a project-specific analytic framework that provides an explicit link between CYP450 testing and various health outcomes of importance to decisionmakers.

We searched MEDLINE^®^ (1966-May 2006), the Cochrane Database of Abstracts of Reviews of Effects (DARE), PsychInfo, HealthSTAR, and CINAHL. Searches of these databases were supplemented by reviews of the reference lists contained in all included articles and in relevant review articles. Documents from the FDA that could be publicly accessed were also included. The searches yielded a total of 1,200 citations. Pairs of researchers independently reviewed each abstract and selected 140 for full-text review. Project-specific inclusion/exclusion criteria were developed, and both researchers were required to agree on inclusion status at the full-text stage. A total of 37 articles were included for data abstraction.

Evidence tables were developed, and data abstraction was carried out by one investigator and checked for accuracy and completeness by another. At the data abstraction stage, researchers were asked to evaluate each included article for factors affecting internal and external validity using guidelines from ACCE criteria for analytic validity (for Question 2) and by the Oxford Centre for Evidence-based Medicine (for all other key questions).

The draft version of this report was reviewed by a panel of experts vetted by AHRQ, and reviewer comments and suggestions have been incorporated into the final report.

## Results

Results are summarized below by key question.

### Question 1 (Overarching Question)

No studies were identified that directly addressed any aspect of Question 1.

### Question 2 (CYP450 Test Analytic Validity)

We identified 12 published articles and two documents from the FDA website (on performance of the Roche AmpliChip^®^) that described methods for genotyping various CYP450 enzymes (nine pertaining to CYP2D6, three to CYP2C19, two to CYP2C8, and one each to CYP2C9 and CYP1A1). Of the studies of CYP450 enzymes most relevant to SSRI metabolism (CYP 2D6, 2C19, and 2C9), only four used the gold standard comparison (DNA sequencing), while others were methods comparisons. Notably, very few of the known polymorphisms of the CYP enzymes were tested. Sensitivity and specificity were high (in the range of 94 to 100 percent) for these studies, but confidence intervals for analytic sensitivity for most genotypes were very wide because of the relatively few samples tested. Gene deletion and duplication studies had lower sensitivity and specificity, further compounded by the limitation that there is no accepted gold standard for such tests.

### Question 3a (CYP450 Genotypes and Metabolism of SSRIs)

Sixteen studies met our inclusion criteria, of which five were conducted in healthy adults after a single dose of an SSRI. Of these, three showed that CYP2C19 PMs have significantly higher area under the curve (AUC), longer half-life, and reduced oral clearance of the parent drug, and significantly lower AUC, and lower maximum plasma concentration (C_max_) of the metabolite of each drug than EMs (drugs studied were sertraline, fluoxetine, and citalopram). Similar results were found in a study of CYP2D6*10 (associated with PM status) in healthy volunteers after a single dose of paroxetine, while another study of CYP2D6 using multiple doses of paroxetine found no significant difference between PMs and EMs. The remaining 11 studies were in clinical patients in treatment with SSRIs, were heterogeneous, had small sample sizes, and showed mixed results with respect to the association between CYP2D6/CYP2C9/CYP2C19 polymorphisms and SSRI blood levels.

### Question 3b (CYP450 Testing and Efficacy of SSRIs)

We identified only five studies, three of which involved cohorts of depressed patients in antidepressant treatment. Of these, one found no differences in the proportion of responders among CYP2D6 EMs, IMs, and PMs treated with fluvoxamine. The second found that although plasma concentrations varied significantly between groups (with respect to 2D6 and 2C9 metabolizer status), levels above or below the lower limit of presumed therapeutic levels did not predict response. The third found no differences in depression scores between two groups, CYP2D6 UMs + EMs versus PMs + IMs, treated with paroxetine. The other two studies found significantly higher proportions of CYP2D6 PMs in non-responders to CYP2D6 metabolized SSRIs compared to the general population. The studies had several limitations including non-randomized designs, inadequate power, studying several SSRIs together as a group, and not accounting for other genetic factors that may influence SSRI efficacy (e.g., genetic variations in serotonin transporter proteins or serotonin receptor proteins).

### Question 3c (CYP450 Testing and Adverse Drug Reactions)

We identified nine studies, three of which reported adverse effects in CYP PMs only as a secondary finding. Of the other six, three reported no differences in rates of adverse effects between CYP2D6 PMs and EMs, while a fourth reported no differences in adverse effects between the combined PM + IM and EM + UM groups. One study found a greater prevalence of gastrointestinal adverse effects in PMs compared to EMs. This study also found that the combination of CYP2D6 polymorphism and serotonin receptor 5HT2A polymorphism predicted gastrointestinal adverse effects. Two studies found a significantly higher prevalence of PMs in depressed patients with adverse effects than in the general population. The studies had several limitations including non-randomized design, inadequate power, and not accounting for other genetic factors that may influence SSRI tolerability (e.g., genetic variations in serotonin receptor proteins).

### Questions 4 and 5 (Management Decisions, Clinical Outcomes, Decisionmaking, and Harms)

No studies were identified that directly addressed any aspect of these questions.

### Model of Treatment for Major Depression

As a complement to the evidence review, we constructed a basic decision model to consider the circumstances under which testing for CYP polymorphisms could improve clinical outcomes, or favorably impact costs. We examined four strategies: (1) use a non-CYP metabolized SSRI without testing; (2) test and choose a non-CYP or CYP metabolized SSRI based on the result; (3) test and choose the dose of a CYP metabolized SSRI based on the result; and (4) use a CYP metabolized SSRI without testing. In no plausible scenario was a testing strategy predicted to improve expected outcomes of treatment at 6 weeks. The efficacy of a test strategy could approach the efficacy of use of a non-CYP metabolized drug, although this required the condition that a high correlation exist between genotype and phenotype (metabolizer status), as well as between phenotype and clinical outcomes. Current evidence does not support the conclusion that such high correlations apply. Moreover, the cost of testing is not offset by treatment savings if treatment duration is less than approximately 9 months.

## Discussion

Our literature review revealed a paucity of high-quality clinical studies addressing the key questions. We did not find a single prospective study of CYP450 genotyping and its relationship to clinical outcomes. General limitations of the available evidence include:

- Most studies were small, poor-quality studies examining prevalence rates of certain genotypes in a sample or examining the correlation between various genotypes and limited clinical outcomes, such as response or adverse effects.
- There were no randomized studies of alternative testing strategies.
- Many reports did not take into account concurrent medications. No studies examining interactions between CYP polymorphisms and CYP inhibiting or CYP inducing drugs were identified.
- Several studies looked at limited genotypes and did not account for the fact that more than one CYP enzyme may be involved in the metabolism of a specific SSRI.
- Several studies grouped together multiple SSRIs, or SSRIs with other antidepressants such as tricyclics.
- Genetic factors affecting serotonin receptor proteins, membrane transporters, and signal transduction molecules have important pharmacodynamic effects that could affect SSRI efficacy or tolerability. These were not taken into account in any of the studies.

The rated quality of data did not improve even when we were generous in our inclusion criteria and included studies examining SSRI treatment of conditions other than depression, or when we included studies including other antidepressants in addition to SSRIs.

The available data indicate good analytic validity for testing for CYP2D6 and CYP2C19 polymorphisms, but for a limited number of variants, with rare variants being tested infrequently. The data fail to support a clear correlation between CYP polymorphisms and SSRI levels, SSRI efficacy, or tolerability. There are no data regarding whether testing leads to improved outcomes versus not testing in the treatment of depression; whether testing influences medical, personal, or public health decisionmaking; or whether any harms are associated with testing itself or with subsequent management options.

## Future Research

We propose the following conceptual model to guide future research in cytochrome P450 (CYP450) polymorphism testing for depression management. Broadly speaking, the rationale behind CYP450 testing in patients with non-psychotic depression is as follows:

(a) Major depressive disorder is a significant public health problem.
(b) While SSRIs are the first-line treatment for depression, they are associated with a high rate of non-response to treatment, harboring a potential opportunity to improve public health by improving response rates to SSRI treatment.
(c) One factor that makes identification of the optimal SSRI treatment difficult in a specific clinical situation is the CYP polymorphism-associated differences between patients in the rate of metabolism of SSRIs.
(d) CYP450 testing can be used to predict the rate of SSRI metabolism (i.e., to classify patients as PMs, IMs, EMs, or UMs) and, thus, potentially can reduce the amount of trial and error required to select the optimal SSRI in a specific clinical situation.
(e) The better CYP450 testing predicts metabolizer status, the greater the potential of CYP450 testing to improve the process of identifying the optimal SSRI treatment.
(f) However, the more that factors other than CYP450 enzymes affect the metabolism of SSRIs, the less useful CYP450 testing will be.
(g) Because depression is not often acutely life-threatening and SSRIs are rarely associated with life-threatening adverse effects, the main impact of CYP450 testing is likely to be in reducing the time to find the optimal SSRI, and in reducing the likelihood of adverse effects that would have been expected to occur with a suboptimal SSRI that might have been prescribed in the absence of CYP450 testing, thereby potentially reducing disease-management costs.
(h) Finally, the impact of reducing the time to find the optimal SSRI and reducing the likelihood of SSRI-related adverse effects during the initial dosing period is strong enough to be important to patients.

Although some information regarding the above rationale exists, as a whole it is not sufficient to draw firm conclusions about whether this rationale, while intuitively reasonable, is in fact true. Based on this model, two types of studies are proposed. The first type would better elucidate individual points in the rationale. For example, regarding points (e), (f), and (g), the suggested study design would be a properly sized (likely to be large) randomized trial of CYP genotyping-guided treatment versus treatment as usual. The second type of study would encompass multiple steps in the above rationale. Examples include a study that would involve linking a specific genotype to SSRI type and dose, or a “practical clinical trial,” which would involve randomizing clusters (e.g., clinicians, practices, or regions) rather than patients to have genotyping available or not available. This would provide a test of the overarching question, “What difference does having genotyping available make in clinical practice?”

## Conclusions

The short list of papers addressing the key questions clearly demonstrates the lack of sufficient evidence for incorporation of any of these tests into guidelines for clinical practice in depression management. There is a critical need to carry out research to answer the key questions in this report. If shown to be useful, CYP450 genotyping will make the most impact by reducing the trial and error currently inherent in SSRI treatment, thereby decreasing morbidity and improving quality of life in patients with non-psychotic depression.