# Acknowledgments

The authors gratefully acknowledge Jennifer Farmer and Cara O'Brien for assistance with abstract screening; Georgette De Jesus for help with abstract screening and for over-reading of data abstractions; Udita Patel and R. Julian Irvine for assistance with project management; Greg Samsa for reading and commenting on portions of the draft report; Linda Bradley and Glenn Palomaki for assistance with the material on analytic validity, and Gurvaneet Randhawa, AHRQ Task Order Officer, for overall support.