# Discussion

## Context of the Report

The cytochrome P450 (CYP450) enzyme system is prominently involved in the metabolism of each of the currently available selective serotonin reuptake inhibitors (SSRIs). Pharmacokinetic variability resulting from CYP polymorphisms can potentially impact metabolism of SSRIs. It has been proposed that genotyping may provide information to guide selection and dosing of SSRI therapy, leading to improved efficacy and reduced adverse effects.

In this report we identified and evaluated published research and publicly available U.S. Food and Drug Administration (FDA) reports related to the use of CYP genotyping as it relates to the clinical care of individuals with severe non-psychotic depression, focusing on five key questions: (1) the impact of CYP450 genotyping on outcomes in the treatment of depression, and on medical, personal, and public health decisionmaking (overarching question); (2) the analytic validity of tests available for CYP450 genotyping; (3) the impact of CYP genotypes on SSRI metabolism, efficacy, and tolerability (i.e., clinical validity); (4) the impact of CYP testing on management decisions, clinical outcomes (vs. not testing), and decisionmaking (i.e., clinical utility); and (5) the potential harms associated with testing and with subsequent management options.

## Limitations of the Literature Reviewed

We identified moderately good-quality evidence regarding the operating characteristics of clinical tests used for CYP genotyping (Question 2). However, there was a paucity of high-quality clinical studies addressing the other key questions. In particular, there was no evidence for Questions 1, 4a, 4b, 4c, and 5, and evidence for questions 3a, 3b, and 3c was of limited quality.

Methodological issues identified include the following:

- We did not find a single prospective study of CYP450 genotyping and its relationship to clinical outcomes. Most studies were small, poor-quality cross-sectional studies examining prevalence rates of certain genotypes in the sample, or examining the differences between various genotypes and limited clinical outcomes, such as response or adverse effects.
- There were no randomized studies of alternative testing strategies.
- Almost all of the studies identified as reporting on a novel technique for CYP genotyping failed to report key measurements attesting to the robustness, repeatability and quality control of their proposed methods. Rarely was it possible to calculate the positive and negative predictive value of the tests and fully evaluate all aspects relevant to analytical validity. Additionally, often researchers tended to report allele frequencies, rather than genotype frequencies, preventing assessment of specificity and sensitivity in the clinically relevant level. Moreover, the small sample sizes which were utilized in most of these studies severely diminish the reliability of the proposed tests, reflected in large confidence intervals.
- Many reports did not take into account concurrent medications. Medications that inhibit or induce certain CYP enzymes, including SSRIs themselves, can affect metabolism of CYP metabolized drugs. Additionally, we did not identify any studies that examined effects of CYP inhibition/induction together with genetic polymorphisms of CYP enzymes (e.g., is there an additive effect of a CYP2D6 inhibitor medication in a CYP2D6 poor metabolizer [PM] subject such that SSRI levels are higher than the levels without such an inhibitor medication in a CYP2D6 PM subject?)
- Several studies looked at limited genotypes and did not account for the fact that more than one CYP enzyme may be involved in the metabolism of a specific SSRI.
- Many studies examining the clinical outcomes of efficacy or adverse effects did not comment on blinding between treating clinicians and those responsible for interpreting results of genetic testing, or patient blinding.
- Many studies grouped together multiple SSRIs, or SSRIs and other antidepressants. This approach can potentially confound results because of variability in contribution of different CYP enzymes to metabolism of different SSRIs and other antidepressants, and variability in CYP inhibition by different SSRIs.
- We found only one study that examined combined effect of CYP 450 polymorphism and polymorphism in serotonin 2A receptor.^90^ Genetic factors affecting serotonin receptor proteins, membrane transporters, and signal transduction molecules have important pharmacodynamic effects that could affect SSRI efficacy or tolerability.^50,^ ^86,^ ^97^–^108^ Thus, genetic factors other than pharmacokinetic factors can impact SSRI outcomes, and it may be suboptimal to examine effects of CYP polymorphisms on SSRI outcomes in isolation. Multivariable pathway analysis studies are now starting to emerge; any may provide more information regarding proportion of risk for poor outcomes in SSRI treatment of depression that may be attributable to a certain factor, such as CYP polymorphisms. A recent study^109^ searched for genetic predictors of treatment outcome in 1953 patients with non-psychotic major depression treated with the SSRI citalopram. Sixty-eight chosen candidate genes were genotypes, with 768 single-nucleotide polymorphism markers chosen to detect common genetic variation. A significant association was found between treatment outcome and HTR2A gene, which encodes the serotonin 2A receptor. Genes primarily involved in drug metabolism were excluded from this study, but are under study by another group using the same DNA samples. These forthcoming results may be particularly relevant to some of the questions posed in this report.

The rated quality of data did not improve even when we were generous in our inclusion criteria and included studies examining SSRI treatment of conditions other than depression, or when we included other antidepressants in addition to SSRIs.

## Main Findings by Key Question

### Question 1

We did not find any data to address directly the overarching question of whether testing for CYP450 polymorphisms in adults entering SSRI treatment for non-psychotic depression leads to improvement in outcomes, or whether testing results are useful in medical, personal, or public health decisionmaking.

### Question 2

We identified only a few studies of test performance relative to the gold standard of DNA sequencing, applied to a limited number of genetic variants. Many studies appear to be in the realm of preclinical evaluations and are not clearly relevant to the domain of clinical practice.

These data do suggest that the analytic sensitivity and specificity of available tests are generally high. One concern may be that in the evaluation of gene deletions and duplications, assessing the magnitude of the potential problem is limited by the lack of an established gold standard for gene copy number. Another concern is that few CYP450 variants are included in the studies we identified, particularly less common variants.

### Question 3a

In healthy CYP2C19 PMs, there is evidence of slower metabolism of SSRIs after a single dose, whereas in CYP2D6 PMs, the evidence is weaker. In depressed patients who have reached a steady-state concentration of an SSRI, the existing data (a series of heterogeneous studies in small samples) do not support a clear correlation between CYP metabolizer status and SSRI concentrations.

### Question 3b

In depressed patients, the existing data (a series of heterogeneous studies in small samples) do not support a clear correlation between CYP metabolizer status and the efficacy of SSRIs.

### Question 3c

In depressed patients, the existing data (a series of heterogeneous studies in small samples) do not support a clear correlation between CYP metabolizer status and the tolerability of SSRIs.

### Questions 4a, 4b, 4c

We did not identify any studies that addressed whether CYP450 testing influences depression management decisions by patients and providers in ways that could improve or worsen outcomes, or whether testing for CYP450 polymorphisms in adults entering SSRI treatment for non-psychotic depression leads to improved clinical outcomes compared to not testing. Also, there were no data examining whether testing results are useful in medical, personal, or public health decisionmaking.

### Question 5

There were no data on possible direct or indirect harms associated with testing for CYP450 polymorphisms and subsequent management options.

### Model of Treatment for Major Depression

As a complement to the evidence review, we constructed a basic decision model to consider the circumstances under which testing for CYP polymorphisms could improve clinical outcomes, or favorably impact costs. We examined four strategies: (1) use a non-CYP metabolized SSRI without testing; (2) test and choose a non-CYP or CYP metabolized SSRI based on the result; (3) test and choose the dose of a CYP metabolized SSRI based on the result; and (4) use a CYP metabolized SSRI without testing. In no plausible scenario was a testing strategy predicted to improve expected outcomes of treatment at 6 weeks. The efficacy of a test strategy could approach the efficacy of use of a non-CYP metabolized drug, although this required the condition that a high correlation exist between genotype and phenotype (metabolizer status), as well as between phenotype and clinical outcomes. Current evidence does not support the conclusion that such high correlations apply. Moreover, the cost of testing is not offset by treatment savings if treatment duration is less than approximately 9 months.

## Limitations of the Report

This report has two potentially significant limitations:

- First, we included only articles published in English. While this could lead to missing important studies, we suspect the likelihood of such exclusion is low, as we identified only one study that met the inclusion criteria at the abstract screening stage that was excluded at the full-text screening stage because the full report was in another language.^110^
- A second potential limitation is that we only included peer-reviewed publications and data publicly available from the FDA. This inclusion criterion was based on the judgment of the technical expert panel that it would be difficult to assess the quality of information from other sources (for example, data from manufacturer websites may be biased in favor of the product, or data from scientific meetings may be subject to change when published in peer-reviewed journals).