# Results

## Question 1: Overarching Question

Question 1 is: Does testing for cytochrome P450 (CYP450) polymorphisms in adults entering selective serotonin reuptake inhibitor (SSRI) treatment for non-psychotic depression lead to improvement in outcomes, or are testing results useful in medical, personal, or public health decisionmaking?

To address this question, we sought to identify studies in which patients treated with SSRIs were tested for CYP450 genetic polymorphisms, and in which investigators reported on the impact of such testing on outcomes or on medical, personal, or public health decisionmaking. Even after relaxing our inclusion criteria to include all methods used for genotyping and all indications for SSRI treatment, we were unable to identify any studies that directly addressed this question.

## Question 2: Analytic Validity of Tests That Identify Key CYP450 Polymorphisms

Question 2 is: What is the analytic validity of tests that identify key CYP450 polymorphisms?

### Approach

For purposes of this report, we adopted the definition of analytic validity and its components from the Analytic validity, Clinical validity, Clinical utility and associated Ethical, legal and social implications (ACCE) model (Appendix E ^*^), which reads:

* Appendixes cited in this report are provided electronically at www.ahrq.gov/clinic/tp/cyp450tp.htm.

The analytic validity of a genetic test defines its ability to accurately and reliably measure the genotype of interest. This aspect of evaluation focuses on the laboratory component. The four specific elements of analytic validity include analytic sensitivity (or the analytic detection rate), analytic specificity, laboratory quality control, and assay robustness. Analytic sensitivity defines how effectively the test identifies specific mutations that are present in a sample. Analytic specificity defines how effectively the test correctly classifies samples that do not have specific mutations (although the term “mutation” is used here, the terms “polymorphism” or “variant” may be more appropriate for certain situations). Quality control assesses the procedures for ensuring that results fall within specified limits. Robustness measures how resistant the assay is to changes in pre-analytic and analytic variables.

It is notable that the definitions of sensitivity and specificity above are most directly applicable to tests with dichotomous results (mutation present or absent). Because there are multiple CYP450 polymorphisms that can be assessed, and each study may provide information on only a subset of polymorphisms, we defined analytic sensitivity operationally as the proportion of known genotype challenge samples that are correctly identified by the test under evaluation. Similarly, analytic specificity was defined operationally as the proportion of known wild-type challenge samples that are correctly identified by the test under evaluation.

Our assessment of analytic validity focuses on tests that are actually used, or are likely to be used, in clinical settings. The gold standard method for CYP450 genotyping is unequivocally the bidirectional sequencing of the specific genetic region of the gene of interest. However, many reference methods exist due to the complexity and high costs involved with sequencing of large populations. To date, there is only one technology approved by the U.S. Food and Drug Administration (FDA) specifically for CYP450 genotype testing (the Roche AmpliChip^®^), and one technology approved for genetic testing of a different gene target (Invader Assay for UGT1A1 genotyping) which has been employed in one of the studies for CYP2D6 genotyping.^53^ Other laboratories currently performing CYP450 tests in clinical settings generally employ traditional methods, including polymerase chain reaction and restriction fragment length polymorphism (PCR-RFLP) or allele-specific polymerase chain reaction (AS-PCR, also referred to as allele-specific amplification, or ASA).

In the absence of a substantial number of studies comparing the test under evaluation to the gold standard (bidirectional DNA sequencing), we decided to include studies that used a traditionally accepted methods comparison, typically PCR-RFLP or AS-PCR, acknowledging that a methods comparison would be a lower level of evidence regarding analytic sensitivity and specificity than a gold standard comparison. Consequently, we refer to the comparator tests as a “reference standard.” It should be noted that in most cases even DNA sequencing for the purpose of assay validation may not have been done bidirectionally (not reported), but is referred to as a gold standard nonetheless.

Few studies reported the ethnic makeup of the tested sample populations, and even when details were provided there was no standard format followed, or description provided of the source of ethnicity data (e.g., based on self-reported or medical or other documentation). We therefore summarize all studies by the common denominator of general ethnic group (e.g., Caucasian).

Some studies provided information about test performance in assessing individual alleles rather than genotypes. Although these are less clinically relevant, they are included to complement the information about genotypes.

Several studies addressed the issue of gene duplication and deletion. While these are clinically important, there is a lack of an accepted gold standard; in this case, comparisons were based on any reported comparator. Current methods commonly used for assessment of CYP2D6 gene copy number are based on two different approaches, both of which are sensitive to the location of primers used in assay design and are prone to produce erroneous results in rare cases of rearrangement variants or occurrence of mutations in the positions targeted by these primers. The first approach compares CYP2D6 copy number to a gene that is known to have no variation in gene copy number, computing the ratio between them. Most of the analytic validity studies employing these methods do not discriminate further to see which allele is duplicated (hence these are referred to in Table 7, below, as “duplication” and “deletion”). Alternatively, others amplify a duplication-specific fragment, but may miss duplications, depending on the particular primers utilized. These traditionally used fragments also allow limited or no genotyping, since they carry little or no coding regions (intergenic region amplified).

Table 7 Analytic sensitivity and specificity of tests for CYP2D6 polymorphisms - by gene copy number*

Study | | Roche Molecular Systems, Inc., 2004^40^ | Schaeffeler et al., 2003^57^ | Neville et al., 2002^53^ | Soderback et al., 2005^58^ | Stamer et al., 2002^59^ | Genotype-specific analytic sensitivity | 95% CI | Test for homogeneity
Test evaluated | | AmpliChip^®^ | RT-PCR | Long-range PCR and ASA | Pyro-sequencing | RT-PCR
Reference standard | | Sequencing and ASA^#^ | Long range PCR | Long range PCR | Long range PCR | Long range PCR and ASA
Analytic sensitivity | Del/Del | 2/2 | 1/1 | 0/0 | 0/0 | 1/1 | 100% | 42.5 – 100 | 0.97
| Del/SC | 41/41 | 13/13 | 16/16 | 24/24 | 11/11 | 100% | 97.2 – 100 | 0.99
| Dup/Del | 3/3 | 5/5 | 0/0 | 0/0 | NR | 100% | 67.1 – 100 | 0.87
| Dup/SC | 31/33 | 0/3^‡^ | 11/11 | 13/13 | NR | 91.67% | 82.4 – 97.7 | 0.06
Analytic specificity | SC/SC | 425/426 | 43/43 | NR | 3/3 | NR | 99.79% | 99.0 – 100 | 0.46

Notes to Table 7:

* Methods combining both gene deletion assays (*5 variant) and identification of other variants are included in both Tables 6 and 7, as evaluation of analytic validity addresses different parameters of the test in each table.

‡ Real-time polymerase chain reaction (RT-PCR) detects gene copy number and uses an algorithm for genotype assignment based on the single nucleotide polymorphism-genotype analysis. When 2 alleles are detected, the most likely genotype is wild type (2 active alleles), with a less likely result of a combination between duplication and deletion.

® Results of genotype calls for the AmpliChip method comparison are pooled for all method validation tests performed, as the report does not specify genotype calls by each method specifically.

Abbreviations: ASA = allele-specific amplification; CI = confidence interval; Del = deletion (*5 allele); Dup = duplication (more than a single gene copy); NR = not reported; PCR = real-time polymerase chain reaction; RT-PCR = real-time polymerase chain reaction; SC = single gene copy

On the advice of the technical expert panel, we reviewed studies for polymorphisms in all CYP450 enzymes. Results for those most relevant to SSRI metabolism (CYP2D6, 2C19, and 2C9) are presented in this section; results for the remaining enzymes are provided in Evidence Table 1 (Appendix D ^*^).

### Results

Results for analytic sensitivity and specificity for genotype polymorphisms are presented below by CYP450 enzyme. All calculations were performed using FastPro version 1.8 (Academic Press, 1992). Summaries of evidence regarding sensitivity and specificity for individual alleles, gene deletion and duplication, laboratory quality control, and robustness issues are also provided. Detailed results relating to these latter issues are included in Evidence Table 1 (Appendix D ^*^).

CYP2D6. We identified nine reports that compared clinical methods for genotyping CYP2D6 enzyme polymorphisms to a reference standard (Tables 6 and 7). Of these, eight were published studies^53^–^60^ and one was reported on the FDA website.^40^ Only two studies^40,^ ^55^ provided a comparison to the gold standard, DNA sequencing. One study^60^ provided results in allele counts only and thus is not considered further here (for details see Evidence Table 1, Appendix D ^*^). Five of the studies tested different 2D6 variants (Table 6), while five reported results on gene copy number (Table 7); two studies^40,^ ^59^ reported both.

Table 6 Analytic sensitivity and specificity of tests for CYP2D6 polymorphisms - by variant*

Study | | Roche Molecular Systems, Inc., 2004^40^ | Hersberger et al., 2000^55^ | Eriksson et al., 2002^54^ | Muller et al., 2003^56^ | Stamer et al., 2002^59^ | Genotype-specific analytic sensitivity | 95% CI | Test for homogeneity
Test evaluated | | AmpliChip^®^ | ASA | Pyro-sequencing | RT-PCR | RT-PCR
Reference standard^†^ | | Sequencing, ASA and PCR-RFLP^#^ | Sequencing | PCR-RFLP | PCR-RFLP | ASA
Analytic sensitivity | *2/*1 | 31/31 | NR | NR | NR | NR | 100% | 90.6 – 100 | NA
| *2/*2 | 16/16 | NR | NR | NR | NR | 100% | 82.43 – 100 | NA
| *2/*3 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *2/*4 | 20/20 | NR | NR | NR | NR | 100% | 85.76 – 100 | NA
| *2/*5 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*6 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *2/*7 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*8 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*9 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *2/*10 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *2/*11 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*19 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*20 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *2/*35 | 8/8 | NR | NR | NR | NR | 100% | 67.07 – 100 | NA
| *2/*41 | 5/5 | NR | NR | NR | NR | 100% | 51.39 – 100 | NA
| *3/*1 | 2/2 | 3/3 | 1/1 | NR | NR | 100% | 58 – 100 | 0.95
| *3/*3 | 2/2 | NR | 1/1 | NR | NR | 100% | 30.17 – 100 | 0.84
| *3/*4 | 3/3 | NR | 3/3 | NR | NR | 100% | 58 – 100 | 1
| *3/*5 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *3/*35 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *3/*41 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *4/*1 | 31/31 | 4/4 | 29/29 | NR | NR | 100% | 95.39 – 100 | 0.77
| *4/*4 | 24/24 | 2/2 | 5/5 | NR | NR | 100% | 90.64 – 100 | 0.74
| *4/*5 | 3/3 | NR | NR | NR | NR | 100% | 30.17 – 100 | NA
| *4/*6 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *4/*7 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*8 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*9 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *4/*11 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*15 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *4/*19 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*20 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*35 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *4/*41 | 13/13 | NR | NR | NR | NR | 100% | 78.69 – 100 | NA
| *5/*1 | 15/15 | NR | NR | NR | 11/11 | 100% | 88.92 – 100 | 0.92
| *5/*5 | 2/2 | NR | NR | NR | 1/1 | 100% | 30.17 – 100 | 0.84
| *5/*6 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *5/*9 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *5/*10 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *5/*17 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *5/*29 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *5/*35 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *5/*41 | 7/7 | NR | NR | NR | NR | 100% | 63.07 – 100 | NA
| *6/*1 | 3/3 | 3/3 | NR | NR | NR | 100% | 58 – 100 | 1
| *6/*41 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *7/*1 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *7/*7 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *7/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *8/*1 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *8/*8 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *8/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *9/*1 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *9/*17 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *9/*41 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *10/*1 | 16/16 | NR | NR | NR | NR | 100% | 82.43 – 100 | NA
| *10/*10 | 16/17 | NR | NR | NR | NR | 94.12% | 74.31 – 100 | NA
| *10/*17 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *10/*35 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *10/*36 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *10/*40 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *10/*41 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *11/*1 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *11/*11 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *11/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *17/*1 | 13/13 | NR | NR | NR | NR | 100% | 78.69 – 100 | NA
| *17/*17 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *17/*29 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *17/*41 | 3/3 | NR | NR | NR | NR | 100% | 30.17 – 100 | NA
| *19/*1 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *19/*19 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *19/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *20/*1 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *20/*20 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *20/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *29/*1 | 2/2 | NR | NR | NR | NR | 100% | 13.57 – 100 | NA
| *29/*29 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *29/*36 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *29/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *35/*1 | 13/13 | NR | NR | 14/14 | NR | 100% | 89.31 – 100 | 0.98
| *35/*35 | 1/1 | NR | NR | 3/3 | NR | 100% | 42.49 – 100 | 0.75
| *35/*41 | 4/4 | NR | NR | NR | NR | 100% | 42.49 – 100 | NA
| *40/*1 | 1/1 | NR | NR | NR | NR | 100% | 0.25 – 100 | NA
| *41/*1 | 14/14 | NR | NR | 14/14 | NR | 100% | 89.68 – 100 | 1
| *41/*41 | 9/9 | NR | NR | 3/3 | NR | 100% | 77.07 – 100 | 0.73
Analytic specificity | *1/*1 | 31/31 | 8/8 | 24/24 | 101/101 | NR | 100% | 98.18 – 100 | 0.89

Notes to Table 6:

* Methods combining both gene deletion assays (*5 variant) and identification of other variants are included in both Tables 6 and 7, as evaluation of analytic validity addresses different parameters of the test in each table.

† To avoid double counting, for studies reporting both sequencing and PCR-RFLP as reference standards,^40,^ ^55^ only sequencing data are included here. Full details of genotype and allele results are provided in Evidence Table 1 (Appendix D ^*^ ).

# Results of genotype calls for the AmpliChip® method comparison are pooled for all method validation tests performed, as the report does not specify genotype calls by each method specifically.

Abbreviations: ASA = allele-specific amplification; CI = confidence interval; NA = not applicable; NR = not reported; PCR-RFLP = polymerase chain reaction and restriction fragment length polymorphism; RT-PCR = real-time polymerase chain reaction

In all studies analytic sensitivity and specificity for each tested genotype ranged from 94.12 to 100 percent, with the exception of Schaeffeler et al.,^57^ which reported sensitivity of 91.67 percent to detect the duplication/(single copy) genotype and specificity of 99.79 percent. However, only 26 of approximately 100 known CYP2D6 polymorphisms (www.cypalleles.ki.se) were evaluated in the included studies, with most studies focusing on only a handful of these variants.

Analytic sensitivity and specificity based on combined allele counts (as opposed to genotype calls presented in Table 6) ranged from 98 to 100 percent in all studies, again with the exception of Schaeffeler et al.,^57^ which reported sensitivity of 73.1 percent and specificity of 98 percent. However, correct allele counts do not necessarily reflect correct genotype calls (which are assumed to predict treatment outcomes) and are therefore less relevant in the clinical context (details on allele counts, sensitivity, and specificity are presented in Evidence Table 1, Appendix D ^*^).

CYP2D6 gene copy number methods exhibit relatively high sensitivity and specificity, although two of the four studies reporting results on duplication variants reported failures, resulting in sensitivity of 91.67 percent to identify duplication/(single copy) genotypes, and a homogeneity p-value of 0.06. It should be noted that traditional assays designed to identify the deletion variant *5 fail to depict some rearrangement-deletion alleles (the most common of which in Caucasians are *13 and *16 [0.5 to 1 percent], not tested in any of the studies above). These are non-functional alleles and result in the same metabolic phenotype as *5 (i.e., poor metabolizer [PM]).

Quality control procedures include the integration of negative and positive controls into the genotyping process in most studies^40,^ ^53,^ ^57^–^59^ to ensure that results fall within the specified assay limits. Robustness was not measured and reported in all studies. The effect of pre-analytic variables (such as blood sample collection and DNA extraction method) was reported only by Chou et al.,^60^ but they did not perform a comprehensive comparison between the two DNA extraction methods employed. The effect of analytic variables was measured in three of the studies, each reporting a different measurement: Schaeffeler et al.^57^ reported inter- and intra-assay variability in a subset of the tested samples separately; Soderback et al.^58^ reported the reproducibility of linear regression coefficients; and Roche investigators^40^ reported reproducibility scores by combining the effects of sites, replicates, dates, and reagent lots. All three studies reported high rates of robustness, but these were not comparable and could not be summarized together (details are presented in Evidence Table 1, Appendix D ^*^).

CYP2C19. We identified three reports that compared clinical methods for genotyping CYP2C19 enzyme polymorphisms to a reference standard (Table 8). Of these, two were published studies^54,^ ^61^ and one was reported on the FDA website.^41^ Only one study^41^ provided a comparison to the gold standard, DNA sequencing.

Table 8 Analytic sensitivity and specificity of tests for CYP2C19 polymorphisms

Study | | Roche Molecular Systems, Inc., 2005^41^ | Eriksson et al., 2002^54^ | Mizugaki et al., 2003^61^ | Genotype-specific analytic sensitivity | 95% CI | Test for homogeneity
Test evaluated | | AmpliChip^®^ | Pyro-sequencing | ASA and TaqMan
Reference standard | | Sequencing | PCR-RFLP | PCR-RFLP
Analytic sensitivity | *2/*1 | 101/101 | 24/24 | 45/45 | 100% | 98.25 – 100 | 0.9
| *2/*2 | 14/15 | 5/5 | 8/8 | 96.43% | 83.96 – 100 | 0.78
| *2/*3 | 6/6 | NR | 9/9 | 100% | 81.33 – 100 | 0.9
| *3/*1 | 6/6 | NR | 29/29 | 100% | 91.68 – 100 | 0.62
| *3/*3 | 1/1 | NR | 2/2 | 100% | 30.17 – 100 | 0.84
| *4/*1 | NR | 1/1 | NR | 100% | 0.25 – 100 | NA
Analytic specificity | *1/*1 | 270/270 | 108/108 | 51/51 | 100% | 99.3 – 100 | 0.87

Abbreviations: ASA = allele-specific amplification; CI = confidence interval; NA = not applicable; NR = not reported; PCR-RFLP = polymerase chain reaction and restriction fragment length polymorphism

All three studies reported a high sensitivity and specificity (96.43 to 100 percent). However, each study focused on detection of two out of the three common CYP2C19 alleles (*2, *3, and *4). Similar results were obtained when performing calculations based on allele calls (Evidence Table 1, Appendix D ^*^). Quality control procedures employed by the above studies included the incorporation of polymorphism surrounding sequence in assay design as an internal control,^54^ and testing positive and negative control samples routinely.^41^ Only Roche Molecular Systems, Inc.,^41^ reported the robustness of their technology for CYP2C19 allele detection by means of reproducibility of correct genotype calls (99.6 percent; for details see Evidence Table 1, Appendix D ^*^).

CYP2C9. We identified one report that compared clinical methods for genotyping CYP2C9 enzyme polymorphisms to a reference standard.^54^ This study did not use the gold standard, DNA sequencing. Investigators reported lack of detection of homozygotes for the *2 and/or the *3 alleles. They also stated that compound heterozygotes (*2/*3 genotype) were identified, but they provided no genotype counts, preventing calculation of genotype analytic sensitivity and specificity.

Calculation of analytic sensitivity based on allele counts was 100 percent. Due to an unreported number of compound heterozygotes, it is impossible to calculate confidence intervals of assay specificity, but it is implied that mean specificity is 100 percent.

No measures of robustness were reported. Quality control featured interrogation of the surrounding sequence, along with the variable positions tested and providing internal controls.

Other CYPs. We identified two studies that compared clinical methods for genotyping CYP2C8 enzyme polymorphisms to a reference standard (Table 9), and one that did the same for CYP1A1 polymorphisms (Table 10). Only one study (of CYP2C8) provided a comparison to the gold standard, DNA sequencing.^62^

Table 9 Analytic sensitivity and specificity of tests for CYP2C8 polymorphisms

Study | | Muthiah et al., 2004^62^ | Weise et al., 2004^63^ | Genotype-specific analytic sensitivity | 95% CI | Test for homogeneity
Test evaluated | | Multiplex PCR | RT-PCR
Reference standard | | Sequencing | PCR-RFLP
Analytic sensitivity | *2/*1 | 2/2 | 2/2 | 100% | 42.49 – 100 | 1
| *3/*1 | 3/3 | 16/16 | 100% | 85.05 – 100 | 0.6
| *3/*4 | NR | 1/1 | 100% | 0.25 – 100 | NA
| *4/*1 | NR | 8/8 | 100% | 67.07 – 100 | NA
Analytic specificity | *1/*1 | 52/52 | 95/95 | 100% | 97.98 – 100 | 0.85

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; PCR = polymerase chain reaction; PCR-RFLP = polymerase chain reaction and restriction fragment length polymorphism; RT-PCR = real-time polymerase chain reaction

Table 10 Analytic sensitivity and specificity of tests for CYP1A1 polymorphisms

Study | | Wu et al., 2002^64^ | Genotype-specific analytic sensitivity | 95% CI
Test evaluated | | Mismatch hybridization
Reference standard | | PCR-RFLP
Analytic sensitivity | m1/*1 | 8/8 | 100% | 67.07 – 100
| m1/m1 | 20/20 | 100% | 85.76 – 100
Analytic specificity | *1/*1 | 22/22 | 100% | 86.94 – 100
Analytic sensitivity | m2/*1 | 5/5 | 100% | 51.39 – 100
| m2/m2 | 21/21 | 100% | 86.4 – 100
Analytic specificity | *1/*1 | 24/24 | 100% | 86.4 – 100

Abbreviations: CI = confidence interval; PCR-RFLP = polymerase chain reaction and restriction fragment length polymorphism

All studies reporting assay performance for the detection of CYP2C8 and CYP1A1 exhibit 100 percent analytic sensitivity and specificity. Calculations based on allele calls reflect the same findings. Quality control procedures employed include the incorporation of positive and negative controls into the genotyping process.^62^ Robustness was assessed only by Wu et al.,^64^ by means of inter- and intra-assay variability. The intra-assay coefficients of variance were reported to be lower than 11.2 percent for both CYP1A1 assays, and the inter-assay coefficients of variance were lower than 14.3 percent. Weise et al.^63^ implied 100 percent inter-assay reproducibility of results obtained by four different investigators.

### Discussion

Based on emerging standards, analytic validity of genetic tests includes not only the ability of the test to accurately identify challenge genotypes (as assessed by a gold standard test), but also quality control and robustness. We identified only a few studies of test performance relative to the gold standard of DNA sequencing (bidirectionally or unidirectionally), applied to a limited number of samples (as reflected by the wide confidence intervals calculated for analytic sensitivity and specificity), and covering but a small set of possible genetic variants. Many studies appear to be in the realm of preclinical evaluations and are not clearly relevant to the domain of clinical practice.

These data do suggest that the analytic sensitivity and specificity of available tests are generally high. One concern may be that in the evaluation of gene deletions and duplications, assessing the magnitude of the potential problem is limited by the lack of an established gold standard for gene copy number. Another concern is that few CYP450 variants are included in the studies we identified, which focused particularly on the more common variants in Caucasians and African-Americans. However, variants that are rare in these populations may be more frequent, and thus more clinically relevant, in other populations. In the same context, it should be noted that most studies focus on developing reliable methods for the genotyping of CYP2D6 variants known to be non-functional (PM). Of these, the most common in Caucasians and African-Americans are *3, *4, *5, and *6, and the majority of studies target their assays at capturing these variants. Even the AmpliChip^®^, which targets the largest set of CYP2D6 variants (n = 26), fails to capture a large set of rare variants leading to deficient enzyme activity.

Many analytic validity studies, particularly those published less recently, tend to report results by stating allele counts and frequencies, without direct comparison to a reference standard. While this format allows comparison to published allele frequencies in populations similar to the ones employed in their studies, it is not helpful in estimating genotype-specific performance. For completeness, however, data summarizing allele frequencies are provided in Evidence Table 1 (Appendix D ^*^).

### Conclusions

Although these results suggest that analytic validity for detecting some of the CYP450 genotypes more frequently encountered in the Caucasian population is good, overall the data are limited, with relatively small numbers of samples and a relatively narrow range of polymorphisms tested. In addition to studies addressing these limitations, research should include closer examination of the issue of deletions and duplications. Furthermore, practical concerns of quality control and robustness deserve greater investigation based on emerging standards for such studies.

## Question 3a: CYP450 Genotypes and Metabolism of SSRIs

Question 3a is: How well do particular CYP450 genotypes predict metabolism of particular SSRIs? Do factors such as race/ethnicity, diet, or other medications affect this association?

### Approach

There is definitive literature supporting the association between certain CYP450 genotypes and their predicted phenotypes (i.e., how they would metabolize probe drugs specific for that CYP enzyme). Our question sought to address how well a certain genotype (or its corresponding predicted phenotype) predict metabolism of particular SSRIs. For example, does a CYP2D6 *5*5 or predicted poor metabolizer (PM) of the probe drug dextromethorphan also metabolize fluoxetine poorly? To address this question, we sought to identify all studies in which patients on SSRIs were tested for CYP450 genetic polymorphisms. Studies were included irrespective of the method used for genotyping. Because of the overall paucity of data, we included studies that had diagnoses other than non-psychotic depression as an indication for SSRI treatment, as clinical outcomes in such scenarios may be indicative of genotype effects. We also included studies in which only a subgroup of patients was treated with SSRIs, while others were treated with other antidepressants, including tricyclics.

### Results

Note: Here, as throughout Chapter 3, the terms “poor metabolizer (PM),”“extensive metabolizer (EM),” etc., refer to general phenotypes (for a probe drug) as predicted by genotyping.

We identified 16 studies that met the inclusion criteria for this question (see Evidence Table 2, Appendix D ^*^). Five studies examined SSRI metabolism in healthy adults,^43,^ ^65^–^68^ while the other 11 looked at SSRI metabolism in patients who had achieved a steady state after multiple doses.^69^–^79^

The first group of five studies examined the effect of different genotypes of CYP2C19 and CYP2D6 on SSRI metabolism in healthy volunteers. Results are summarized in Table 11.

Table 11 Analytic sensitivity and specificity of tests for CYP1A1 polymorphisms

Study | Subjects (n, ethnicity) | SSRI | Genotypes | Results
Liu et al., 2001^65^ | 14 Chinese | Fluoxetine | 2C19 *1, *2, *3 | Increased AUC, t_½_, and C_max_, decreased oral clearance in PMs vs. EMs
Wang et al., 2001^43^ | 12 Chinese | Sertraline | 2C19 *1, *2, *3 | Increased AUC, t_½_, and C_max_, decreased oral clearance in PMs vs. EMs
Yu et al., 2003^67^ | 13 Chinese | Citalopram | 2C19 *1, *2, *3 | Increased AUC, t_½_, and C_max_, decreased oral clearance in PMs vs. EMs
Yoon et al., 2000^68^ | 16 Koreans | Paroxetine | CYP2D6 *1, *2, *10B | Heterozygotes/homozygotes for *10B showed lower volume of distribution, oral clearance, and higher AUC vs. homozygous for wild type. No difference in C_max_, t_½_, or renal clearance between groups
Ozdemir et al., 1999^66^ | 17 Caucasians | Paroxetine | 2D6*1, *3, *4, *5 | Heterozygous EMs had twofold higher median steady-state concentration than homozygous EMs, but difference not statistically significant

Abbreviations: AUC = area under the curve; C_max_ = maximum plasma concentration; EMs = extensive metabolizers; PMs = poor metabolizers; t_½_ = terminal elimination half-life

All these studies used standard measures such as area under the curve (AUC, which is an assessment of bioavailability of the drug), half-life (time taken to eliminate half the total ingested quantity of the drug from the body), and oral clearance (pertains to distribution and elimination of drug) as measures of rate of metabolism. Three of the five studies^43,^ ^65,^ ^67^ included young, healthy, male, non-smoking, Chinese subjects who were free of medications and alcohol for at least 2 weeks prior to the study. These studies looked at the effect of CYP2C19 genotypes and predicted phenotypes (EM vs. PM) on the metabolism of three different SSRIs, namely, fluoxetine, sertraline, and citalopram. All three studies found significantly higher AUC, longer half-life, and reduced oral clearance of the parent drug, and significantly lower AUC and lower maximum plasma concentration (C_max_) of the metabolite of each drug, in PMs as compared to EMs. The fluoxetine and citalopram studies also found a gene dose effect such that heterozygous EMs showed values between homozygous EMs and PMs.

Of the remaining two studies, the first^68^ was carried out in 16 healthy, young, Korean subjects and examined the effect of the CYP2D6*10 allele (predictive of poor metabolism) on paroxetine metabolism. Investigators found that homozygotes and heterozygotes for *10 alleles showed significantly greater volume of distribution, greater AUC, and lower oral clearance of paroxetine than wild type homozygotes.

Thus, all studies in healthy adults using a single dose of an SSRI found that PMs, as predicted by genotyping, metabolized the SSRI more slowly than EMs, irrespective of particular SSRI.

The other study^66^ was a multiple-dose study that looked at paroxetine pharmacokinetics in 17 healthy, young, non-smoking Caucasian subjects who received paroxetine 20 mg/day for at least 5 days (range, 5 to 15 days). It found that heterozygous EMs had twofold higher median paroxetine steady-state concentrations than homozygous wild type EMs (n = 10); the difference was not statistically significant (p = 0.2).

The 11 studies conducted in clinical populations (with sample sizes ranging from 11 to 146) examined the effects of genotypes of 2D6, 2C9, and 2C19 on the pharmacokinetics of various SSRIs. Results are summarized by SSRI in Table 12 for all studies of individual SSRIs.

Table 12 CYP450 predicted phenotypes and metabolism of various SSRIs in clinical populations

SSRI | CYP enzyme | Drug concentration findings
Paroxetine^69,^,^70,^,^74,^,^76,^,^77,79^ n = 14 to 124 | 2D6 | PM mother had highest concentration; her infant had undetectable level; a UM infant had undetectable level^69^
| | PM > EM^70^
| | (PM + IM) = (EM + UM)^74^
| | PM > EM only at 10-mg dose, not at higher doses^76^
| | Trough concentration in lower half of reference range for PM (n = 1) and EM^77^
| | IM > PM and EM in 30 mg/d dose group only^79^
SSRI | CYP enzyme | Drug concentration findings
Fluoxetine^70,^,^71,^,^73,^,^78,^ n = 11 to 78 | 2D6 | PM > EM^70^
| | PM > EM (S isomer only)^71^
| | PM = EM (active moiety)^73^
| | PM = EM (active moiety)^78^
| 2C19 | PM = EM (active moiety)^78^
| 2C9 | Heterozygous EM > homozygous EM (active moiety)^73^
| | Heterozygous EM > homozygous EM (active moeity)^78^
| | Heterozygous EM > homozygous EM (R isomer only)^78^
Fluvoxamine^75^ n = 46 | 2D6 | PM = EM^75^
Citalopram^69^ n = 14 | 2C19 | PM mother had highest citalopram concentration, five *1*2 infants had higher concentration than five *1*1 infants (3 vs. 0.8 nmol/L). 3 of 4 infants with undetectable level were *1*169

Note to Table 12: “Active moiety” = fluoxetine + norfluoxetine (active metabolite)

Abbreviations: EM = extensive metabolizer; IM = intermediate metabolizer; PM = poor metabolizer; UM = ultra-rapid metabolizer

Table 13 reports confidence intervals for differences in mean SSRI levels between extensive metabolizers and comparison groups for those studies reporting the necessary data.

Table 13 Confidence intervals for differences in mean SSRI levels between extensive metabolizers (EMs) and comparison groups

SSRI/CYP enzyme | Study | Mean drug concentration, EM group | Mean drug concentration, comparator group (PM, heterozygous EM, etc.) | P-value | Confidence interval^80^ for difference in mean drug concentration | Dose | Comments
Paroxetine/ 2D6 | Charlier et al., 2003^70^ | 20.97 ± 21.17 microg/L (n = 30) | 72.50 ± 29.65 microg/L (n = 6) | 0.00001 | 31.40 to 71.66 | 20 mg/d | -
| Sawamura et al., 2004^76^ | 2.99 ± 3.52 ng/mL (n = 16) | 7.30 ± 6.11 ng/ mL (*1*10 or *10*10) (n = 35) | 0.019 | 1.04 to 7.58 | 10 mg/d | No difference at higher doses, data not provided
| Murphy et al., 2003^74^ | 71.65 ± 52.55 ng/mL (n = 105) (EM + UM) | 99.51 ± 37.35 ng/mL (IM + PM) (n = 15) | NR | -0.15 to 55.87 | Mean 30.21 (EM), 26.67 (PM) | (EM + UM), (IM +PM) groups combined to increase power
| Ueda et al., 2006^79^ | 150.9 ± 20.6 ng/mL/mg/kg (n = 17) | 76.7 ± 6.1 ng/mL/mg/kg (n = 12) | NR | -86.45 to 61.95 | 30 mg/d | IM level greater than EM or PM, no difference at other doses
Fluoxetine/ 2D6 | Charlier et al., 2003^70^ | 49.4 ± 40.7 microg/L (n = 10) | 178.5 ± 68.6 microg/L (n = 2) | 0.004 | 60.83 to 197.37 | 20 mg/d | Reported fluoxetine only
| Eap et al., 2001^71^ | 55 ± 30 ng/mL (n = 6) | 104 ± 8 ng/mL (n = 3) | NR | 12.82 to 85.18 | 20 mg/d | Reported fluoxetine only
| LLerena et al., 2004^73^ | 13.0 ± 7.6 nmol/L/mg (n = 41) | 16.7 nmol/L/mg (n = 1) | NR | -11.61 to 19.01 | Dose-corrected | Reported fluoxetine only. “No significant correlation found between plasma concentration of active moiety and number of active genes”
Fluoxetine/ 2C9 | LLerena et al., 2004^73^ | 25.1± 10.1 nmol/L/mg (n = 19) | 35.5 ± 18.5 nmol/L/mg (*1*2) (n = 11) | < 0.05 | 0.07 to 20.73 | Dose-corrected | Active moiety (all subjects were 2D6 EM)
| | | 38.6 ± 22.1 nmol/L/mg (*1*3) (n = 8) | < 0.01 | 1.34 to 25.66
Fluvoxamine/ 2D6 | Ohara et al., 2003^75^ | 312.7± 195.3 ng/mL/mg/kg (n = 13) | 321± 422.1 ng/mL/mg/kg n = 15) | 0.984 | -245.79 to 262.39 | Dose-corrected | PM defined as 2D6 *10*10; EM defined as no *10 (any allele which was not *3, *4, *5 or *10 was defined as wild-type)

Abbreviations: EM = extensive metabolizer; IM = intermediate metabolizer; NR = not reported; PM = poor metabolizer; UM = ultra-rapid metabolizer

All 11 studies examined some or all genotypes of CYP2D6, while CYP2C9 and 2C19 were considered in three studies each. The studies were heterogeneous with respect to patient population, some with psychiatric outpatients, some with major depression defined either by Diagnostic and Statistical Manual for Mental Disorders, 4^th^ edition (DSM-IV) criteria or using other definitions; one with patients in treatment with an antipsychotic (risperidone) to which fluoxetine was added;^71^ one with breast-feeding mothers on antidepressants and their infants;^69^ and one with patients who developed hyponatremia while on antidepressants.^77^ All studies were cross-sectional in design. The studies were carried out in different ethnic groups. One study^72^ not included in Table 12 or 13 studied several antidepressants, including SSRIs and tricyclics, and the results could not be broken down by particular antidepressant type for different CYP polymorphisms.

The studies for individual SSRIs are summarized in Table 12. Paroxetine was the most studied SSRI, with six studies examining the effect of CYP2D6 polymorphism on paroxetine steady state plasma concentration. Fluoxetine was studied in four studies with respect to CYP2D6, 2C9, and 2C19 polymorphisms. Fluvoxamine and CYP2D6 polymorphism were studied in one study, and citalopram was studied with respect to CYP2C19 polymorphism in one study.

Data for calculating confidence intervals for differences in mean SSRI levels between EM and comparator groups (PM, heterozygous EM, etc.) were available for four studies of paroxetine, four of fluoxetine, and one of fluvoxamine (Table 13). The results for both paroxetine and fluoxetine were mixed, with some studies showing significant differences, and others not showing differences. The studies typically had small numbers of subjects, and hence the confidence intervals for differences in means were very wide, as shown in Table 13. For fluoxetine, two studies^73,^ ^78^ showed a significant difference in active moiety between CYP2C9 EMs and PMs, but failed to show differences in active moiety levels between EMs and PMs of CYP2D6 (data for Scordo et al., 2005^78^ are not shown in Table 13, as results were reported as median and range rather than means ± standard deviation).

### Discussion

The 16 included studies provide mixed evidence regarding the first part of Question 3a (on possible correspondences between CYP450 genotypes and metabolism of particular SSRIs). In multiple dose studies of SSRIs, inconsistent results were obtained for individual SSRIs, and also for individual CYP enzymes.

Methodological issues in studies addressing this question include:

(1) Single-dose studies in healthy volunteers:^43,^ ^65,^ ^67,^ ^68^ Clinical situations may be very different from single-dose studies, because of the possible effects of the medication on CYP enzymes over time. Data from single-dose experiments cannot be extrapolated to long-term drug therapy, as saturation pharmacokinetics, irreversible enzyme blockade, or enzyme up- or down-regulation might change the outcome with multiple dosing.^3,^ ^81,^ ^82^
(2) Small sample sizes: All the studies had very small samples of the PM or ultra-rapid metabolizer (UM) groups, and thus may not have been powered adequately to detect significant differences, as shown by wide confidence intervals.
(3) Heterogeneity: The studies were quite variable in terms of the population of interest, specific SSRIs considered, and specific CYP450 polymorphisms.
(4) Not accounting for multiple CYP enzymes that may be involved in metabolism of a certain SSRI: Only one study^73^ took into account the possibility that more than one CYP enzyme might be involved in the metabolism of a certain SSRI and therefore controlled for polymorphisms in another enzyme.
(5) Not accounting for active metabolites of certain SSRIs like fluoxetine: Two studies measured active moiety rather than parent drug alone,^73,^ ^78^ whereas two others did not.^70,^ ^71^
(6) Most studies for accounted for co-medications that may be inhibitors or substrates for the enzyme being studied; one did not.^69^ Benzodiazepines were typically allowed in these psychiatric cohorts, as these drugs are metabolized mainly by CYP3A4 and have no influence on the enzymes studied.
(7) Diet was not taken into account in any study.
(8) One study^72^ combined SSRIs and other antidepressants and examined effects of polymorphisms of various CYP enzymes. Combining various SSRIs, and moreover SSRIs with other antidepressant medications, may have confounded results because of variability in the contribution of different CYP enzymes to metabolism of different SSRIs and other antidepressants, and variability in CYP inhibition by different SSRIs.

The quality assessment criteria we applied to individual studies in this report^52^ (Appendix E ^*^) yielded a range of scores between “3b” and “4.” For the suggestion that the genotypes affect metabolism of SSRIs, the grade of recommendation based on available data would be “C.”

### Conclusions

In depressed patients treated with SSRIs, the existing data (a series of heterogeneous studies in small samples) do not support a clear correlation between CYP metabolizer status as predicted by genotyping and SSRI concentrations.

## Question 3b: CYP450 Testing and Efficacy of SSRIs

Question 3b is: How well does CYP450 testing predict drug efficacy? Do factors such as race/ethnicity, diet, or other medications, affect this association?

### Approach

To address this question, we sought to identify all studies in which patients treated with SSRIs were tested for CYP450 genetic polymorphisms. Studies were included irrespective of the method used for genotyping. Because of the overall paucity of data, we included studies that had diagnoses other than non-psychotic depression as an indication for SSRI treatment, as clinical outcomes in such scenarios may be indicative of genotype effects. We also included studies in which only a subgroup of patients was treated with SSRIs, while others were treated with other antidepressants, including tricyclics.

### Results

Note: Here, as throughout Chapter 3, the terms “poor metabolizer (PM),”“extensive metabolizer (EM),” etc., refer to general phenotypes (for a probe drug) as predicted by genotyping.

We identified only five studies that examined the association between CYP450 genotypes and SSRI efficacy (see Evidence Table 3, Appendix D ^*^). All studies were cross-sectional in design. All five studied CYP2D6 polymorphisms. One additionally studied 2C9 and 2C19 polymorphisms. Three studies examined depressed patients on antidepressant treatment (Table 14). Gerstenberg et al.^83^ found no differences in the proportion of responders among CYP2D6 EMs, intermediate metabolizers (IMs), and PMs treated with fluvoxamine. There were also no differences between the three groups on final Montgomery-Åsberg Depression Rating Scale (MADRS) scores, percent improvement, or amelioration score. Fluvoxamine steady-state concentrations were found to be significantly higher in responders than in non-responders, but were not reported by genotype. Grasmader et al.^72^ found that although plasma concentrations varied significantly between groups (with respect to 2D6 and 2C9 metabolizer status), levels above or below the lower limit of presumed therapeutic levels did not predict response. Murphy et al.^74^ found no differences in depression scores between two groups, CYP2D6 UMs + EMs versus PMs + IMs, treated with paroxetine. The groups were combined because of low numbers of UM and PM phenotypes.

Table 14 CYP450 predicted phenotypes and efficacy of SSRIs

Study/ design | Patient characteristics | SSRI(s) | Alleles of interest | Predicted phenotypes | Results
Gerstenberg et al., 2003^83^ | 49 Japanese patients with depression | Fluvoxamine (50 mg 1st week, 100 mg 2nd week, and 200 mg in remaining 4 weeks) | 2D6 *1, *3, *4, *5, *10 | EMs = 25%; IMs = 55%; PMs = 20% | Final MADRS score, % improvement, amelioration score, and proportion of responders not significantly different in the 3 groups (Ems, IMs, PMs). Raw data and p-values NR
Cross-sectional study
Grasmader et al., 2004^72^ | 136 depressed patients (70 on SSRIs), ethnicity NR (refers to Caucasians in conclusion) | Fluvoxamine, paroxetine, sertraline, citalopram | CYP2C9 *1 to *3, CYP2C19*1 and *2, 2D6 *1 to *9 and gene duplication | NR | Plasma concentration above or below lower limit of presumed therapeutic levels did not predict response (p = 0.082 for CGI, p = 0.982 for HAM-D)
Cross-sectional study
Murphy et al., 2003^74^ | 246 with depression, ethnicity NR | Paroxetine (n = 120) (and mirtazapine) | 2D6: 16 alleles, deletion, duplication, and *41 allele | PMs = 6.5%; IMs = 10.5%; UMs = 4%; EMs = 79% | No differences between PM + IM vs. EM + UM groups in depression measures (p-values NR)
Cross-sectional study | | | | For paroxetine, PM + IM (n = 15, 12.5% ) vs. EM + UM (n = 105, 87.5%)

Abbreviations: CGI = Clinical Global Impressions Scale; EM(s) = extensive metabolizer(s); HAM-D = Hamilton Rating Scale for Depression; IM(s) = intermediate metabolizer(s); MADRS = Montgomery-Åsberg Depression Rating Scale; NR = not reported; PMs = poor metabolizer(s); SSRI(s) = selective serotonin reuptake inhibitor(s); UM(s) = ultra-rapid metabolizer(s)

The remaining two studies examined the prevalence of different CYP2D6 genotypes in non-responders to adequate antidepressant treatment, including SSRIs (Table 15). Rau et al.^84^ found a three-fold increase in the frequency of CYP2D6 UMs in a group of 16 German depressed patients non-responsive to antidepressants (only five treated with SSRIs) in comparison to the general population. Kawanishi et al.^85^ found a significantly greater prevalence of 2D6 UM phenotypes in non-responders (subgroup of 81 Nordic Caucasian patients treated with 2D6 metabolized drugs) compared to the general population. “Worst week” Hamilton Rating Scale for Depression (HAM-D) scores were found to be higher in UMs than in EMs.

Table 15 Prevalence of CYP2D6 predicted phenotypes in non-responders to antidepressant treatment

Study/ design | Patient characteristics | SSRI(s) | Alleles of interest | Results
Rau et al., 2004^84^ | 16 patients with non-response to SSRIs (n = 5), SNRIs, ethnicity NR (alludes to white) | Various SSRIs | 2D6 *3, *4, *6, *2, *8, *10, *14, *41, *5 | 18% were UMs (3/16), compared to 2.5 to 3% in the general German population (5-fold increase; p = 0.0013)
Cross-sectional prevalence study
Kawanishi et al., 2004^85^ | 108 Nordic Caucasians with depression and non-response to > 2 treatments | Various SSRIs, plus other classes of antidepressants | 2D6 gene duplication, and *2, *3, *4, *5 | Frequency of PM genotype was 0.028 (95% CI 0 to 0.058), less than in general population (0.068).
Cross-sectional prevalence study | | | | Frequency of UMs in the subgroup of 81 subjects treated with CYP2D6 substrates was 9.9% (95%CI 3.4 to 16.4%), significantly greater than in the general Swedish (1%)/Danish (0.8%) populations (95% CI 0.2 to 1.4%)

Abbreviations: CI = confidence interval; EM(s) = extensive metabolizer(s); HAM-D = Hamilton Rating Scale for Depression; NR = not reported; PMs = poor metabolizer(s); SNRI(s) = serotonin/norepinephrine reuptake inhibitors; SSRI(s) = selective serotonin reuptake inhibitor(s); UM(s) = ultra-rapid metabolizer(s)

### Discussion

Based on the available evidence, a definitive association of CYP450 (2D6, 2C9, 2C19) genotypes and efficacy of SSRIs cannot be inferred.

Methodological issues in studies addressing this question include:

(1) Study-design and power: None of the studies was a prospective randomized trial. Three^72,^ ^74,^ ^83^ were observational or correlational studies, and two^84,^ ^85^ were pilot studies of prevalence of CYP polymorphisms in non-responders to antidepressant treatment. All the studies had very small numbers of patients in the UM groups.
(2) Only two studies^74,^ ^83^ studied individual SSRIs (fluvoxamine and paroxetine respectively), while the others grouped the SSRIs together or with groups of other antidepressants. Combining various SSRIs, and moreover SSRIs with other antidepressant medications, may have confounded results because of variability in contribution of different CYP enzymes to metabolism of different SSRIs and other antidepressants, and variability in CYP inhibition by different SSRIs.
(3) The two prevalence studies considered^84,^ ^85^ have the obvious shortcoming of comparing CYP2D6 UM prevalence in depressed non-responder patients to the UM prevalence in the general population. It is possible that CYP2D6 UM phenotype itself is associated with presence of severe depression that is treatment-resistant, which may have accounted for high prevalence of this phenotype in non-responders to antidepressant treatment. It would be more meaningful to compare prevalence rates between responders and non-responders to a given SSRI, which would require a very large sample. In addition, neither of these studies specified exclusion criteria.
(4) The data considered do not lead to any conclusions about the possible impact of race/ethnicity, diet, or other medications on the association between CYP450 genotypes and SSRI efficacy.
(5) Genetic factors affecting serotonin receptor proteins, membrane transporters, and signal transduction molecules could also have important pharmacodynamic effects that could affect SSRI efficacy.^86^ Thus, examining the impact of pharmacokinetic variability resulting from CYP enzyme polymorphisms on SSRI efficacy in isolation may not be optimal.

The quality assessment criteria we applied to individual studies in this report^52^ (Appendix E ^*^) yielded a range of scores between “3b” and “4.” For the suggestion that CYP450 genotypes do not affect SSRI efficacy, the grade of recommendation based on available data would be “C.”

### Conclusions

Because of the poor quality of relevant data that could be identified to address the question, no firm conclusions can be drawn about the relationship between CYP450 genotypes and efficacy of SSRI treatment in patients with non-psychotic depression.

## Question 3c: CYP450 Testing and Adverse Drug Reactions

Question 3c is: How well does CYP450 testing predict adverse drug reactions? Do factors such as race/ethnicity, diet, or other medications, affect this association?

### Approach

To address this question, we sought to identify all studies in which patients treated with SSRIs were tested for CYP450 genetic polymorphisms. Studies were included irrespective of the method used for genotyping. Because of the overall paucity of data, we included studies that had diagnoses other than non-psychotic depression as an indication for SSRI treatment, as clinical outcomes in such scenarios may be indicative of genotype effects. We also included studies in which only a subgroup of patients was treated with SSRIs, while others were treated with other antidepressants, including tricyclics. Studies that specifically examined adverse effects were particularly sought.

### Results

Note: Here, as throughout Chapter 3, the terms “poor metabolizer (PM),”“extensive metabolizer (EM),” etc., refer to general phenotypes (for a probe drug) as predicted by genotyping.

We identified nine studies that met our inclusion criteria (see Evidence Table 4, Appendix D ^*^). Of these, three reported the incidence of adverse effects in PMs, but this outcome was not central to the aims of the study.^43,^ ^72,^ ^87^ These studies do not add any information of value to the discussion and are not considered further here. The remaining six studies are summarized in Table 16.

Table 16 CYP450 predicted phenotypes and adverse effects associated with SSRIs

Study/design | Patient characteristics | SSRI(s) | Alleles of interest | Predicted phenotypes | Results
Chen et al., 1996^88^ | 74 patients, ethnicity NR | Various, including paroxetine, fluoxetine, sertraline, fluvoxamine, (also TCAs) | 2D6 - A, B, D, E, and T alleles | NR | PM phenotype was significantly more frequent in depressed patients (n = 18; 44%) reporting adverse effects to substrate of 2D6 compared to a random group (n = 56; 21%) of depressed patients (p < 0.05), or compared to the general population
Cross-sectional prevalence study
Rau et al., 2004^84^ | 28 patients with adverse effects to SSRIs (9 patients), SNRIs, ethnicity NR (alludes to white) | Various SSRIs | 2D6 *3, *4, *6, *2, *8, *10, *14, *41, *5 | PM: 29% | 29% PMs compared to 7% in the German population (p < 0.0001).
Cross-sectional prevalence study | | | | IM: 7% | There were no differences between PM, IM, and EM groups in frequency of dose reduction (p = 0.14), stopping treatment (p = 0.51), reducing or terminating antidepressant (p = 0.39), or number of adverse effects (p = 0.12)
| | | | EM: 64%
| | | | UM: 0
Gerstenberg et al., 2003^83^ | 49 Japanese | Fluvoxamine (50 mg 1st week, 100 mg 2nd week, and 200 mg in remaining 4 weeks) | 2D6 *1, *3, *4, *5, *10 | PM: 20% | Incidence of adverse effects (nausea) was not significantly different between the 3 groups (raw data and p-value NR)
Cross-sectional study | | | | EM: 25%
| | | | IM: 55%
Murphy et al., 2003^74^ | 246 patients, ethnicity NR | Paroxetine (and mirtazapine, not reported here) | 2D6: 16 alleles, deletion, duplication, and *41 allele | PM: 6.5% | No differences between PM + IM vs. EM + UM groups in severity of adverse effects or frequency of discontinuation (p-values NR)
Cross-sectional study | | | | IM: 10.5%
| | | | UM: 4%
| | | | EM: 79%
Roberts et al., 2004^89^ | 125 patients, ethnicity NR | Fluoxetine n = 65 (randomized to fluoxetine or nortriptyline) | 2D6 alleles *1 to * 16, *19, *20 | PM: 9% | PMs were no more likely to experience adverse effects than EMs (17% of PMs vs 41% of EMs) and were no more likely to drop out of the study than EMs (PMs 33% vs. EMs 14%) (p-values NR)
Cross-sectional study | | | | EM: 91%
Suzuki et al., 2006^90^ | 97 Japanese | Fluvoxamine (25–200 mg) | 2D6 alleles *5, *10 | PM: 22.7% | Greater prevalence of GI side effects in PMs compared to EMs (p = 0.043; CI 1.019 to 3.254). Discontinuation rates similar between PMs and EMs (p = 0.310)
Cross-sectional study | | | | EM: 77.3%

th Abbreviations: CI = confidence interval; DSM-IV = Diagnostic and Statistical Manual for Mental Disorders, 4 edition; EM(s) = extensive metabolizer(s); GI = gastrointestinal; HAM-D = Hamilton Rating Scale for Depression; IM(s) = intermediate metabolizer(s); MADRS = Montgomery-Åsberg Depression Rating Scale; NR = not reported; PMs = poor metabolizer(s); SNRI(s) = serotonin/norepinephrine reuptake inhibitors; SSRI(s) = selective serotonin reuptake inhibitor(s); TCAs = tricyclic antidepressants; UM(s) = ultra-rapid metabolizer(s)

All six studies examined CYP2D6 polymorphisms only. Three of the six studies reported no differences in rates of adverse effects between PMs and EMs,^83,^ ^84,^ ^89^ while a fourth^74^ reported no differences in adverse effects between the combined PM + IM and EM + UM groups. One study found a greater prevalence of gastrointestinal (GI) adverse effects in PMs compared to EMs.^90^ This study also found that the combination of CYP2D6 polymorphism and serotonin receptor 5HT2A polymorphism predicted GI adverse effects, such that PM + GG and PM +AG had a significantly greater risk of developing GI side effects compared to EM + AA.

Two studies^84,^ ^88^ found a significantly higher prevalence of PMs in depressed patients with adverse effects than in the general population. One of these^88^ also found the PM phenotype to be more frequent in depressed patients with adverse effects than in a random group of depressed patients. Studies that reported types of adverse effects reported a range of typical SSRI adverse effects including but not limited to anxiety, agitation, restlessness, nausea, GI upset, headache, sleep disturbance, and sexual dysfunction.^83,^ ^84,^ ^89^ The most common adverse effect reported in studies was nausea.

### Discussion

Although four studies did not find any differences in adverse effects in PMs versus EMs, these studies are heterogeneous, with major methodological problems, including:

(1) Study design and power: None of the studies was a prospective randomized trial. Four^74,^ ^83,^ ^89,^ ^90^ were observational or correlational studies, and two^84,^ ^88^ were pilot studies of the prevalence of CYP polymorphisms in patients who had adverse effects with antidepressant treatment. All the studies had very small numbers of patients in the PM groups.
(2) Three studies examined individual SSRIs^74,^ ^83,^ ^89^ (paroxetine, fluvoxamine, and fluoxetine, respectively), whereas the other two grouped the SSRIs together or with groups of other antidepressants. Combining various SSRIs, and moreover SSRIs with other antidepressant medications, may have confounded results because of variability in contribution of different CYP enzymes to metabolism of different SSRIs and other antidepressants, and variability in CYP inhibition by different SSRIs.
(3) The two prevalence studies considered^84,^ ^88^ did not specify exclusion criteria. Moreover, comparing a group of patients with adverse effects to a particular SSRI to a group of patients with no adverse effects to that SSRI may have been more meaningful, but will require a large number of patients.
(4) The data considered do not lead to any conclusions about the possible impact of race/ethnicity, diet, or other medications, on the association between CYP450 genotypes and adverse effects to SSRIs.
(5) Genetic factors affecting serotonin receptor proteins, membrane transporters, and signal transduction molecules could also have important pharmacodynamic effects that could affect SSRI tolerability.^86^ Thus, examining impact of pharmacokinetic variability resulting from CYP enzyme polymorphisms on SSRI tolerability in isolation may not be optimal. Only one study^90^ addressed this issue and did in fact show combined effects of CYP2D6 and 5HT2A polymorphisms on GI adverse effects, further supporting this point.

The quality assessment criteria we applied to individual studies in this report^52^ (Appendix E ^*^) yielded a range of scores between “2b” and “4.” For the suggestion that CYP450 genotypes do not affect SSRI tolerability, the grade of recommendation based on available data would be “C.”

### Conclusions

Because of the poor quality of relevant data that could be identified to address the question, no firm conclusions can be drawn about the relationship between CYP450 genotypes and tolerability of SSRI treatment in patients with non-psychotic depression.

## Question 4: Management Decisions, Clinical Outcomes, and Decisionmaking

Question 4 is:

(a) Does CYP450 testing influence depression management decisions by patients and providers in ways that could improve or worsen outcomes?

(b) Does the identification of the CYP450 genotypes in adults entering SSRI treatment for non-psychotic depression lead to improved clinical outcomes compared to not testing?

(c) Are the testing results useful in medical, personal, or public health decisionmaking?

To address this question, we sought to identify studies in which patients treated with SSRIs were tested for CYP450 genetic polymorphisms, and in which investigators reported on the impact of such testing on outcomes or on medical, personal, or public health decisionmaking. Even after relaxing our inclusion criteria to include all methods used for genotyping and all indications for SSRI treatment, we were unable to identify any studies that directly addressed any aspect of this question. In addition, we did not find any studies examining the effect of CYP genotypes on SSRI inhibition of CYP enzymes, leading to adverse effects associated with concurrent medications.

## Question 5: Harms Associated With CYP450 Testing and Subsequent Management Options

Question 5 is: What are the harms associated with testing for CYP450 polymorphisms and subsequent management options?

To address this question, we sought to identify studies in which patients treated with SSRIs were tested for CYP450 genetic polymorphisms, and in which investigators reported on harms or negative outcomes associated with testing or with subsequent management options. It may be hypothesized that, like other genetic tests, CYP genotyping could raise issues of labeling (“treatment-resistant” in the case of UMs) in the minds of providers, patients, or third-party payers that may negatively impact outcomes. This question of harm therefore is very relevant as we consider feasibility of CYP genotyping in practice.

Even after relaxing our inclusion criteria to include all methods used for genotyping and all indications for SSRI treatment, we were unable to identify any studies that directly addressed any aspect of this question.

## Model of Treatment for Major Depression

This section explores the potential clinical impact of CYP450 genotype testing as a guide to therapy of patients newly diagnosed with depression.

### Background

In deciding whether to use CYP450 genotype testing to guide depression therapy, it would be ideal to have direct scientific studies demonstrating that use of genotype testing leads to improved clinical outcomes. In the absence of such direct evidence, decision modeling can be used to provide indirect evidence based, for example, on the relationship between genotype and specific serotonin selective reuptake inhibitor (SSRI) metabolism (phenotype), and the relationship between phenotype and responsiveness to therapy. Examining these clinical relationships is of paramount importance. Genetic testing, like all forms of diagnostic tests, should only be promoted if the potential benefits (such as improved response to treatment for depression) outweigh the potential harms (such as increased adverse effects).

Decision analysis is a tool that provides a mechanism for inferring the likely outcomes of competing options by modeling the relationship between each option and the outcome of interest. Such decision models provide a framework for linking information from multiple sources (e.g., epidemiological studies, test performance studies, treatment efficacy studies, and surveys of patient preferences and quality of life). In addition to providing a “best guess” about the impact of a particular decision, decision models can offer insight into the dynamic relationship between various clinical inputs and decision relevant outcomes - under what circumstances is one decision preferred over others? This use of a decision model is especially valuable when the input data are not particularly strong, as is the case here.

We constructed and evaluated a decision model to address the question: Under what circumstances would genetic testing for CYP isoenzymes during the initial evaluation of an individual with non-psychotic major depression lead to a better clinical outcome, when compared to empiric SSRI therapy?

### Methods

Population. The population of interest for the model was treatment-naïve adults who met the DSM-IV criteria for major depression. They were otherwise generally healthy and not taking medications that could interact with SSRIs.

Model structure. The model is a simple tree structure (Figure 2) with four options: (1) do not test and treat empirically with an SSRI not affected by genotype; (2) test and use the results to select an SSRI that is or is not affected by genotype; (3) test and use the results to select the dose of an SSRI affected by genotype; or (3) do not test and treat empirically with an SSRI affected by genotype. In this analysis, we were not focusing on any particular SSRI; however, the issue is illustrated by the examples of fluoxetine and sertraline. Fluoxetine is a generic and inexpensive medication that is primarily metabolized by the 2D6 enzyme, and sertraline is a more expensive medication that is not.^87^ Although the overall response rate for standard dosing of fluoxetine (40 mg) is similar to that for sertraline, the adverse event rate is likely to be higher in those with poor metabolism (due to higher than normal serum concentrations), and the response rate lower in those with ultra-rapid metabolism (due to lower than normal serum concentrations). In this setting, empiric therapy with the non-CYP metabolized medication will always be the most effective strategy since it eliminates the potential for complications related to enzyme metabolism; however, the higher cost limits its widespread availability.

Figure 2. Model structure

For each strategy, an individual could have one of three phenotypes: ultra-rapid metabolizer, extensive metabolizer/intermediate metabolizer, or poor metabolizer, with a probability based on the distribution of phenotypes in the population. We combined the extensive and intermediate metabolizers into a single phenotype to simplify the model since there was little data to support a difference in response to therapy for these two groups. For the first model strategy (use of a non-CYP metabolized SSRI without testing), the likelihood of treatment success is assumed to be the same for all phenotypes. For the second option (use of genetic testing to select SSRI), patients with genotypes that correspond to phenotypes with a high probability of treatment failure (ultra-rapid and poor metabolizers) would receive the more expensive non-CYP metabolized medication, while those not at high risk (extensive and intermediate metabolizers) would receive the less expensive CYP metabolized one. For the third option (use of genetic testing to select dose of SSRI), results of the genetic test are used to adjust the dose of the CYP metabolized medication. A low dose would be used for poor metabolizers, a standard dose for extensive and intermediate metabolizers, and a high dose for ultra-rapid metabolizers. For the fourth option (use of a CYP metabolized SSRI without testing), the likelihood of treatment success depends upon phenotype.

The model was created as a decision tree using TreeAge ProSuite 2006 (TreeAge Software Inc, Williamstown, MA)

Model parameters. The estimate and source for each model parameter are shown in Tables 15 and 16. For the purposes of this model our estimates for efficacy of therapy were based upon fluoxetine for the CYP metabolized SSRI and sertraline for the non-CYP metabolized SSRI.

Table 17 Basic model parameter estimates

Description | Value | Source
Prevalence ultra-rapid metabolizers in general depressed population | 0.03 | Grasmader et al., 2004;^68^ Charlier et al., 2003^66^
Prevalence of extensive metabolizers in general depressed population | 0.86 | Grasmader et al., 2004;^68^ Charlier et al., 2003^66^
Prevalence of poor metabolizers in general depressed population | 0.11 | Grasmader et al., 2004;^68^ Charlier et al., 2003^66^
Utility of untreated depression | 0.32 | Bennett et al., 2000^88^
Utility of treated depression | 0.99 | Expert opinion
Probability of responding to sertraline | 0.56 | Rossini et al., 2005^89^
Cost of medication primarily metabolized by CYP450 (fluoxetine) | 12 | Anonymous^90^
Cost of medication not primarily metabolized by CYP450 (sertraline) | 130 | Anonymous^90^
Cost of genetic testing | 1000 | Palylyk-Colwell, 2006^91^

Table 18 Model parameters for the relationship between testing and predicted clinical response

Description | High correlation | Low correlation
Probability phenotype poor will have genotype poor | 0.58 | 0.35
Probability phenotype poor will have genotype extensive | 0.37 | 0.39
Probability phenotype poor will have genotype ultra-rapid | 0.05 | 0.26
Probability phenotype extensive will have genotype poor | 0.2 | 0.23
Probability phenotype extensive will have genotype extensive | 0.45 | 0.35
Probability phenotype extensive will have genotype ultra-rapid | 0.35 | 0.42
Probability phenotype ultra-rapid have genotype poor | 0.14 | 0.13
Probability phenotype ultra-rapid will have genotype extensive | 0.49 | 0.36
Probability phenotype ultra-rapid will have genotype ultra-rapid | 0.5 | 0.38
Probability of responding to high dose fluoxetine if phenotype ultra-rapid | 0.61 | 0.56
Probability of responding to high dose fluoxetine if phenotype extensive | 0.5 | 0.45
Probability of responding to high dose fluoxetine if phenotype poor | 0.4 | 0.21
Probability of responding to medium dose fluoxetine if phenotype ultra-rapid | 0.5 | 0.45
Probability of responding to medium dose fluoxetine if phenotype extensive | 0.61 | 0.56
Probability of responding to medium dose fluoxetine if phenotype poor | 0.5 | 0.45
Probability of responding to low dose fluoxetine if phenotype ultra-rapid | 0.4 | 0.21
Probability of responding to low dose fluoxetine if phenotype extensive | 0.5 | 0.45
Probability of responding to low dose fluoxetine if phenotype poor | 0.61 | 0.56

In clinical decisionmaking, a key question is the probability that any particular genotype will correspond to a particular level of drug metabolism (phenotype). This question is paramount since the phenotype is purported to effect the likelihood of treatment success, both effectiveness and adverse effects. However, the available literature presents limited data on these essential probability estimates. In the absence of data, we used the technique of bootstrapping to backwards calculate probabilities which were consistent with the two correlation coefficients (0.2 and 0.8). Specifically, we created a series of tables (genotype x phenotype) in which synthetic patient samples were assigned to cells with the target correlation coefficient; the cells were divided by the row totals, and the resulting elements were the estimated probabilities that a specific genotype would be associated with a specific phenotype. We repeated this exercise for both levels of correlation on each genotype to phenotype pair. For example, when the correlation between genotype and phenotype is 0.8 (high), the estimated probability that an ultra-rapid phenotype will have an ultra-rapid genotype is 0.5; if the correlation is 0.2 (low), the estimated probability is only 0.38.

The clinical predictive value of phenotype is reflected in the model as the probability that an individual with a specific phenotype will respond to a specific SSRI. These estimates were based upon expert opinion; however, their clinical plausibility was verified by comparing calculated overall population response rates (using the estimates and known prevalence rates) to published response rates.

As a practical strategy for examining the impact of variations in the relationship between genotype and phenotype, and between phenotype and clinical response, we created four scenarios for levels of linkage between genotype and clinical outcome. These four scenarios corresponded to the four possible combinations of level of correlation between genotype and phenotype (high or low), and correlation between phenotype and clinical response (high or low).

Response rates for the non-CYP metabolized medication were assumed to be the same for all three genotypes since metabolism is not affected significantly by any one of the polymorphisms. For the purposes of this model we assumed that the analytic sensitivity and specificity of the genetic testing used in the field compared to a gold standard genetic testing was 100 percent.

In order to understand the impact of each strategy on quality of life, patient outcomes were adjusted by a quality of life multiplier. This multiplier intended to represent patient preferences for a given health state as a utility. We used the utility of moderate depression to represent those individuals who did not respond to medication by 6 weeks, and a utility very close to that of non-depressed healthy individuals for those who did.^88^

Outcomes. We estimated two different clinical outcomes at 6 weeks: percent response to medical therapy and cumulative quality-adjusted survival at 6 weeks (in years). Response to medical therapy was defined as a 50 percent or greater improvement as measured by the HAM-D scale. We chose to measure these outcomes at 6 weeks, since response to an initial 6-week trial predicts both ultimate success with a medication and adherence to it. Longer time frames do not improve the response to initial therapy, and since adverse effects are rarely serious, the greatest potential benefit of genetic testing will be to improve initial response rates. In addition, we calculated the average cost for each strategy over a single trial of therapy (6 weeks).

Analyses. In decision modeling it is typical to create a best-guess or “base case” estimate of outcomes. Given the lack of high quality data permitting a credible point estimate for model inputs, we chose to provide results for each of the four levels of linkage, described above. For each of these levels, we also performed one-way sensitivity analysis on all other model inputs (that is, other than probabilities related to the levels of linkage.)

### Results

The outcomes for each of the four analyses are presented in Figures 3 and 4.

Figure 3. Model results at 6 weeks for response rate

Figure 4. Model results at 6 weeks for quality adjusted life

For each of the four scenarios, treating with a non-CYP metabolized SSRI without testing was the most effective strategy, while treating with a CYP metabolized SSRI was the least effective. Of the two testing strategies examined, using testing to guide use of a CYP- versus a non-CYP metabolized SSRI was superior to using testing to guide the dose of a non-CYP SSRI, both in terms of response rates and quality-adjusted life. However, as the level of linkage between genotype and phenotype increased, the difference in efficacy between the two testing strategies and between the testing strategies and the dominant strategy narrowed, such that at the high linkage level both testing strategies approached the efficacy of the optimal strategy of using a non-CYP metabolized SSRI. For example, in the low linkage scenario, the difference between the two testing strategies was 7.92 % in response rate and 0.04 years for cumulative quality-adjusted survival, while in the high linkage scenario the difference was only 0.78% in response rate and 0.005 years for cumulative quality-adjusted survival at 6 weeks.

One-way sensitivity analyses were performed for the following variables: prevalence of each phenotype, utility of depression, probability of responding to sertraline, cost of fluoxetine, cost of sertraline, and cost of genetic testing. The results of these analyses (not shown) were robust, with the relationship between the various options remaining similar at all levels of linkage between genotype and clinical response.

Because of the non-trivial cost of testing, 6-week costs are always greater for the testing strategy (results not shown), even when compared to the strategy of using a non-CYP metabolized drug without testing. For example, using genetic testing to guide medication choice cost $909 more than empiric therapy with a non-CYP medication, while using genetic testing to guide CYP dosing cost $882 more. The least effective strategy was also the least expensive- empiric treatment with a CYP metabolized medication cost $118 less than the empiric treatment with a non-CYP medication. However, if the length of treatment is expected to exceed approximately 9 months, the cost of the test strategies break even.

### Discussion

In this analysis of the potential impact of CYP450 genotype testing on treatment outcomes in a trial of SSRI therapy, use of a non-CYP metabolized SSRI without testing was always the most effective strategy, and use of a CYP metabolized SSRI was always least effective. The two genetic testing strategies considered (testing as a guide to use of a CYP or non-CYP metabolized SSRI) had intermediate efficacy. The degree of efficacy depended primarily on the linkage between genotype and clinical outcome. At relatively low levels of linkage testing provides little benefit over use of a CYP metabolized SSRI without testing. Testing approached the optimal efficacy only at the highest levels of linkage between genotype and clinical outcome. Further, the modeling exercise suggests that the most important element of the link is the ability of genotype to predict phenotype. It is notable that these results apply even though it was assumed that the analytic validity of the test used (ability of the test to discern true genotype) was perfect.

Given the lack of evidence regarding many of the model inputs, it is important not to overstate the specific numerical results. However, the analysis does provide insight into the reasons why various strategies may or may not be clinically desirable. What is easiest to explain is the superiority of the strategy using a non-CYP drug without testing. The reason is that we assume that non-CYP medications do not have increased adverse event rates or reduced response rates in the poor and ultra-rapid metabolizers, respectively, and the CYP drug was assumed to never be superior for any phenotype. What may be less evident is why neither testing strategy was optimal for any combination of plausible model inputs. The explanation is that an imperfect genetic test (i.e., one that provides less than perfect guidance to metabolism, efficacy, or adverse effects) can lead to worse outcomes for misclassified individuals. When ultra-rapid or poor metabolizers are misclassified as extensive metabolizers, they are mistakenly managed with higher risk treatments. In the strategy in which testing is used to guide use of a CYP or non-CYP metabolized SSRI, misclassified individuals are given a CYP metabolized SSRI at standard doses, increasing their risk for adverse effects or lowering the probability of responding. In a strategy in which genetic testing is used to adjust the dose of a CYP metabolized SSRI, misclassified individuals are offered either very high or very low doses of the CYP metabolized SSRI, effectively doubling their risk of a poor outcome.

This basic analysis suggests that when non-CYP metabolized SSRIs are available, they should be used. When this approach is not feasible, CYP genotyping may provide similar patient outcomes if the test results can be shown to be highly predictive of clinical response. A difficulty in supporting the use of CYP450 genotype testing is the lack of evidence regarding the ability of CYP genotyping to guide treatment; if the correlation between genotype and outcomes is only modest, testing strategies are unlikely to be much more effective than treating with a CYP metabolized SSRI without testing. Also, since testing has its own cost, testing strategies do not save costs, even for the optimistic “high correlation” scenario, unless expected treatment duration exceeds approximately 9 months.

Clearly, studies of the relationship between genotype and clinical outcomes present a high value target for future research. Additional modeling which includes variable lengths of treatment, the possibility of treatment changes would help clarify the likely impact of CYP 450 genotype testing on long-term benefits, risks, and costs.