# Methods

This section of the report describes the basic methodology used to develop the evidence report, including topic assessment and refinement, analytic framework, literature search strategies and results, literature screening, quality assessment, data abstraction methods, and quality control procedures.

## Topic Assessment and Refinement

The two study sponsors, the Agency for Healthcare Research and Quality (AHRQ) and the Centers for Disease Control and Prevention (CDC), originally identified five key questions to be addressed by the report. The Duke research team clarified and refined the overall research objectives and key questions by first consulting with these sponsors and then by convening a national panel of technical experts to serve as advisors to the project. These experts were selected to represent relevant specialties, including genomics and neuropsychiatry. Members of the technical expert panel were:

Kathryn A. Phillips, Ph.D., University of California, San Francisco, CA (member of the CDC Evaluation of Genomic Applications in Practice and Prevention [EGAPP] Working

Group)

Margaret Piper, Ph.D., M.P.H., B.C.B.S.A., Atlanta, GA (EGAPP Working Group member)

Ora Strickland, Ph.D., Emory University, Atlanta, GA (EGAPP Working Group member)

Dan G. Blazer, M.D., Ph.D., Duke University Medical Center, Durham, NC

Stephen Stahl, M.D., Ph.D., Neuroscience Education Institute, Carlsbad, CA

The Duke research team refined the key questions as follows:

Question 1 (overarching question): Does testing for cytochrome P450 (CYP450) polymorphisms in adults entering selective serotonin reuptake inhibitor (SSRI) treatment for non-psychotic depression lead to improvement in outcomes, or are testing results useful in medical, personal, or public health decisionmaking?

Question 2: What is the analytic validity of tests that identify key CYP450 polymorphisms?

Question 3a: How well do particular CYP450 genotypes predict metabolism of particular SSRIs? Do factors such as race/ethnicity, diet, or other medications, affect this association?

Question 3b: How well does CYP450 testing predict drug efficacy? Do factors such as race/ethnicity, diet, or other medications, affect this association?

Question 3c: How well does CYP450 testing predict adverse drug reactions? Do factors such as race/ethnicity, diet, or other medications, affect this association?

Question 4a: Does CYP450 testing influence depression management decisions by patients and providers in ways that could improve or worsen outcomes?

Question 4b: Does the identification of the CYP450 genotypes in adults entering SSRI treatment for non-psychotic depression lead to improved clinical outcomes compared to not testing?

Question 4c: Are the testing results useful in medical, personal or public health decisionmaking?

Question 5: What are the harms associated with testing for CYP450 polymorphisms and subsequent management options?

## Analytic Framework

The methodological approach to this review was designed to inform the EGAPP Working Group's deliberations in formulating evidence-based recommendations for the use of genetic testing in depression treatment decisionmaking. With input from the EGAPP Working Group, we developed a project-specific analytic framework (Figure 1) to address the key questions within the context of a standardized evidence report.

Figure 1. Analytic framework for evidence report

Within the domain of testing and depression management, the analytic framework depicted in Figure 1 provides an explicit link between the use of the test and the various health outcomes of importance to decisionmakers. Such a framework also serves to clarify the relevant key questions (numbers in the figure refer to key questions):

- Question 1 poses the overarching question of whether testing for CYP450 polymorphisms before SSRI treatment in non-psychotic depressed adults improves outcomes. Any evidence relating to this question would be “direct” evidence for the purpose of decisionmaking. In the absence of compelling direct evidence of this type, it is relevant to consider the component questions (Questions 2 through 5).
- Question 2 examines the ability of clinically available tests for CYP450 polymorphisms to detect genetic variations in the CYP450 genes. This is a question of analytic validity that compares available tests to the gold standard of DNA sequencing. Issues related to harms due to misclassification are addressed in Question 5, below.
- Questions 3a, 3b, and 3c concern the relationship between CYP genotypes or their predicted phenotypes and metabolism of individual SSRIs, efficacy of SSRIs in depression treatment, and adverse effects associated with SSRIs, respectively. These questions relate to clinical validity. Additionally, they address surrogate outcomes in depression management. Efficacy of SSRIs is a surrogate outcome measured by change in depression scores on depression rating scales such as the Hamilton Rating Scale for Depression (HAM-D)^44^ or the Montgomery-Åsberg Depression Rating Scale (MADRS).^45^
- Questions 4a and 4c examine the influence of CYP genotyping on management decisions by patients or providers, and on medical, personal, or public health decisionmaking, respectively. Both of these are surrogate outcomes. Question 4b addresses whether such testing improves outcomes in depression management versus not testing. Examples of health outcomes of depression include health associated quality of life measured by the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36),^46^ the Sheehan Disability Scale,^47^ or the Quality of Life Enjoyment and Satisfaction Questionnaire (QLESQ).^48^ Economic outcomes may include healthcare utilization or absenteeism related to depression. These questions concern decisionmaking at both individual and societal levels. These questions relate to clinical utility and raise the most important aspects of Question 1.
- Question 5 addresses the potential harms associated with CYP testing itself and with subsequent management options. Potential harms could include labeling of patients as “treatment resistant” if they are found to be ultra-rapid metabolizers of relevant drugs, or harms could result from basing treatment decisions on inaccurate test results. As such, this question relates to both surrogate and health outcomes.

## Literature Search and Review

### Sources

The primary source of literature was MEDLINE^®^ (1966-May 2006). Additional databases searched included the Cochrane Database of Abstracts of Reviews of Effects (DARE), PsychInfo, HealthSTAR, and CINAHL. Searches of these databases were supplemented by reviews of the reference lists contained in all included articles and in relevant review articles. We also included data from the U.S. Food and Drug Administration (FDA) website describing the operating characteristics of the Roche AmpliChip^®^ CYP450 Test.^40,^ ^41^ On the advice of our technical expert panel, we did not undertake a comprehensive search of the grey literature.

### Search Strategies

The basic search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE.^®^ Searches were limited to articles published in English. The exact search string used is given in Appendix A.^*^ The searches yielded a total of 1,200 citations, whose records are maintained in a ProCite (Thompson ISI ResearchSoft, Berkeley, CA) database.

* Appendixes cited in this report are provided electronically at www.ahrq.gov/clinic/tp/cyp450tp.htm.

### Abstract and Full-Text Screening

Paired researchers from the Duke research team independently reviewed all abstracts and classified each as “included” or “excluded” according to project-specific criteria, which they developed. The exclusion criteria were:

- Single case.
- SSRI inhibition of CYP enzymes (unless the study examines how this is related to genotype).
- Outside the scope of the report.

An abstract was included for further review if at least one of the paired reviewers recommended that it be included. A total of 140 abstracts were included for review at the full-text stage. Inter-rater reliability for include/exclude decisions at the abstract stage was tested by having five pairs of readers review 862 abstracts. Agreement (kappa statistic) ranged from -0.037 to 0.613.^49^

At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When two reviewers returned different decisions about whether to include or exclude an article, they were asked to reconcile the difference. Detailed full-text exclusion criteria are listed immediately below.

### Full-Text Screening Criteria

Studies were excluded at the full-text screening stage if any of the following applied:

- Single case.
- Patient age < 18 years.
- No gold standard comparison or methods comparison (for articles on analytic validity).
- Study falls outside study scope (e.g., there were several good reviews, including one that made pharmacogenetics-based therapeutic recommendations,^50^ that did not answer any of the key questions directly).

At the full-text stage, studies were further identified as addressing one or more of the following criteria:

A [underlined: Clinical tests for polymorphisms]. These include studies of commercial (e.g., AmpliChip^®^) and other tests that may be used for determining genetic polymorphisms in a clinical setting.
B [underlined: Gold standard]. DNA sequencing is the accepted gold standard for genotyping. Because very few studies used a gold standard comparison, a decision was made also to include studies that used methods comparisons (e.g., polymerase chain reaction and restriction fragment length polymorphism [PCR-RFLP]). In keeping with the clinical diagnostic test literature, these methods are referred to here as a reference standard, acknowledging that they provide a lower level of evidence than gold standard comparisons.
C [underlined: Predicted metabolism of SSRIs]. This includes metabolizer status of an individual with respect to a particular SSRI, e.g., “poor metabolizer” (PM) or “ultra-rapid metabolizer” (UM), and is distinct from PM or UM of a probe drug for a given CYP enzyme. Because an SSRI may not be exclusively metabolized by a certain CYP enzyme, its metabolism may vary from that of the probe drug for that enzyme in a person carrying a function-altering mutation of that CYP enzyme.
D [underlined: Decisionmaking]. This includes decisionmaking by patients and providers; medical, personal, and public health decisionmaking.
E [underlined: Health outcomes of interest]. Heath outcomes included: drug efficacy, adverse drug reactions, and other outcomes such as improved prognosis and quality of life.
F [underlined: Harms]. Harms associated with testing or with subsequent management decisions.

Studies were then classified as addressing one or more of the key questions. For example:

Question 2 (analytic validity): A + B

Question 3a (metabolism of SSRIs): (A or B) + C

Question 4b (improved outcomes versus not testing): (A or B) + E

Please note that although (A or B) + E would apply to all health outcomes questions, we did not expect to find many studies addressing these, and therefore we did not break down E further.

Summaries of the results of the abstract screening and full-text review are provided in Tables 4 and 5. A list of excluded articles, with reasons for exclusion, is provided in Appendix B ^*^

Table 4 Results of abstract screening and full-text review

Articles identified | 1,200
Abstracts reviewed | 1,200
Included | 140
Excluded | 1,060
Full-text articles reviewed | 140
Included | 37
Excluded | 103

Table 5 Included full-text articles by key question

Question 1 (overarching question) | 0
Question 2 (analytic validity) | 14
Question 3a (effects on metabolism) | 16
Question 3b (effects on drug efficacy) | 5
Question 3c (adverse drug reactions) | 9
Question 4a (effects on disease management) | 0
Question 4b (effects on outcomes) | 0
Question 4c (testing usefulness) | 0
Question 5 (testing and management harms) | 0
Total | 37*

* The sum across questions exceeds total because some articles were included for more than one question.

## Data Abstraction and Development of Evidence Tables

The Duke research team developed data abstraction forms/evidence table templates for abstracting data for the various key questions (Appendix C ^*^). Based on clinical expertise, a pair of researchers was assigned to the research questions to abstract data from the eligible articles. One of the pair abstracted the data, and the second researcher over-read the article and the accompanying abstraction to check for accuracy and completeness. The completed evidence tables are provided in Appendix D.^*^

## Quality Assessment Criteria

At the data abstraction stage, the abstracting researcher was asked to evaluate each included article for methodological quality. For Question 2 regarding analytic validity, we assessed quality of studies based on questions in the Analytic validity, Clinical validity, Clinical utility and associated Ethical, legal and social implications (ACCE) model for evaluation of genetic testing (Appendix E ^*^). For all other questions for which we could identify data, we intended to use the quality assessment criteria developed by the Tufts-New England Medical Center Evidence-based Practice Center for an evidence report on “Effects of Omega-3 Fatty Acids on Cardiovascular Disease.”^51^ However, these criteria require the study to be either a randomized controlled trial, longitudinal cohort study, or case-control study, and none of the studies identified for our report had these study designs. Therefore, we elected to use criteria developed by the Oxford Centre for Evidence-based Medicine^52^ (Appendix E ^*^) to evaluate individual studies based on type of the study (therapy vs. prognosis vs. prevalence) and strength of study design, with numerical scores ranging between 1 and 5 (including 1a, 1b, 1c, 2a, 2b, 2c, 3a, 3b, 4, 5). The overall strength of recommendation for each question was then graded for each question as A, B, C, or D according to criteria that take into account the quality of individual studies identified for each question. The quality assessment scores for individual studies are reported in the relevant evidence tables. Because numerical value may not convey details about quality assessment, methodological issues pertaining to studies relevant to individual questions are addressed in the discussion of results for each question.

## Model of Treatment for Major Depression

In addition to conducting the literature review described above, we also developed a decision model of the decision to test for genotype or not, with the primary outcome of interest being success of initial treatment (resolution of depression without adverse effects). The goal of this exercise was to examine the relationships between the intermediate steps described above and outcomes of importance to patients and physicians. Results are discussed in Chapter 3.

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include: three progressively stricter screening opportunities for each article (abstract screening, full-text article review, data abstraction review); involvement of three individuals (two investigators and a copy-editor) in each data abstraction; and agreement of at least two investigators on all included studies.

Our principal external quality-monitoring device is the peer-review process. Nominations for peer reviewers were solicited from several sources, including the technical expert panel and interested federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers submitting comments is provided in Appendix F ^*^