# Introduction

## Major Depressive Disorder

Major depressive disorder (MDD) is widely distributed in the population and is usually associated with substantial symptom severity and role impairment. The lifetime prevalence of MDD by recent population study estimates is as high as 16 percent, with an annual prevalence rate of approximately six percent.^1^ The condition is twice as common in females as in males. MDD is the leading cause of disability in the United States and is predicted to become the second leading cause of disability worldwide in the next 15 years.^2^ Depression is the fourth leading cause of disease burden, accounting for 4.4 percent of total disability-adjusted life years in the year 2000, and it causes the largest amount of non-fatal burden, accounting for almost 12 percent of all total years lived with disability worldwide.^3^ The suicide rate associated with MDD is approximately four percent.^4^

The course of MDD differs a great deal among affected individuals. The average age of onset of major depression is in the mid-20s, but the first episode may occur at any age. The disease course is highly variable, and generally the number of previous episodes predicts the likelihood of having another episode. For example, 50 to 60 percent of patients with a first episode of depression will have a second episode, and those with two episodes have a 70 percent chance of having a third. After the third episode, the chance of having a fourth is 90 percent.^5^ Data for over 15,000 employees of a major U.S. corporation showed that depressive illness was associated with a mean of 9.86 annual sick days, significantly more than any of the other medical conditions examined.^6^ In a naturalistic study of followup of depression (in which treatment was not controlled by the investigators), 20 percent of patients continued to show no evidence of achieving remission, 40 percent showed partial remission, and 40 percent had no evidence of mood disorder at the end of 1 year.^7^ In the recently completed STAR*D trial, the response rate (rate of improvement in symptoms) was 47 percent and the remission rate (rate of substantial improvement, with only minimal residual symptoms) only 33 percent after 14 weeks of treatment with a selective serotonin reuptake inhibitor (SSRI).^8^ The high rate of non-response in MDD is one of the biggest challenges in psychiatry as it impacts disease burden.

## Selective Serotonin Reuptake Inhibitors (SSRIs) in the Treatment of MDD

The advent of the SSRI class of drugs has dramatically changed the landscape of depression treatment. SSRIs have quickly superseded the older tricyclic antidepressants to become first-line drugs in the treatment of depression. The SSRIs currently available on the market include fluoxetine, paroxetine, fluvoxamine, sertraline, citalopram, and escitalopram. Of the top 25 prescription drugs in the U.S. in 2004, two were SSRIs: Zoloft^®^ (sertraline), with over 29 million prescriptions, and Lexapro^®^ (escitalopram), with over 22 million prescriptions.^9^ Of the SSRIs, fluoxetine and (more recently) citalopram are available in generic forms. Fluoxetine is the only SSRI with an active metabolite (in the form of norfluoxetine) that is more potent in serotonin reuptake inhibition than the parent compound and which is thought to play a significant role in therapeutic effect.^10^ Moreover, fluoxetine is a racemic mixture of S- and R-fluoxetine, with both enantiomers being approximately equipotent in serotonin reuptake inhibition. However, of the enantiomers of their respective metabolites, S-norfluoxetine has significant serotonin reuptake inhibition and is 20 times more potent than R-norfluoxetine.^11^

The popularity of SSRI drugs has been attributed to their better tolerability and relative safety in overdose, which is an important consideration when treating depressed patients who may become suicidal. However, SSRIs are not without drawbacks. In addition to the high rates of non-response described above, another limitation of SSRI treatment of depression is the time to response, with most SSRIs starting to show benefit only after 2 to 4 weeks of adequate dosing. In the STAR*D trial, the majority of patients who achieved response or remission did so after 8 weeks of SSRI treatment.^8^ In addition, even this class of drugs is associated with intolerable adverse effects (such as nausea, diarrhea, or headaches) necessitating discontinuation of treatment in 12 to 15 percent of patients in short-term studies.^12,^ ^13^ Because of variable efficacy and tolerability among patients, the SSRIs are generally titrated by trial and error, potentially further lengthening the time to response. Additionally, when a drug is discontinued as a result of intolerability, it can result in a “lost opportunity” to treat a condition such as depression that is associated with stigma.

### Therapeutic Drug Monitoring in SSRI Treatment

In general, no clear relationship has been found between blood concentration and clinical response with SSRIs at usual doses, nor has any threshold been identified that defines toxic concentrations. Citalopram showed no significant correlation between steady-state plasma concentration and final Montgomery-Åsberg Depression Rating Scale (MADRS) scores (measure of response) in two studies, with numbers of patients ranging from 13 to 16, and doses ranging from 5 to 60 mg/d.^14,^ ^15^ Paroxetine studies have found no statistically significant differences in plasma levels of paroxetine between responders and non-responders.^16^ No correlation has been found between Hamilton Rating Scale for Depression (HAM-D) scores (measure of response) and plasma levels of paroxetine. Studies had numbers of subjects ranging from 16 to 44, and doses from 20 to 60 mg/day.^17^–^19^ Similarly, studies of fluoxetine with small numbers of patients have suggested either no relationship between plasma concentration of the drug and clinical response,^20,^ ^21^ or have suggested a curvilinear relationship between clinical response and plasma concentrations.^22^–^24^ The limitation of most of these studies is that they may not have been adequately powered. Perhaps the biggest study of plasma concentration and response has been of fluoxetine,^25^ a multicenter study in which plasma concentrations were available for 615 patients receiving 20 mg/day of fluoxetine. No apparent relationship was observed between plasma concentration and drug response, and plasma concentrations of fluoxetine, norfluoxetine, active moiety, or fluoxetine/norfluoxetine ratio did not differ between responders and non-responders. This is probably the only study with adequate power to be meaningful. However, one limitation of this study was the fact that it was a fixed dose study of fluoxetine at 20 mg/day, raising the possibility that a dose-response relationship could exist at higher doses, or a threshold effect may be possible at lower doses.

Adverse effects of SSRIs, although not generally life-threatening, are typically dose-related. Therapeutic drug monitoring is not routinely recommended for SSRI treatment, but is thought to be of value for ascertaining compliance, for patients who do not respond to multiple SSRIs, or have poor tolerability.^26^

## Cytochrome P450 Enzyme System

The cytochrome P450 (CYP450) enzymes are members of an isoenzyme superfamily that catalyzes the oxidation of many drugs and chemicals. These enzymes are variably distributed in tissues, but are mainly present in the liver, which is the site of first phase metabolism for many drugs. Genetic polymorphisms have been identified for some of the CYP450 enzyme genes that alter enzyme activity, with inactivating alleles that markedly decrease or eliminate enzyme activity (the latter also called deficient activity). Individuals carrying combinations of decreased activity alleles are referred to as intermediate metabolizers (IMs), while individuals homozygous or compound heterozygous for the deficiency alleles are defined as poor metabolizers (PMs), reflecting the extent of decrease in activity. Alleles carrying multiple copies of functional genes, on the other hand, lead to increased enzyme activity, with individuals expressing these alleles termed ultra-rapid metabolizers (UMs). Phenotypically, this may translate into differing rates of metabolism of drugs with potential for toxicity or lack of efficacy. Table 1 outlines how function-altering genetic polymorphisms in CYP450 enzymes may affect drug metabolism. Note that for a “prodrug,” which is converted into its active form only after metabolism by CYP2D6, the drug effects will be in the opposite direction, e.g., PMs will show lower than expected efficacy due to lower than expected levels of active metabolite. Thus, Table 1 assumes that the metabolite resulting from the CYP metabolism is less active or inactive in comparison with the parent drug. Additionally, Table 1 applies only to those drugs where the CYP enzyme is the primary route by which the drug is metabolized.

Table 1 Effects of genetic polymorphisms of CYP enzyme genes on drug metabolism

Metabolizer status | Genotype | Expected drug effects
UM (ultra-rapid) | More than two copies of active enzyme gene alleles | Usual doses may not lead to therapeutic drug concentration, possible non-response
EM (extensive) | Two copies of active enzyme gene alleles | Usual doses lead to expected drug concentrations and response
IM (intermediate) | Homozygous for two reduced activity enzyme gene alleles or are heterozygous for an inactive allele and a reduced activity allele | Drug effects between those of EMs and PMs
PM (poor) | Homozygous or compound heterozygous for deficiency alleles | Usual doses may lead to higher than expected drug concentrations and possibly adverse reactions

Abbreviations: EM(s) = extensive metabolizer(s); IM = intermediate metabolizer; PM(s) = poor metabolizer(s); UM = ultra-rapid metabolizer

There are racial differences in function-altering polymorphisms. For example, approximately seven percent of Caucasians are CYP2D6 PMs, whereas only one to two percent of Asians and two to four percent of African-Americans are PMs.^27^ In contrast, 10 percent of southern Europeans have duplication of the CYP2D6 gene, which is associated with the ultra-rapid phenotype. There are sizeable data regarding specific CYP variants and their predicted enzymatic function. Much of these data are based on how a particular variant affects metabolism of a “probe drug.” A probe drug for a given CYP enzyme is a drug that is exclusively metabolized by that CYP enzyme (e.g., dextromethorphan by CYP2D6), is non-toxic, and can be easily measured in serum or urine. Metabolism of the probe drug is used for phenotyping CYP enzymes, but the process is time-consuming and can be influenced by concurrent medications or diet. Table 2 provides examples of allele frequencies of CYP enzyme variants in different ethnic groups.

Table 2 Allele frequencies of CYP2D6 variants in selected populations

CYP2D6 variant | Predicted enzymatic function | Caucasian (Europe)^27^ | Caucasian (U.S.)^27^ | African-American^27^ | Swedish^28^
*1 | Normal | 33–36% | 27–40% | 29–35% | 36.7%
*2 (35%) | Normal | 22–33% | 26–34% | 18–27% | 32.4%
*3 | Deficient | 1–4% | 1–1.4% | < 1% | 1.4%
*4 | Deficient | 12–23% | 18–23% | 6–9% | 24.4%
*5 | Deficient | 2–7% | 2–4% | 6–7% | 4.3%
*6 | Deficient | 1–1.4% | 1% | < 1% | 0.9%
*9 | Decreased activity | 0–2.6% | 2–3% | < 1% | -
*10 | Decreased activity | 1.4–2% | 2–8% | 3–8% | -
*17 | Decreased activity | < 1% | < 1% | 15–26% | -
*41 | Decreased activity | 20% | - | - | -
*1×N | Increased activity | < 1% | < 1% | 1.3% | -
*2×N | Increased activity | 1.5% | < 1% | 1.3% | -
*4×N | Deficient | < 1% | < 1% | 2.3% | -

The CYP450 enzymes - primarily CYP2D6, CYP2C19, and CYP2C9 - are involved in the metabolism of all of the SSRIs.^29^ It is important to note that enzymes other than CYP are also involved in SSRI metabolism,^30,^ ^31^ and for a given SSRI, more than one CYP enzyme may be involved in its metabolism.^32,^ ^33^ Additionally, it is noteworthy that CYP2D6 with identical pharmacologic and molecular properties has been identified in microsomal fractions in the brain. Hence, CYP2D6 may potentially contribute to local clearance of psychotropics at the site of action. Differences in personality traits between extensive metabolizers (EMs) and PMs were noted in both Swedish and Spanish healthy white subjects, also suggesting that there may be an endogenous substrate for CYP2D6 in the brain.^34^

Another key issue in terms of clinical practice is the incidence of drug interactions. Several SSRIs are potent inhibitors of some CYP450 enzymes; for example, 2D6 is substantially inhibited by fluoxetine and paroxetine. Not all SSRIs inhibit all CYP enzymes equally. Table 3 provides information about extent of inhibition of CYP enzymes by individual SSRIs.

Table 3 SSRI inhibition of CYP enzymes*

CYP enzyme | Citalopram | Fluoxetine | Fluvoxamine | Paroxetine | Sertraline
CYP1A2 | +/- | + | +++ | + | +/-
CYP2C9/10 | ? | ? | ? | ? | +
CYP2C19 | ? | ++ | +++ | | +
CYP2D6 | + | +++ | + | +++ | +
CYP3A4 | ? | ++ | ++ | +/- | +/-

* Table 3 adapted with permission from Harvey and Preskorn, 1996.^35^ Additional information derived from Gram et al., 1993;^36^ Skjelbo and Brosen, 1992; ^37^ and Rasmussen et al., 1995.^38^

Key to symbols: +/- = unlikely; ? = unknown; + = mild; ++ = moderate; +++ = substantial

SSRI inhibition of a CYP enzyme can raise serum concentrations of drugs metabolized by that enzyme. Because SSRIs are commonly prescribed to patients with medical comorbidities who may be on multiple other medications, CYP polymorphisms may increase the likelihood or severity of such drug-drug interactions.

Currently there are no well-defined strategies regarding SSRI selection in individual patients, and this may contribute to low efficacy and an increased risk of side effects. Knowledge about CYP polymorphisms could potentially aid the selection of a specific SSRI and/or guide decisions about appropriate dosing to optimize efficacy and tolerability for individual patients.

## Genetic Testing for Key CYP450 Polymorphisms

Several companies offer genetic testing for CYP450 polymorphisms using different test formats. These have mainly supported clinical trials and to a smaller extent patient management. The Blue Cross and Blue Shield Association Technology Evaluation Center report on CYP450 genotyping^39^ offers the most current compilation of such tests. Additionally, laboratories may develop and validate their own tests for CYP450 genotyping that are required to meet Clinical Laboratory Improvement Amendment (CLIA) standards. A significant recent development was the approval by the U.S. Food and Drug Administration (FDA) of the Roche AmpliChip^®^ CYP450 Test for this purpose.^40,^ ^41^ The AmpliChip^®^ delivers the results of testing for CYP2D6 and CYP2C19 polymorphisms in the form of “predicted phenotypes,” classifying test subjects as PMs, IMs, EMs, or UMs. There are currently no guidelines regarding how testing for polymorphisms, and the knowledge such testing yields about predicted phenotypes, can be incorporated into clinical practice, and little information about whether such testing produces any real benefits at all.

## Utility of CYP Genotyping in Treatment of MDD With SSRIs

There has been increasing interest in the role of genetic polymorphisms of CYP450 enzymes and metabolism of SSRIs in relation to clinical practice.^29,^ ^42,^ ^43^ The availability of an FDA-approved test for identifying CYP450 polymorphisms has brought the field of pharmacogenetics to the threshold of influencing clinical practice, as advertising in leading journals exposes physicians to the availability of tests. Given the prevalence of MDD and the prevalence of SSRI treatment of MDD, there is an urgent need to critically review the available literature using standard methods of evidence-based medicine to inform the future use of genetic testing in the treatment of MDD with SSRIs, as well as to guide research priorities in service to optimal patient care.

The Agency for Healthcare Research and Quality (AHRQ), on behalf of the Centers for Disease Control and Prevention (CDC) Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Project, requested the development of the present evidence report on “Testing for Cytochrome P450 Polymorphisms in Adults with Non-Psychotic Depression Treated with Selective Serotonin Reuptake Inhibitors (SSRIs).” The report will be used to inform the EGAPP Working Group's deliberations in a process similar to that used by the U.S. Preventive Services Task Force (USPSTF) to formulate evidence-based recommendations.

A team of investigators at the Duke Evidence-based Practice Center, comprised of experienced investigators in health policy, psychiatry, and pharmacogenetics, have developed the report. The approach included developing an analytic framework concerning testing for CYP450 polymorphisms and treatment related to depression and performing a comprehensive literature review linked to this framework. The report provides a clear view of the current state of the science in CYP450 polymorphism testing in depression, and - where research is now insufficient for policy decisionmaking - proposes a list of rational research priorities. Further, the report provides a framework for evaluating the general issue of genetic testing for decisionmaking in depression treatment.