# Appendix F. Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

Shashi Amur, Ph.D., Senior Staff Fellow, Genomics Group, Office of Clinical Pharmacology and Biopharmaceutics, Center for Drug Evaluation and Research (CDER), U.S. Food and Drug Administration (FDA), Rockville, Maryland

Dan Blazer, M.D., Ph.D., JP Gibbons Professor, Department of Psychiatry, Duke University Medical Center, Durham, North Carolina

Linda Bradley, Ph.D., Geneticist, Office of Genomics and Disease Prevention, Centers for Disease Control and Prevention (CDC), Atlanta, Georgia

Wylie Burke, M.D., Ph.D., Professor and Chair, Department of Medical History and Ethics, University of Washington, Seattle, Washington

Stephen Crystal, Ph.D., Institute for Health, Health Care Policy and Aging Research, Research Professor, School of Social Work, Rutgers, State University of New Jersey, New Brunswick, New Jersey

Julia Kirchheiner, M.D., Professor of Clinical Pharmacology, Department of Pharmacology of Natural Products and Clinical Pharmacology, University of Ulm, Ulm, Germany

William Lawrence, M.D., M.S., Center for Outcomes and Evidence, Agency for Healthcare Research and Quality (AHRQ), Rockville, Maryland

Dennis J. O'Kane, Ph.D., FACB, Department of Lab Medicine and Pathology, Mayo Clinic, Rochester, Minnesota

Kathryn Phillips, Ph.D., Professor of Health Economics and Health Services Research, School of Pharmacy, Institute for Health Policy Studies and ECSF Comprehensive Cancer Center, University of California SF, San Francisco, California

Margaret Piper, Ph.D., M.P.H., Associate Director, Blue Cross/Blue Shield Association, Technology Evaluation Center, Atlanta, Georgia

Gurvaneet Randhawa, M.D., M.P.H., Center for Outcomes and Evidence, Agency for Healthcare Research and Quality (AHRQ), Rockville, Maryland

Matthew Rudorfer, M.D., Assistant Chief, Division of Services and Intervention Research, National Institute of Mental Health, Bethesda, Maryland

Stephen Stahl, M.D., Ph.D., Chair, Neuroscience Education Institute, Adjunct Professor of Psychiatry, University of California SD, San Diego, California

Combined comments from the Evaluation of Genomics Applications in Practice and Prevention (EGAPP)/Centers for Disease Control and Prevention (CDC) Discussion Group

Comments from the Editorial Staff of the Agency for Healthcare Research and Quality (AHRQ), Rockville, Maryland

Comments from the National Institute of General Medical Sciences (NIGMS)/National Institutes of Health (NIH) Discussion Group

Nominations for peer reviewers were solicited from several sources, including the project's technical expert panel and interested federal agencies. The list of nominees was vetted and approved by the Agency for Healthcare Research and Quality (AHRQ).