# Appendix E. Quality Assessment Tools

## ACCE Model for Evaluation of Genetic Testing^1^ 1 Available at: www.cdc.gov/genomics/gtesting/ACCE.htm. Accessed September 11, 2006. (used for Question 2)

## Oxford Centre for Evidence-based Medicine Levels of Evidence^2^ 2 Available at http://www.cebm.net/levels_of_evidence.asp. Accessed September 11, 2006. (used for all remaining questions)