# Appendix D. Evidence Tables

Evidence Table 1. Question 2: What is the analytic validity of tests that identify key CYP450 polymorphisms?^1^

Study | Study Design | Patient Characteristics | Results | | | | | | Quality Assessment/Comments
Roche Molecular Systems, Inc., 2004 | Geographical location: Not reported | Race/ethnicity: Not reported | Summary of test performance: | | | | | | Quality assessment:
#11890 | Size of population: 246 (compared with sequencing) and 403 (compared with PCR-RFLP) for CYP2D6 analysis; 123 (compared with sequencing) and 798 (compared with PCR-RFLP) for CYP2C19 genotyping | | Note: Comparisons of genotype calls as compared to the gold standard of sequencing are presented in Tables 6and 7of the report. | | | | | | 1) How often is the test positive when a polymorphism is present?
and | Method of CYP testing or product used: AmpliChip CYP450 microarray | | 2D6 allele | Number of alleles sequenced | Amplichip CYP450 test results | | | Percent agreement | CYP2D6 = 99.22%;
Roche Molecular Systems, Inc., 2005 | Cytochromes (and specific mutations) tested for: CYP2D6 *1, *2, *3, *4, *5, *6, *9, *10, *15, *17, *29, *35, *36, *40, *41, *1×N, *2×N, *4×N, *10×N, *17×N, *35×N, *41×N | | | | Correct calls | Miscalls | No calls | | CYP2C19 = 100%
#13610 | CYP2C19 *1, *2, *3 | | *1 | 103 | 102 | 0 | 1 | 99 | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: Bidirectional DNA sequencing, allele specific amplification (ASA) and PCR-RFLP | | *2 | 64 | 63 | 0 | 1 | 98.4 | CYP2D6 = 99.02%;
| | | *3 | 14 | 14 | 0 | 0 | 100 | CYP2C19 = 99.6%
| | | *4 | 73 | 73 | 0 | 0 | 100 | *2/*10 was identified as *2/*2 by both PCR-RFLP and AmpliChip (both alleles predict poor metabolizer status)
| | | *5 | 26 | 26 | 0 | 0 | 100 | 3) Is an internal QC program defined and externally monitored?
| | | *6 | 8 | 8 | 0 | 0 | 100 | - A 7-member panel for CYP2D6 testing ang 6-member panel for CYP2C19 testing was constructed from cell lines representing all known alleles were repeatedly tested at multiple sites; - Comparison to PCR-RFLP and sequencing; - Some alleles (CYP2D6 *7, *8, *11, *19, *20) were analytically validated using imitation samples; - Some alleles were tested only on one or few samples (CYP2D6 *15, *36, *40, *17×N, *35×N, *41×N)
| | | *9 | 9 | 9 | 0 | 0 | 100 | 4) Have repeated measurements been made on specimens?
| | | *10 | 40 | 40 | 0 | 0 | 100 | Yes, in triplicates for 5 runs at each site
| | | *15 | 1 | 1 | 0 | 0 | 100 | 5) What is the within- and between-laboratory precision?
| | | *17 | 28 | 28 | 0 | 0 | 100 | CYP2D6 = 941/944 correctly called = 99.7%;
| | | *29 | 12 | 12 | 0 | 0 | 100 | CYP2C19 = 806/809 correctly called = 99.6%
| | | *35 | 32 | 32 | 0 | 0 | 100 | 6) How often does the test fail to give a useable result?
| | | *36 | 2 | 2 | 0 | 0 | 100 | Never
| | | *40 | 2 | 2 | 0 | 0 | 100 | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | *41 | 71 | 71 | 0 | 0 | 100 | Inter-laboratory variability was assessed as part of a reproducibility score by comparing genotype calls between three sites.
| | | *1×N | 1 | 0 | 0 | 1 | 0 | Comments:; - Allele frequency data cannot be compared to published findings due to lack of ethnicity information on tested samples; - Commercial laboratory
| | | *2×N | 1 | 0 | 0 | 1 | 0
| | | *4×N | 1 | 1 | 0 | 0 | 100
| | | *10×N | 1 | 1 | 0 | 0 | 100
| | | *17×N | 1 | 1 | 0 | 0 | 100
| | | *35×N | 1 | 1 | 0 | 0 | 100
| | | *41×N | 1 | 1 | 0 | 0 | 100
| | | Total | 492 | 488 | 0 | 4 | 99.2
| | | 2C19 allele | Number of alleles sequenced | Amplichip CYP450 test results | | | Percent agreement
| | | | | Correct calls | Miscalls | No calls
| | | *1 | 153 | 153 | 0 | 0 | 100
| | | *2 | 79 | 78 | 1 | 0 | 98.7
| | | *3 | 14 | 0 | 0 | 0 | 100
| | | Total | 246 | 245 | 1 | 0 | 99.6
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness
| | | AmpliChip vs. sequencing | CYP2D6 | | Reproducibility 7 samples (7 genotypes) × 3 sites × triplicates × 5 runs × 3 lots of reagents, correct genotype calls = 940/944 (99.6%; 98.9–99.8)
| | | | *2,*3,*4,*5,*6,*9,*10*,*15,*17,*29,*35,*36,*40,*41,*1×N,*2×N, *4×N,*10×N, *17×N, *35×N, *41×N
| | | | 291/293 | 99.3% [97.5–99.8]
| | | | *1
| | | | 102/103 | 99% [94.7–99.8]
| | | AmpliChip vs. PCR-RFLP/ASA/PCR size^^^ | CYP2D6 *2,*3,*4,*5,*6,*9,*10,*15,*17,*29,*35,*36,*40,*41,*1×N, *2×N, *4×N, *10×N, *17×N, *35×N, *41×N
| | | | 583/588 | 99.2% [98–99.6]
| | | | *1
| | | | 217/218 | 99.5% [97.4–99.9]
| | | AmpliChip vs. sequencing | CYP2C19 | | Reproducibility 6 samples (3 genotypes) × 3 sites × triplicates × 5 runs × 3 lots of reagents, correct genotype calls = 806/809 (99.6%; 98.9–99.9)
| | | | *2,*3
| | | | 92/93 | 98.9% [94.2–99.8]
| | | | *1
| | | | 153/153 | 100% [97.6–100]
| | | AmpliChip vs. PCR-RFLP/ASA/PCR size^^^ | CYP2C19
| | | | *2,*3
| | | | 57/58 | 100% [97.5–100]
| | | | *1
| | | | 494/494 | 100% [99.4–100]
Chou, Yan, Robbins-Weilert, et al., 2003 | Geographical location: USA | Race/ethnicity: Caucasian 87.3% | Summary of test performance: | | | | | | 1) How often is the test positive when a polymorphism is present?
#15370 | Size of population: 232 | African-American 5.5% | CYP 2D6 genotype | No. of individuals sequenced | Method comparisonNumber of individuals genotyped | | Total allele counts | | 100%.
| Method of CYP testing or product used: CYP450 GeneChip® (previous version of AmpliChip®) | Hispanic 1.7% | | | AmpliChip | ASA | | | 2) How often is the test negative when a polymorphism is not present?
| Cytochromes (and specific mutations) tested for: CYP2D6 *3, *4, *6, *7 and *9 | Asian 1.2% | NR^*^ | | | | *3 | 4/4 | 100%.
| Reference standard test: Allele-specific amplification (ASA) | Multiracial 2.5% | | | | | *4 | 94/94 | 3) Is an internal QC program defined and externally monitored?
| | | | | | | *6 | 4/4 | - Each genotyping method was performed in a different laboratory.; - Insufficient yields of the longer PCR products in the GeneChip multiplex PCR reaction were routinely used in smaller volumes of DNA or re-extracted using Qiagen Blood Amp Kit.; - All discrepancies between the two genotyping methods were addressed by 2 additional repeats of AS-PCR tests.
| | | | | | | *7 | 0/0 | 4) Have repeated measurements been made on specimens?
| | | | | | | *9 | 10/10 | Only when discrepancies between the two methods were discovered.
| | | Results of genotype counts validated and compared to the ASA method reference are not provided. | | | | | | 5) What is the within- and between-laboratory precision?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | The intra-assay precision was tested only for 2 samples with *41/*1 genotype, which showed 100% precision.
| | | GeneChip vs. ASA | CYP2D6 | | Pre-analytic robustness: genotyping success sensitive to DNA quality ~20% of cases | | | 6) How often does the test fail to give a useable result?
| | | | *3,*4,*6,*7,*9 | | | | | - 4/236 (1.7%) samples did not achieve desirable quality/quantity of DNA or could not give unambiguous genotype; - The method is very sensitive to DNA quality and ~20% of samples failed to yield sufficient amounts of the longer PCR products in the first attempt.
| | | | | | Inter-assay reproducibility (2 samples × 2) = 100% [34.2–100] | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | 112/112 | 100% [96.7–100] | | | | Allele frequencies obtained by both methods (n = 464) are not reported by ethnicity, although the study population was heterogeneous. Allele frequencies are reported for Caucasians only (n = 412), but this report is based on a total of 472 alleles (including 4 additional individuals genotyped only by the GeneChip, and of unknown ethnicity).
| | | | *1 | | | | | Comments:This version of the AmpliChip includes a smaller set of alleles tested, a less developed software for distinguishing between signals of duplicated alleles and single copy alleles and better controlled sensitivity to the different length of PCR products multiplexed in the reaction. The current version of the kit incorporates positive and negative controls, which were not reported in this article
| | | | NR | NR
Hersberger, Marti-Jaun, Rentsch, et al., 2000 | Geographical location: Switzerland | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
| Size of population: 57 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
#5290 | Method of CYP testing or product used: 3 single tube tetraprimer PCR assays for allele specific amplification (ASA) | | | | ASA (repeated tests) | PCR-RFLP | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP2D6 *3, *4, *6 | | *3/*1 | 3 | 3 (× 7) | | Sequencing: | | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: PCR-RFLP | | | 2 | | | *3 | 3/3 | 100%.
| | | *1/*1 | | 2 (× 7) | | *1 | 7/7 | 3) Is an internal QC program defined and externally monitored?
| | | | | 57 | 57 | PCR-RFLP: | | Known *3, *4, *6 genotypes by sequencing were reanalyzed multiple times as controls for the samples analyzed.
| | | | | | | *1 | 114/114 | 4) Have repeated measurements been made on specimens?
| | | *4/*1 | 4 | 4 (× 11) | | Sequencing: | | 7–11 repeats of control DNAs were made to ensure reproducibility of results in comparison to sequencing results.
| | | | | 26 | 26 | *4 | 8/8 | 5) What is the within- and between-laboratory precision?
| | | *4/*4 | 2 | 2 (× 11) | | *1 | 8/8 | Not reported.
| | | | | 3 | 3 | PCR-RFLP: | | 6) How often does the test fail to give a useable result?
| | | *1/*1 | 2 | 2 (× 11) | | *4 | 32/32 | Never.
| | | | | 28 | 28 | *1 | 82/82 | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | *6/*1 | 2 | 2 (× 9) | | Sequencing: | | Allele frequencies are comparable to published data in Caucasian populations
| | | | 1 | 1 | | *6 | 3/3 | Comments:; - The 4 mutations tested predict 93–94.5% of poor metabolizers in Caucasians
| | | *1/*1 | 4 | 4 (× 9) | | *1 | 11/11
| | | | | 56 | 56 | PCR-RFLP:
| | | | | | | *1 | 112/112
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness
| | | ASA vs. sequencing | CYP2D6 | | Inter-assay reproducibility:
| | | | *4,*6
| | | | 14/14 | 100% [78.5–100] | *3 (3 samples × 7) = 100% (implied)
| | | | *1
| | | | 26/26 | 100% [87.1–100]
| | | ASA vs. PCR-RFLP | CYP2D6 | | *4 (4 samples × 11) = 100% (implied)
| | | | *4
| | | | 32/32 | 100% [89.3–100]
| | | | *1 | | *6 (2 samples × 9) = 100% (implied)
| | | | 308/308 | 100% [98.8–100]
Muller, Zopf, Bachofer, et al., 2003 | Geographical location: Germany | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#11710 | Size of population: 105 - deletion, duplication | Population included volunteers and patients (59 of whom were depressive inpatients) | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| 116 - preamplification | | | | RT-PCR (repeated tests) | PCR-RFLP | | | 100%.
| Method of CYP testing or product used: Real-Time (RT) long PCR | | *35/*1 | | 14 | 14 | PCR-RFLP: | | 2) How often is the test negative when a polymorphism is not present?
| Cytochromes (and specific mutations) tested for: CYP2D6 *2, *41^%^, *4, *5, *2, *35, *1×N | | *35/*35 | | 3 | 3 | *35 | 20/20 | 100%.
| Reference standard test: Long range and multiplex PCR, as well as PCR-RFLP | | | | | | *1 | 206/206 | 3) Is an internal QC program defined and externally monitored?
| | | *1/*1 | | 101 | 101 | Multiplex PCR^*^: | | Not reported.
| | | | | | | *2G^%^ | 14/14 | 4) Have repeated measurements been made on specimens?
| | | | | | | *2C^%^ | 30/30 | Yes, different investigators repeatedly analyzed the same samples.
| | | | | | | *4 | 19/19 | 5) What is the within- and between-laboratory precision?
| | | | | | | *5 | 1/1 | Not reported.
| | | | | | | *1×N | 1/1 | 6) How often does the test fail to give a useable result?
| | | | | | | *1 | 53/53 | Never.
| | | Notes: Genotype counts for method comparison to multiplex PCR are not reported. % *2G refers to *41, while *2C is common to both the EM *2 allele and the IM *41 allele | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | Allele frequencies are reported for depressive patients only (not comparable to healthy individual know frequencies).
| | | | | | | | | Comments:; - Actual numbers with polymorphisms not reported
| | | RT-PCR vs. PCR-RFLP | CYP2D6
| | | | *35
| | | | 20/20 | 100% [83.9–100]
| | | | *1
| | | | 206/206 | 100% [98.2–100]
| | | RT-PCR vs. multiplex PCR | CYP2D6
| | | | *2G^%^,
| | | | *2C^%^,
| | | | *4,*5,*1×N
| | | | 65/65 | 100% [94.43–100]
| | | | *1
| | | | 53/53 | 100% [93.2–100]
Eriksson, Berg, Wadelius, et al., 2002 | Geographical location: Sweden | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#4820 | Size of population: 2D6: 117 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| 2C9: 28 | | | | Pyrosequencing (repeated tests) | PCR-RFLP | | | Genotypes tested by PCR-RFLP showed 100% sensitivity (CYP2D6 *3, *4, CYP2C9 *2, *3, CYP2C19 *2, *3 and *4).
| 2C19: 138 | | *3/*1 | | 1 | 1 | *3 | 6/6 | 2) How often is the test negative when a polymorphism is not present?
| Method of CYP testing or product used: Multiplex pyrosequencing assay | | *3/*3 | | | | *4 | 42/42 | Genotypes tested by PCR-RFLP showed 100% specificity (CYP2D6 *3, *4, CYP2C9 *2, *3, CYP2C19 *2, *3, and *4).
| Cytochromes (and specific mutations) tested for: CYP2D6 *3, *4 | | | | 1 | 1 | *1 | 78/78 | 3) Is an internal QC program defined and externally monitored?
| CYP2C9 *2, *3 | | *3/*4 | | 3 | 3 | | | Confirmatory data obtained from surrounding sequence as internal control.
| 2C19 *2, *4 | | *4/*1 | | 29 | 29 | | | 4) Have repeated measurements been made on specimens?
| Reference standard test: PCR- RFLP | | *4/*4 | | 5 | 5 | | | Not reported.
| | | *1/*1 | | 24 | 24 | | | 5) What is the within- and between-laboratory precision?
| | | CYP 2C9 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | Not reported.
| | | | | Pyrosequencing (repeated tests) | PCR-RFLP | | | 6) How often does the test fail to give a useable result?
| | | *2/×^%^ | | 14 | 14 | *2 | 14/14 | Not reported.
| | | *3/×^%^ | | 10 | 10 | *3 | 10/10 | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | *1/*1 | | 9 | 9 | *1 | NR^%^ | Allele frequencies are comparable to published data in Caucasian populations.
| | | CYP 2C19 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | Comments: None
| | | | | Pyrosequencing (repeated tests) | PCR-RFLP
| | | *2/*1 | | 24 | 24 | *2 | 34/34
| | | *2/*2 | | 5 | 5 | *4 | 1/1
| | | *4/*1 | | 1 | 1 | *1 | 241/241
| | | *1/*1 | | 108 | 108
| | | Note: % genotype results state some individuals were compound heterozygotes, but no counts are provided
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness
| | | Pyrosequencing vs. PCR-RFLP | CYP2D6
| | | | *3,*4
| | | | 48/48 | 100% [92.6–100]
| | | | *1
| | | | 186/186 | 100% [98–100]
| | | | CYP2C9
| | | | *2,*3
| | | | 24/24 | 100% [86.2–100]
| | | | *1
| | | | NR | NR
| | | | CYP2C19
| | | | *2,*4
| | | | 35/35 | 100% [90.1–100]
| | | | *1
| | | | 241/241 | 100% [98.4–100]
Stamer, Bayerer, Wolf, et al., 2002 | Geographical location: Germany | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#4890 | Size of population: 323 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present (sensitivity)?
| Method of CYP testing or product used: Real Time (RT) PCR, melting profiles | | | | RT-PCR (repeated tests) | ASA | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP2D6 *3, *4, *5, *6, *7, *8 | | *5/*1 | | 1 | 1 | *3 | 6/6 | 2) How often is the test negative when a polymorphism is not present (specificity)?
| Reference standard test: Allele-specific multiplex PCR (ASA), sequencing | | *5/*5 | | 11 | 11 | *4 | 120/120 | 100%.
| | | *5/*6 | | 1 | 1 | *5 | 17/17 | 3) Is an internal QC program defined and externally monitored?
| | | | | | | *6 | 20/20 | - Positive controls for each genotype were integrated into the genotyping process.; - Uncertain results obtained with allele-specific multiplex PCR and positive controls were sequenced bidirectionally to confirm real-time PCR findings.
| | | | | | | *7 | 0/0 | 4) Have repeated measurements been made on specimens?
| | | | | | | *8 | 1/1 | Yes (3 times).
| | | | | | | *1 | 478/478 | 5) What is the within- and between-laboratory precision?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | Same results with 3 different investigators in the same lab.
| | | RT-PCR vs. ASA | CYP2D6 | | Deviation from expected sequence =4/323 (1.2%; 0.5–3.1) | | | 6) How often does the test fail to give a useable result?
| | | | *3,*4,*5,*6,*8 | | | | | Never.
| | | | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | 164/164 | 100% [97.8–100] | Inter-assay reproducibility (3 investigators): 100% | | | Frequencies comparable to expected results in Caucasians
| | | | *1 | | | | | Comments:; - 4 samples showed abnormal melting profiles indicating the presence of a mutation other than the expected ones. These findings were confirmed by sequencing, as *28, C1776T and G3027A
| | | | 478/478 | 100% [99.2–100]
Schaeffeler, Schwab, Eichelbaum, et al., 2003 | Geographical location: Germany | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#4590 | Size of population: 64 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Real-time (RT) PCR Quantification of 2D6 gene copies in relation to albumin as internal reference gene | | | | RT-PCR (repeated tests) | Long range PCR | | | 100%.
| Cytochromes (and specific mutations) tested for: 2D6 gene copy number | | Del/Del | | 1 (× 2) | 1 | Deletion (Del) 14/18 | | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: Long-range PCR | | Del/SC | | 13 | 13 | | | 73.1%. TaqMan gene quantification gives unambiguous results for homozygotes with a gene count of 1. If 2 genes are present, 2 constellations are possible: one with two single-gene alleles on 2 chromosomes, and one in which a duplicated allele is combined with a deletion allele on the other chromosome. Functionally, both alternatives yield similar activity profiles, thus clinically this specificity issue should not be of relevance.
| | | Dup/SC | | 5 | 5 | Duplication (Dup) 5/8 | | 3) Is an internal QC program defined and externally monitored?
| | | Dup/Del | | 0 | 1 | | | - CYP2D6*5/*5 DNA was used as an authentic genomic control.; - 5 known *1, *2, *3 copies analyzed in duplicates.
| | | SC/SC | | 43 | 43 | Single copy (SC)100/102 | | 4) Have repeated measurements been made on specimens?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | 12 measurements, coefficient of variation reported to be between 7% and 13%.
| | | RT-PCR vs. Long range PCR | CYP2D6 | | Intra-assay coefficient of variance (12 samples × 2) = 7–13% | | | 5) What is the within- and between-laboratory precision?
| | | | Del,Dup | | | | | Inter-assay variability of 8 samples on 3 different days: coefficient of variation 9% to 26%.
| | | | 19/26 | 73.1% [54–86.3] | | | | 6) How often does the test fail to give a useable result?
| | | | SC | | | | | Never.
| | | | 100/102 | 98% [93.1–99.4] | Inter-assay coefficient of variance (8 samples × 3) = 9–26% | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | The sample was not random, population-based, but rather it was enriched with individuals with low sparteine metabolic ratios. Allele frequencies thus do not necessarily reflect findings in comparable healthy populations.
| | | | | | | | | Comments: None
Soderback, Zackrisson, Lindblom, et al., 2005 | Geographical location: Sweden | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#4180 | Size of population: 270 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Pyrosequencing | | | | [underlined: Pyrosequencing (repeated tests)] | Long range PCR | | | 1×D6: 23/24 = 96%.
| Cytochromes (and specific mutations) tested for: 2D6*5 deletion and *2×N duplication variants. | | Del/SC | | 23 | 24 | Deletion (Del) 23/24 | | 3×D6: 13/13 = 100%.
| Reference standard test:Long-range PCR | | Dup/SC | | 13 | 13 | Duplication (Dup) 13/13 | | 2) How often is the test negative when a polymorphism is not present?
| | | SC/SC | | 3 (× 2) | 3 | Single copy (SC) 43/43 | | 230/232 = 99%.
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | 3) Is an internal QC program defined and externally monitored?
| | | Pyrosequencing vs. Long range PCR | CYP2D6 | | Reproducibility of linear regression coefficients (4 samples × 9) = 0.9731–0.9994, and 0.9632–0.9979) | | | 200 control DNAs.
| | | | Del,Dup | | | | | 4) Have repeated measurements been made on specimens?
| | | | 36/37 | 97.3% [86.2–99.5] | | | | 9 times on 4 known samples.
| | | | SC | | | | | 5) What is the within- and between-laboratory precision?
| | | | 43/43 | 100% [91.8–100] | | | | Not reported (used blood samples provided from diff labs, but not reported if previously genotyped, with which methods and if concordant).
| | | | | | | | | 6) How often does the test fail to give a useable result?
| | | | | | | | | 1/270 = 0.4%.
| | | | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | Comparable to published allele frequencies in Caucasians
| | | | | | | | | Comments: None
Neville, Selzer, Aizenstein, et al., 2002 | Geographical location: Not reported | Race/ethnicity: Not reported | Summary of test performance: | | | | | | Quality assessment:
#4910 | Size of population: 181 | | CYP 2D6 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Long range PCR and allele specific amplification (ASA) | | | | Long range PCR and ASA (repeated tests) | Long range PCR | | | 100%.
| Cytochromes (and specific mutations) tested for: 2D6 gene copy number | | NR | | | | Deletion (Del) 16/16 | | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: Long-range PCR | | | | | | Duplication (Dup) 11/11 | | 100%.
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | 3) Is an internal QC program defined and externally monitored?
| | | Long range PCR and ASA vs. Long range PCR | CYP2D6 | | | | | - Each PCR product was detected by at least two Invader assays.; - Negative and positive controls were integrated into genotyping process.; - CYP2D6 copy number assay was performed in duplicates.
| | | | Del,Dup | | | | | 4) Have repeated measurements been made on specimens?
| | | | 27/27 | 100% [87.6–100] | | | | Yes (twice).
| | | | SC | | | | | 5) What is the within- and between-laboratory precision?
| | | | NR | NR | | | | Within-lab duplicated, 100% agreement.
| | | | | | | | | 6) How often does the test fail to give a useable result?
| | | | | | | | | - 7/181 DNA samples were too degraded to generate PCR products.; - 10/1914 alleles (ambiguous low signals) – 0.5% (missing data rate).
| | | | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | Ethnicity of population not reported and cannot be compared to published data
| | | | | | | | | Comments: None
Weise, Grundler, Zaum-segel, et al., 2004 | Geographical location: Germany | Race/ethnicity: Caucasian 100% | Summary of test performance: | | | | | | Quality assessment:
#4520 | Size of population: 122 | | CYP 2C8 geno-type | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Real-time (RT) PCR | | | | RT-PCR (repeated tests) | PCR-RFLP | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP2C8 *2, *3, *4 | | *2/*1 | | 2 (× 2) | 2 | *2 | 2/2 | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: PCR- RFLP | | *3/*1 | | 16 (× 2) | 16 | *3 | 17/17 | 100%.
| | | *4/*1 | | 8 (× 2) | 8 | *4 | 9/9 | 3) Is an internal QC program defined and externally monitored?
| | | *3/*4 | | 1 (× 2) | 1 | *1 | 216/216 | Not reported.
| | | *1/*1 | | 95 (× 2) | 95 | | | 4) Have repeated measurements been made on specimens?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | Repeated analyses of all analyzed samples were performed by four different investigators with 100% concordance.
| | | RT PCR vs. PCR-RFLP | CYP2C8 | | Inter-assay reproduci-bility (all samples × 4 investiga-tors) = 100% | | | 5) What is the within- and between-laboratory precision?
| | | | *2,*3,*4 | | | | | Not reported.
| | | | 28/28 | 100% [88–100] | | | | 6) How often does the test fail to give a useable result?
| | | | *1 | | | | | Never.
| | | | 216/216 | 100% [98.3–100] | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | Allele frequencies are comparable to published data in Caucasians
| | | | | | | | | Comments: None
Wu, Zhou, and Xu, 2002 | Geographical location: China | Race/ethnicity: Not reported (presumably Chinese) | Summary of test performance: | | | | | | Quality assessment:
#4900 | Size of population: 50 | | CYP 1A1 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Mismatch hybridization | | | | Mismatch hybridization (repeated tests) | PCR-RFLP | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP1A1 m1 and m2 | | m1/*1 | | 20 | 20 | m1 | 36/36 | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: PCR-RFLP | | m1/m1 | | 8 | 8 | *1 | 64/64 | 98%.
| | | *1/*1 | | 22 | 22 | | | 3) Is an internal QC program defined and externally monitored?
| | | m2/*1 | | 21 | 21 | m2 | 31/31 | In design phase, 5 samples of each genotype were randomly tested by reference method.
| | | m2/m2 | | 5 | 5 | *1 | 69/69 | 4) Have repeated measurements been made on specimens?
| | | *1/*1 | | 24 | 24 | | | Single DNA sample was split into 5 aliquots and stored at -20 degree C. On 5 different days, a single split was removed, subjected to PCR, split into 2 aliquots, then hybridized and measured.
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | 5) What is the within- and between-laboratory precision?
| | | Mismatch hybridization vs. PCR-RFLP | CYP1A1 | | Inter-assay coefficient of variance = 3.3–9.5% | | | Not reported.
| | | | m1 | | | | | 6) How often does the test fail to give a useable result?
| | | | 36/36 | 100% [90.4–100] | | | | Never.
| | | | *1 | | Intra-assay coefficient of variance = 5–12.9% | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | 64/64 | 100% [94.3–100] | | | | Allele frequencies reported match Asian published data
| | | Mismatch hybridization vs. PCR-RFLP | CYP1A1 | | Inter-assay coefficient of variance = 5.1–11.2% | | | Comments: None
| | | | m2
| | | | 31/31 | 100% [89–100]
| | | | *1 | | Intra-assay coefficient of variance = 8.9–14.3%
| | | | 69/69 | 100% [94.7–100]
Mizugaki, Hiratsuka, Agatsuma, et al., 2000 | Geographical location: Japan | Race/ethnicity: Japanese 100% | Summary of test performance: | | | | | | Quality assessment:
#5380 | Size of population: 144 | | CYP 2C18 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Allele-specific amplification (ASA) and TaqMan PCR for 2C18 m1 and m2 | | | | ASA (repeated tests) | PCR-RFLP | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP2C19 *2, *3 | | m1/*1 | | 29 (× 3) | 29 | m1 | 42/42 | 2) How often is the test negative when a polymorphism is not present?
| CYP2C18 m1, m2 used as surrogates | | m2/m2 | | 8 (× 2) | 8 | 176/176 | | 100%.
| Reference standard test: PCR-RFLP | | *1/*1 | | 51 (× 3) | 51 | | | 3) Is an internal QC program defined and externally monitored?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | Not reported.
| | | ASA vs. PCR-RFLP | CYP2C18 | | Inter-assay variability implied as 100% | | | 4) Have repeated measurements been made on specimens?
| | | | m1,m2 | | | | | Yes (3 times).
| | | | 112/112 | 100% [96.7–100] | | | | 5) What is the within- and between-laboratory precision?
| | | | *1 | | | | | Not reported.
| | | | 176/176 | 100% [97.9–100] | | | | 6) How often does the test fail to give a useable result?
| | | | | | | | | Not reported.
| | | | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | Allele frequencies for the CYP2C18 and CYP2C19 match published data in Japanese
| | | | | | | | | Comments:
| | | | | | | | | - In Japanese populations there is complete linkage disequilibrium between the tested polymorphisms in CYP2C18 and 19:; CYP2C18 m1 = CYP2C19*3; CYP2C18 m2 = CYP2C19*2; - Similar linkage is reported also for Caucasians (Inoue et al, 1998)
Muthiah, Lee, The, et al., 2004 | Geographical location: Malaysia | Race/ethnicity: Malaysian Indians 100% | Summary of test performance: | | | | | | Quality assessment:
#4240 | Size of population: 57 | | CYP 2C8 genotype | No. of individuals sequenced | Method comparison Number of individuals genotyped | | Total allele counts | | 1) How often is the test positive when a polymorphism is present?
| Method of CYP testing or product used: Two step multiplex PCR | | | | Multiplex PCR (repeated tests) | | | | 100%.
| Cytochromes (and specific mutations) tested for: CYP2C8 *2, *3, *4 | | *2/*1 | 2 | 2 | | *2 | 2/2 | 2) How often is the test negative when a polymorphism is not present?
| Reference standard test: Sequencing | | *3/*1 | 3 | 3 | | *3 | 3/3 | 100%.
| | | *1/*1 | 52 | 52 | | *1 | 109/109 | 3) Is an internal QC program defined and externally monitored?
| | | Comparison between methods | Alleles and total counts | Sensitivity & specificity [confidence interval] | Robustness | | | - 3 heterozygous mutations (*2, *3) sequenced and used as positive controls; - *4 mutagenesis-generated positive control used; - Negative controls with no DNA also used
| | | Multiplex PCR vs. sequencing | CYP2C8
| | | | *2,*3
| | | | 5/5 | 100% [56.6–100] | | | | 4) Have repeated measurements been made on specimens?
| | | | *1 | | | | | Not reported (only to determine optimal annealing temperatures).
| | | | 109/109 | 100% [88–100] | | | | 5) What is the within- and between-laboratory precision?
| | | | | | | | | Not reported.
| | | | | | | | | 6) How often does the test fail to give a useable result?
| | | | | | | | | Never.
| | | | | | | | | 7) How similar are results obtained in multiple laboratories using the same or different technology?
| | | | | | | | | Little is published about expected allele frequencies in this population
| | | | | | | | | Comments: None

1 Studies in this evidence table are ordered by significance: first CYP2D6, then others, primarily CYP2C9 and CYP2C19. Within each of these categories,reference to sequencing is regarded as a higher level of evidence than other methods. Also, within the CYP2D6 category, we first group all the CYP2D6-variantstudies and then the CYP2D6 gene copy number studies.

Evidence Table 2. Question 3a: How well do particular CYP450 genotypes correspond with metabolism of particular SSRIs? Do factors such as race/ethnicity, diet, or other medications affect this association?

Study | Study Design | Patient Characteristics | Results | | | | | | Comments/Quality Scoring
Berle, Steen, Aamo, et al., 2004 | Geographical location: Norway | Age: Mean:31 | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Exclusion criteria not described; - No comment on concurrent medications; - Infant blood level not drawn in a consistent manner, which may affect level
#440 | Dates: NR | Range: 20–42 | Overview of genotypes in mothers tested: | | | | | | Quality assessment: 3b
| Size of population: 24 mothers and 25 infants (one pair of dizygotic twins; 14 mothers and 15 infants on citalopram and paroxetine) | Weight: NR | CYPD6
| Method of CYP testing or product used:; - Restriction enzyme digestion assays of CYP2C19-specific PCR-products; - For CYP2D6, multiplex PCR with modification, long PCR assays; - Blinded to demographic/ pharmacologic data | Race/ethnicity: White | *1/*1 (EM) | *1/*3(EM) | *1/*4 (EM) | *2×2/*4 (EM) | *4/*4 (PM) | *1/*2×2 (UM)
| Cytochromes (and specific mutations) tested for: 2C19 *2, *3, *4, *12D6 *3, *4, *6, *7, *8, *5, *1 | Inclusion criteria: DSMIV Major depression Anti-depressant therapy | 12 | 2 | 8 | 1 | 1 | 1
| SSRI(s): Citalopram, fluoxetine, paroxetine, sertraline (or venlafaxine) | Exclusion criteria: NR | CYP2C19
| | | *1/*1 (EM) | *1/*2 (EM) | *2/*2 (PM)
| | | 14 | 9 | 1
| | | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | | One 2D6 PM mother-infant pair (SSRI-paroxetine): Mother had highest paroxetine level (210 nmol/L), but infant had undetectable level.
| | | One 2D6 UM infant did not have detectable paroxetine level (total 5 infants had undetectable paroxetine levels).
| | | One 2C19 PM mother treated with citalopram had highest citalopram level of all (394 nmol/L) at dose of 20 mg/day. Her heterozygous twin infants were EMs and had detectable but low concentration of citalopram.
| | | 5 infants with 2C19 *1*2 genotype had higher mean citalopram levels than the 5 infants with *1*1 genotype (p-value NR), and 3 of 4 infants with undetectable citalopram levels had *1*1 genotype.
| | | For other drugs, such comparisons could not be performed because of undetectable levels of drug or skewed distribution of various genotypes
Charlier, Broly, Lhermitte, et al., 2003 | Geographical location: Belgium | Age: Mean (SD): 48.2 (12.7) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - 2D6*41 not investigated; - No comment on diet, role of other CYP enzymes; - Rate of deficiency of 2D6 expression found in this study is 16.3% compared to general population (also supported by a previous study of a psychiatric population showing 14%); - Ultrarapid genotype only 2% in this study, compared to 4.59 reported elsewhere (referenced).
#650 | Dates: NR | Range: 21–81 | Fluoxetine: 10 EMs, 2 PMs | | | | | | Quality assessment: 3b
| Size of population: 49 | Weight: NR | Paroxetine: 30 EMs, 6 PMs, 1 UM
| Method of CYP testing or product used: Genomic RFLP analysis PCR-SSCP analysis | Race/ethnicity: North European White origin | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6 “gene copy number” | Inclusion criteria: DSM IV major depressive episode, MADRS ≥ 21 | Fluoxetine: 2 PMs had significantly higher steady state plasma concentration than the 10 EMs (p = 0.004).
| SSRI(s): Fluoxetine 20 mg/d (n = 12), paroxetine 20 mg/d (n = 37) | Exclusion criteria: Meds other than occasional benzodiazepines | Paroxetine: 6 PMs had significantly higher plasma concentration compared to 30 EMs (p = 0.00001). One UM had undetectable plasma concentration
Eap, Bondolfi, Zullino, et al., 2001 | Geographical location: Switzerland | Age: Mean (SD): 41(15) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Small sample size; - Risperidone for varying duration before study; - Steady state not achieved of (S) isomer of fluoxetine
#1510 | Dates: NR | Range: 18–63 | 4 patients received co-medications (clorazepate, fluorazepam, procyclidine, acetaminophen, lormetazepam, lactulose, fenofibrate, lorazepam). | | | | | | Quality assessment: 3b
| Size of population: 11 | Weight: Mean (SD): 83 kg (15) | Number of PMs = 3 (*4/*4)
| Method of CYP testing or product used: Allele-specific PCR | Range: 53–104 kg | Number of heterozygous EMs = 2 (*1/*4)
| Cytochromes (and specific mutations) tested for: 2D6 *3, *4, *6, | Race/ethnicity: NR | Number of homozygous EMs = 6 (*1/*1)
| SSRI(s): Fluoxetine 20 mg from day 6 to 30 of 30-day study | Inclusion criteria: Subjects taking risperidone before the study who might benefit from combination therapy with risperidone (2 mg bid × 30 days) and fluoxetine | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | Exclusion criteria: Abnormal labs, inducers/inhibitors of hepatic enzymes for 2 weeks before study | Mean concentration of S-fluoxetine and S-norfluoxetine significantly increased between days 14 and 23, indicating steady state had not been reached on day 14 (p < 0.01 for both).
| | | No significant differences in the concentrations of R- fluoxetine and R-norfluoxetine between days 14 and 23, suggesting steady state had been reached at day 14.
| | | For days 7, 14, and 23, no significant differences between concentrations of R-fluoxetine and R-norfluoxetine between PMs and EMs (p-values NR).
| | | Mean S-fluoxetine concentration was significantly higher and mean
| | | S-norfluoxetine concentration was significantly lower on day 7 (p = 0.037) and day 14 (p = 0.014) in PMs compared to EMs, and similar trend observed for day 23 (p = 0.068) where one sample for PM was missing.
| | | Heterozygous EMs had levels between homozygous and PMs (but not significantly different from homozygous EMs)
Gras-mader, Verwohlt, Rietschel, et al., 2004 | Geographical location: Germany | Age: Mean (SD): 49 (14) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Accounted for co-meds that are substrates/inhibitors/inducers of 5 major CYP enzymes; - HAMD and CGI used; - Cut-off for therapeutic plasma concentration (weekly trough levels measured); - UKU side effect rating scale used; - SSRIs and other meds (including TCAs, venlafaxine, mirtazapine); most results reported for entire group, not just for SSRIs; - Other treatments allowed (e.g., psychotherapy), some patients on multiple antidepressants.Numbers reported in analyses don't add up.; - Therapeutic levels not well-established for SSRIs.
#450 | Dates: 2000-2003 | Weight: Mean (SD): 76.3 kg (17.5) | Testing for CYP2C9 and 2C19 showed no significant differences with respect to allele frequencies and number of carriers of none, one, or two functional alleles (p = 0.445, p = 0.847, respectively) when compared with other Caucasian control groups. | | | | | | Quality assessment: 4
| Size of population: 136 total 70 (SSRIs) (68 blood concentrations?) | Race/ethnicity: NR (refers to Caucasians in conclusion) | 2D6 PMs were underrepresented in the sample (p = 0.05) compared to 195 healthy volunteers (in literature).
| Method of CYP testing or product used:; - RFLP-PCR; - Positive and negative control samples | Inclusion criteria: ICD-10 diagnosis F3, CGI > 4, antidepressant therapy (including SSRIs) | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: CYP2C9 *1 to *3, CYP2C19*1 and *2, 2D6 *1 to *9 and gene duplication | Exclusion criteria: Substance abuse/dependency, prior treatment with fluoxetine, acute suicidality, pregnancy, admission by legal commitment or for crisis intervention | The relative deviation of mean dose-corrected plasma concentrations from drug-specific median was significantly higher in CYP2D6 PMs (p < 0.001) and in persons with 2D6-inhibiting co-meds (p < 0.001).
| SSRI(s): Fluvoxamine, paroxetine, sertraline, citalopram | | This parameter was lower in 2C19 EMs (p = 0.005) and in smokers (p = 0.033). Two PMs showed dose-corrected plasma concentrations > 2 times higher than median
Liu, Cheng, Huang, et al., 2001 | Geographical location: China | Age: Mean (SD): 20.1 (1.1) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Single dose; - Don't know status of other CYP gene polymorphisms, e.g., 2D6, that are involved in fluoxetine metabolism; - Method for CYP testing not reported in this study, references provided
#1440 | Dates: NR | Range: 18–22 | No of EMs: 8 (4 *1/*1, and 4 *1/*2) | | | | | | Quality assessment: 3b
| Size of population: 14 healthy | Weight: Mean (SD): 63 kg (6.4) | No of PMs: 6 (4 *2/*2, and 2 *2/*3)
| Method of CYP testing or product used: NR (“previously determined”) | Range: 55–80 kg | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2C19 *1, *2, *3 | Race/ethnicity: Chinese - 100% | PMs showed 46% increase in fluoxetine Cmax (p < 0.001), 128% increase in AUC (p < 0.001), 113% increase in half-life (p < 0.001), and 55% decrease in oral clearance (p < 0.001) compared with EMs.
| SSRI(s): Fluoxetine (40 mg after overnight fast.AUC calculated for F and NorF.) | Inclusion criteria: Healthy (history, PE, no lab abnormalities indicating renal or hepatic disease) | Mean norfluoxetine AUC significantly lower in PMs than in EMs (p < 0.001).
| | Exclusion criteria: Medication, alcohol, smoking in preceding 2 weeks | Mean fluoxetine oral clearance was significantly higher in wild type homozygotes compared to heterozygotes (p < 0.01) and in PMs (p < 0.001).
| | | Mean norfluoxetine AUC in PMs was significantly smaller than that in wild type homozygotes (p < 0.05) and in heterozygotes (p < 0.001)
LLerena, Dorado, Berecz, et al., 2004 | Geographical location: Spain | Age: Mean (SD): 51 (15) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Overall great inter-individual variability in fluoxetine, norfluoxetine, and fluoxetine/norfluoxetine ratio was found in this study; - Enantiomers of fluoxetine not studied
#580 | Dates: NR | Range: 18–77 | 2D6 genotype | Proposed phenotype | Number of patients | | | | Quality assessment: 3b
| Size of population: 64 | Weight: NR | *1/*1 | Homozygous EM | 41
| Method of CYP testing or product used: PCR based AmpliTaq Gold System (2D6*3, *4, *6), Expand Long Template PCR system (2D6*5), RFLP-PCR (2C9*1, *2, *3) | Race/ethnicity: White European - 100% | *1/*4 | Heterozygous EM | 17
| Cytochromes (and specific mutations) tested for: 2D6: *3, *4, *5, *6 | Inclusion criteria: Psychiatric outpatients, same fluoxetine dose for at least 45 days (range10 to 60 mg/d); no inhibitors or substrates of 2D6/2C9 | *1/ *6 | Heterozygous EM | 2
| 2C9: *1, *2, *3 | Exclusion criteria: NR | *4/*4 | PM | 1
| SSRI (s): Fluoxetine | | *1/*1×dN or *1/ *2×N | UM | 3
| | | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | | Dose-corrected plasma concentration of fluoxetine significantly related to number of active 2D6 genes (p < 0.01). No such correlation between norfluoxetine or active moiety (fluoxetine + norfluoxetine) and 2D6 gene copies.
| | | Fluoxetine/norfluoxetine ratio was overall significantly correlated with number of active CYP2D6 genes (p < 0.01).
| | | In homozygous EMs of 2D6 (*1/*1), influence of 2C9 was evaluated(n = 38 total for *1/*1, *1/*2 and *1/*3).
| | | Dose-corrected plasma concentration of fluoxetine and active moiety were significantly higher in CYP2C9 *1/*2 and *1/*3 (p < 0.05) compared to *1/ *1 (wild).
| | | Norfluoxetine concentration higher in CYP2C9 *1/*3 (p < 0.05) compared to *1/*1.
| | | Fluoxetin/norfluoxetine ratios not significantly different.
| | | 3 patients with *2/*2, *2/*3, *3/*3 reported to be “not highly different” compared to those heterozygous for *2 or *3, but analysis not shown, p-value not reported
Murphy, Kremer, Rodrigues, et al., 2003 | Geographical location: Multicenter, USA | Age: NR (reported for subgroups) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Numbers do not add up for paroxetine or mirtazapine total N; - Patients grouped to improve strength, IMs may not be very different from EMs
#680 | Dates: NR | Weight: NR (reported for subgroups) | Frequency of common 2D6 alleles did not differ significantly from that reported in Caucasian populations. *10B was over-represented in the sample (possibly because 15 ethnic minority patients in the sample). | | | | | | Quality assessment: 3b
| Size of population: 124 paroxetine | Race/ethnicity: NR | PM n = 16, IM n = 26, UM n = 10, EM n = 94.
| 122 mirtazapine | Inclusion criteria: DSM-IV major depressive episode; 17-item HAMD score ≥ 18 | Because of small number of PMs and UMs, groups combined as follows for analyses: PM + IM vs. EM + UM.
| Method of CYP testing or product used:; - Oligonucleotide microarrays; - Scored by 2 observers blind to clinical data | Exclusion criteria: < 65 yrs, major medical problems, MMSE < 25% percentile for age, clinically significant lab abnormalities, unstable medical conditions, drug or alcohol abuse, psychosis, recent suicide attempt, other psychiatric problems, antidepressant treatment within 7 days of starting study | For paroxetine: PM + IM n = 15, EM + UM, n = 105
| Cytochromes (and specific mutations) tested for: 2D6: 16 alleles, deletion, duplication, and *41 allele | | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| SSRI(s): Paroxetine (and mirtazapine) | | For both meds, no differences between PM + IM vs. EM + UM groups in final daily dose achieved, dosing compliance, or plasma drug levels obtained after 4 weeks (exact p-values not reported).
| | | Same results for Caucasian patients when analyzed alone.
| | | ANOVA showed no effect of concurrent medication that was a 2D6 inhibitor or substrate
Ohara, Tanabu, Ishibashi, et al., 2003 | Geographical location: Japan | Age: Mean (SD):52.5 (16) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Does not account for effects of diet, concurrent meds not described; - Other CYP enzymes not taken into account
#900 | Dates: NR | Range: 24–83 | Number of subjects: | | | | | | Quality assessment: 3b
| Size of population: 46 | Weight: Mean (SD): 55.3 (11.8) | 0 *10 alleles: 13
| Method of CYP testing or product used: 2 step PCR, long PCR | Range: 30–92 kg | 1 *10 allele: 18
| Cytochromes (and specific mutations) tested for: 2D6*10 (in population carrying no *3*4*5) | Race/ethnicity: Japanese - 100% | 2 *10 alleles: 15
| SSRI(s): Fluvoxamine 25 mg/d to 150 mg/d (steady dose for 14 days) | Inclusion criteria: DSM IV MDD; standard doses of benzodiazepines permitted for treatment of sleep disturbance | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | Exclusion criteria: Meds interfering with fluvoxamine metabolism; elevated SGOT, SGPT; physical illness, antiepileptic drugs | Plasma levels of fluvoxamine ranged from 1.95 ng/mL to 127.51 ng/mL.
| | | Fluvoxamine concentration/dose ratio was no different between subjects with 0, 1 or 2 *10 alleles (p = 0.984)
Ozdemir, Tyndale, Reed, et al., 1999 | Geographical location: Toronto, Canada | Age: Median: 29 | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Small sample; - Did not test for all alleles
#2080 | Dates: NR | Range: 21–49 | No. of heterozygous EMs:7 | | | | | | Quality assessment: 3b
| Size of population: 17 | Weight: NR | No. of homozygous EMs:10
| Method of CYP testing or product used: PCR | Race/ethnicity: White - 100% | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6*1, *3, *4, *5 | Inclusion criteria: Healthy | Heterozygous EMs (n = 7) had twofold higher median paroxetine steady-state concentration than homozygous wild type EMs (n = 10), but not statistically significant (p = 0.2).
| SSRI(s): Paroxetine 20mg/d for at least 5 days (5–15 days) | Exclusion criteria: Smokers, “long-term medications that can interfere with 2D6 activity” | Age, duration of treatment, sex, weight did not significantly contribute to variability in paroxetine concentration (p > 0.05, n = 17)
Sawamura, Suzuki, and Someya, 2004 | Geographical location: Japan | Age: Mean (SD): 39.9 (15.4) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Reasons for non-linearity:possible saturation of 2D6, possible self-inhibition of paroxetine metabolism at higher dose; - Skewing of distribution of mutant alleles was not taken into account in comparing the paroxetine concentrations in the older and younger age groups; - Asians CYP2D6*10 ~ 51%; - CYP3A4 (potentially a secondary pathway) not taken into account
#320 | Dates: NR | Range: 13–73 | 9 different genotypes identified. Comparison carried out between *1/*1, *1/*10, *10/*10, and those with one or two *5 mutated alleles at each dose. | | | | | | Quality assessment: 3b
| Size of population: 73 | Weight: NR | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: PCR (*1, *2, *10, *3, *4) Long PCR (*5) | Race/ethnicity: Japanese - 100% | Exponential regression curve between paroxetine dose and mean plasma paroxetine concentration.
| Cytochromes (and specific mutations) tested for: 2D6 *1, *2, *3, *4, *5 *10 | Inclusion criteria: Psychiatric patients | Mean plasma paroxetine level in older subjects was higher than in younger subjects at each dose, statistically significant only at 40 mg dose (p = 0.013). Of note there was one *1/*1 elderly and 20 *1/*1 non-elderly (total numbers in each group NR).
| SSRI(s): Paroxetine, 2 weeks of steady dose | Exclusion criteria: Drugs except benzodiazepines, physical illness (no subjects were taking SJW or OTC meds) | Plasma paroxetine concentrations in patients with *10 alleles were significantly higher than those without *10 allele at 10 mg/day dose (p = 0.019), but not at other doses
Scordo, Spina, Dahl, et al., 2005 | Geographical location: Italy | Age: Mean (SD): 45 (4) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Accounted for co-medications; - Only one CYP2D6 PM patient
#12770 | Dates: NR | Weight: NR | CYP2D6: UM 8%, EM 63%, hetero EM 28.2%, PM 1.3% | | | | | | Quality assessment: 3b
| Size of population: 78 | Race/ethnicity: Caucasian, Italian | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: | Inclusion criteria: On maintenance treatment with fluoxetine for major depression or other depressive disorders, no drugs interfering with CYP2D6/2C9/2C19 | Dose normalized plasma concentrations of S-fluoxetine, R-fluoxetine, S-norfluoxetine, and R-norfluoxetine did not differ significantly between different predicted phenotype groups of CYP2D6 or CYP2C19.
| 2D6: allele-specific PCR, Long PCR | Exclusion criteria: None specified | Median S-norfluoxetine/S-fluoxetine ratios were higher in homozygous vs. heterozygous EMs.
| 2C9, 2C19: PCR-RFLP | | Among 2D6 EMs, 2C9 *1, *1 had lower concentration of R-fluoxetine, and active moiety than heterozygotes or PMs
| Cytochromes (and specific mutations) tested for:
| CYP2D6 *3, *4, *5, *6
| CYP2C9 *2, *3
| CYP2C19 *2
| SSRI(s): Fluoxetine (10–60 mg/d) for at least 5 weeks
Stedman, Begg, Kennedy, et al., 2002 | Geographical location: New Zealand | Age: Mean: 74.5 | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - *9 finding is unlikely to be of significance - intermediate activity; - Small number; - Race not specified; - Exclusion criteria not specified; - Concurrent medications not specified
#1050 | Dates: NR | Range: 51–94 | Fluoxetine n = 11, paroxetine n = 9; 16 were taking 20 mg/day, others were taking 10 mg qod to 40 mg/day. | | | | | | Quality assessment: 4
| Size of population: 20 | Weight: NR | 2D6 allele | Study subjects (n = 20) | Sachse et al. (general population) (n = 589) | Significance (p-value)
| Method of CYP testing or product used: RFLP-PCR | Race/ethnicity: NR | *1 | 0.45 | 0.36 | NS (p = 0.46)
| Cytochromes (and specific mutations) tested for: 2D6 *1, *2, *3, *4, *5, *6, *7, *8, *9, *10, *11, *12, *13, *14, *15, *16 | Inclusion criteria: Taking fluoxetine or paroxetine, with adverse effect of hyponatremia, Na < 130 mmol/L | *2 | 0.3 | 0.32 | NS (p = 0.87)
| SSRI(s): Fluoxetine, paroxetine | Exclusion criteria: None specified | *9 | 0.1 | 0.02 | P = 0.0007
| | | *4 | 0.15 | 0.21 | NS (p = 0.46)
| | | 2D6 *9 (intermediate allele) more common in patient population.
| | | All patients were EM except one paroxetine patient was IM/PM genotype.
| | | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | | All trough concentrations of fluoxetine, norfluoxetine and paroxetine were in lower half of reference range
Ueda, Hirokane, Morita, et al., 2006 | Geographical location: Shinga, Japan | Age: Mean (SD): 45 (14) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments: None
#13750 | Dates: NR | Range: 20–71 yrs | No functional allele: 12 (22%) | | | | | | Quality assessment: 3b
| Size of population: 55 | Weight: Mean (SD): 57 kg (12) | One functional allele: 26 (47%)
| Method of CYP testing or product used: PCR, long-PCR, RFLP | Range: 36–117 kg | Two functional alleles: 17 (31%)
| Cytochromes (and specific mutations) tested for: CYP2D6 *2, *10, *5, *41 | Race/ethnicity (n [%]): Japanese (55 [100%]) | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| SSRI(s): Paroxetine 10–40 mg/d (same daily dose for at least 2 weeks) | Inclusion criteria: Inpatients and outpatients | At 30 mg/d dose, significantly higher concentrations of paroxetine were observed in subjects with one functional allele (243.6 ± 25.2 ng/mL/mg/kg) (n = 26), compared with two functional alleles (150.9 ± 20.6 ng/mL/mg/kg) (n = 17) or no functional alleles (76.7 ± 6.1 ng/mL/mg/kg) (n = 12); p < 0.05 for both comparisons
| | Exclusion criteria: Physical illness, use of “any drugs that have been reported to substantially interfere with CYP2D6 activity”
Wang, Liu, Wang, et al., 2001 | Geographical location: China | Age: Mean (SD): 20 (1) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - CYP2C19 PMs more common in Asians (13–23%) compared to Caucasians (2–5%); - Did not take into account the role of other CYPs in sertraline metabolism; - Possibly same overall patient population (n = 77) as Yu et al., 2003 (#710), below (uncertain)
#1450 | Dates: NR | Range: 19–22 | Of 77 young, healthy Chinese Han subjects tested, 14.3% were PMs and 85.7% EMs. Of these, 6 PMs and 6 EMs were selected by stratified random sampling. | | | | | | Quality assessment: 4
| Size of population: 12 unrelated healthy males | Weight: Mean (SD): 65 kg (7) | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: RFLP-PCR | Range: 54–80 kg | The 6 PMs showed a 41% increase in sertraline AUC (p < 0.05), a 51% increase in sertraline terminal elimination half-life (p < 0.01), and significantly lower oral clearance (p < 0.05) compared to EMs. PMs also showed significantly lower AUC (p < 0.05) and Cmax (p < 0.01) of desmethylsertraline and markedly higher time to reach Cmax for desmethylsertraline (p < 0.01) compared to EMs
| Cytochromes (and specific mutations) tested for: 2C19 *1, *2, *3 | Race/ethnicity: Chinese Han - 100%
| SSRI(s): Sertraline 100 mg | Inclusion criteria: Healthy (by history, physical exam, and labs), male, non-smokers
| | Exclusion criteria: Medication, ethanol 2 weeks before study
Yoon, Cha, Shon, et al., 2000 | Geographical location: Korea | Age(screened population): Mean (SD): 22.4 (1.4) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Race/ethnicity not generalizable; - Sample selected from Ems(2D6 *10 is common in east Asians, Korea population studies show 28% homozygous, and 45% heterozygous for *10 allele); - No gene dose effect found in the study; - 2 subjects with highest metoprolol metabolic ratio values were heterozygous, and two with less enzyme activity were homozygous; - *10B alone is limited in its ability to differentiate paroxetine clearances between Korean EMs
#1900 | Dates: NR | Weight: Mean (SD): 61.1 kg (10.3) | 15 EMs and 1 PMs. | | | | | | Quality assessment: 3b
| Size of population: 224 screened 15 EM and 1 PM of metoprolol selected by stratified random sampling | Race/ethnicity: Korean - 100% | Comparison of 4 sub-groups of EMs, based on metoprolol metabolic ratio.
| Method of CYP testing or product used: Restriction endonuclease testing (PCR based) for *10B allele, oligonucleotide microarray GeneChip system for 17 known alleles | Inclusion criteria: Healthy (PE and labs) | No consistent correlation between metoprolol metabolic ratio value and genotype was found.The genotype of one PM subject could not be identified either by allele-specific PCR or by the GeneChip system.
| Cytochromes (and specific mutations) tested for: | Exclusion criteria: No drugs or alcohol 1 week before study entry or during the study | (*1/*1 and *1/*2 ) n = 6
| CYP2D6 *1, *2, *10B | | (*1/*10B and *2/*10B) n = 6
| (Re-assayed for *1A, *2, *3, *4A-E, *5, *6A-B, *7–*9, *10A-B, *11) | | (*10B/*10B) n = 3
| SSRI(s): Paroxetine 40 mg | | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| | | Heterozygotes and homozygotes for *10B showed significantly lower volume of distribution (p < 0.01) and oral clearance (p < 0.01) of paroxetine compared to *1/*1.
| | | *10B/*10B showed significantly greater total AUC of paroxetine (p < 0.05) compared to *1/*1.
| | | No significant differences were found between heterozygotes and homozygotes for *10B in pharmacokinetic parameters.
| | | Peak plasma concentration, half-life, and renal clearance did not differ significantly between the groups
Yu, Chen, He, et al., 2003 | Geographical location: China | Age: Mean (SD): 21 (1) | 1) Genotypes/phenotypes in patient population: | | | | | | Comments:; - Possibly same overall patient population (n = 77) as Wang et al., 2001 (#1450), above (uncertain)
#710 | Dates: NR | Range: 20–22 | 77 healthy Chinese:EMs 85.7%, PMs 14.3%. From these 13 chosen by stratified random selection. | | | | | | Quality assessment: 3b
| Size of population: 13 (8 EMs, 5 PMs) of 77 screened | Weight: Mean (SD): 64 kg (8) | 2) Drug concentrations (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: RFLP-PCR | Range: 56–81 kg | PMs had significantly higher citalopram AUC (p < 0.01), longer half-life (p < 0.01), and lower oral clearance (p-value NR).
| Cytochromes (and specific mutations) tested for: CYP2C19 *1, *2, *3 | Race/ethnicity: Chinese - 100% | AUC and Cmax of desmethycitalopramwas lower (p < 0.01 and p < 0.05, respectively) than in EMs.
| SSRI(s): Citalopram 40 mg | Inclusion criteria: Male, non-smokers, healthy | DCIT/CIT ratio of EMs was 3 times that of PMs (p < 0.01).
| | Exclusion criteria: Meds/alcohol 2 weeks before and thru study | Half-life, oral clearance of citalopram, and AUC, Cmax, and Tmax of desmethylcitalopram were significantly different in PMs compared to homozygous EMs and heterozygous EMs (p < 0.05).
| | | Dose effect:homozygotes > heterozygotes > PMs.
| | | In the same subjects, under similar conditions, administration of troleandomycin (TAO, to block CYP 3A4) showed that there was no difference in citalopram pharmacokinetics in EMs, with or without TAO.
| | | In PMs, TAO did have a significant effect on citalopram and desmethylcitalopram AUC (p < 0.05)

Evidence Table 3. Question 3b: How well does CYP450 testing predict drug efficacy? Do factors such as race/ethnicity, diet, or other medications, affect this association?

Study | Study Design | Patient Characteristics | Results | Comments/Quality Scoring
Gerstenberg, Aoshima, Fukasawa, et al., 2003 | Geographical location: Japan | Age: | 1) Genotypes/phenotypes in patient population: | Comments:; - Heterogeneous group of patients, including inpatients, outpatients, different subtypes of depression; - Small numbers; - The same group reported in another study that 2D6 genotypes do not affect steady-state concentration of fluvoxamine and its metabolite, probably because of saturation of the enzyme.; - Effect of plasma concentration on response is not concordant with effect of genotype on response
#790 | Dates: NR | Median: 45 | Number of patients with no mutated alleles (EMs): 12 | Quality assessment: 3b
| Size of population: 49 | Range: 24–69 | Number of patients with 1 mutated allele (IMs): 27
| Method of CYP testing or product used:; - Allele-specific PCR; - Long PCR, 2-step PCR; - Blinded to clinical ratings | Weight: Median: 55 kg | Number of patients with 2 mutated alleles (PMs): 10
| Cytochromes (and specific mutations) tested for: 2D6 *1, *3, *4, *5, *10 | Range: 40–84 kg | 2) Efficacy (including effect of race/ethnicity, diet, and other medications):
| SSRI(s): Fluvoxamine (50 mg 1^st^ week, 100 mg 2^nd^ week, and 200 mg in remaining 4 weeks) | Race/ethnicity (n [%]): Japanese | Stepwise multiple regression showed that final MADRS score, % improvement, and amelioration score were not significantly different across the 3 groups. Logistic regression showed that proportion of responders was not significantly different across the 3 groups
| | Inclusion criteria: DSM-IV major depressive episode, no psychotic/atypical features; no other psychiatric disorders; MADRS ≥ 21; benzodiazepines permitted
| | Exclusion criteria: Current antidepressant treatment, medical illness, medications in past 2 weeks
Grasmader, Verwohlt, Rietschel, et al., 2004 | Geographical location: Germany | Age: Mean (SD): 49 (14) | 1) Genotypes/phenotypes in patient population: | Comments:; - Accounted for co-meds that are substrates/inhibitors/inducers of 5 major CYP enzymes; - HAMD and CGI used; - Cut-off for therapeutic plasma concentration (weekly trough levels measured); - UKU side effect rating scale used; - SSRIs and other meds (including TCAs, venlafaxine, mirtazapine); most results reported for entire group, not just for SSRIs; - Other treatments allowed (e.g., psychotherapy), some patients on multiple antidepressants. Numbers reported in analyses don't add up.; - Therapeutic levels not well-established for SSRIs.
#450 | Dates: 2000-2003 | Weight: Mean (SD): 76.3 kg (17.5) | Testing for CYP2C9 and 2C19 showed no significant differences with respect to allele frequencies and number of carriers of none, one, or two functional alleles (p = 0.445, p = 0.847. respectively) when compared with other Caucasian control groups. | Quality assessment: 4
| Size of population: 136 total 70 (SSRIs) (68 blood concentrations?) | Race/ethnicity: NR (refers to Caucasians in conclusion) | 2D6 PMs were underrepresented in the sample (p = 0.05) compared to 195 healthy volunteers (in literature).
| Method of CYP testing or product used:; - RFLP-PCR; - Positive and negative control samples | Inclusion criteria: ICD-10 diagnosis F3, CGI > 4, antidepressant therapy (including SSRIs) | 2) Efficacy (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: CYP2C9 *1 to *3, CYP2C19*1 and *2, 2D6 *1 to *9 and gene duplication | Exclusion criteria: Substance abuse/dependency, prior treatment with fluoxetine, acute suicidality, pregnancy, admission by legal commitment or for crisis intervention | According to HAMD-based response criterion, 42.9% were responders, by CGI criterion, 33% were responders. Plasma concentrations above or below lower limit of presumed therapeutic levels did not predict response (p = 0.082 for CGI, p = 0.982 for HAMD)
| SSRI(s): Fluvoxamine, paroxetine, sertraline, citalopram
Kawanishi, Lundgren, Agren, et al., 2004 | Geographical location: Sweden | Age: Mean (SD): 45 (12.4) | 1) Genotypes/phenotypes in patient population: | Comments:; - Limitations: study of cases only, no control, no therapeutic monitoring, and small sample size. May be better to test in a population where gene duplication is more common.; - Plasma lymphocyte samples
#11560 | Dates: NR | Weight: NR | Frequencies of genotype were as follows: EM 0.0889, PM 0.028, genotype with duplication 0.083. | Quality assessment: 3b
| Size of population: 108 | Race/ethnicity: Caucasians of Nordic origin - 100% | Frequency of PM genotype was 0.028 (95% CI 0 to 0.058), less than in the general population (0.068).
| Method of CYP testing or product used: PCR-RFLP, long PCR, TaqMan Universal PCR + probes | Inclusion criteria: Current DSM-IV major depression, persistent symptoms during a recent episode which did not improve over 8 weeks, failed 4-week adequate dose trials of > 2 antidepressants/mood stabilizers | Frequency of gene duplication in the subgroup of 81 subjects treated with CYP2D6 substrates was 9.9% (95% CI 3.4 to 16.4%). This is significantly greater than in the general Swedish/Danish population (1%/0.8%; 95% CI 0.2 to 1.4%).
| Cytochromes (and specific mutations) tested for: 2D6 gene duplication, and *2, *3, *4, *5 | Exclusion criteria: NR | Incidence of gene duplication (0.083, 95% CI 0.031 to 0.135) was higher than that reported in healthy Swedish subjects (0.01).
| SSRI(s): Various SSRIs, plus other classes of antidepressants | | 2) Efficacy (including effect of race/ethnicity, diet, and other medications):
| | | “Worst week (in past year) HDRS scores” were much higher in patents with duplication than without (p = 0.026). Past week scores were similar between the groups (p = 0.992)
Murphy, Kremer, Rodrigues, et al., 2003 | Geographical location: Multicenter, USA | Age: NR (reported for subgroups) | 1) Genotypes/phenotypes in patient population: | Comments:; - Numbers do not add up for paroxetine or mirtazapine total N; - Patients grouped to improve strength, IMs may not be very different from EMs
#680 | Dates: NR | Weight: NR (reported for subgroups) | Frequency of common 2D6 alleles did not differ significantly from that reported in Caucasian populations. *10B was over-represented in the sample (possibly because 15 ethnic minority patients in the sample). | Quality assessment: 3b
| Size of population: | Race/ethnicity: NR | PM n = 16, IM n = 26, UM n = 10, EM n = 94.
| 124 paroxetine | Inclusion criteria: DSM-IV major depressive episode; 17-item HAMD score ≥ 18 | Because of small number of PMs and UMs, groups combined as follows for analyses: PM + IM vs. EM + UM.
| 122 mirtazapine | Exclusion criteria: < 65 yrs, major medical problems, MMSE < 25% percentile for age, clinically significant lab abnormalities, unstable medical conditions, drug or alcohol abuse, psychosis, recent suicide attempt, other psychiatric problems, antidepressant treatment within 7 days of starting study | For paroxetine: PM + IM n = 15, EM + UM, n = 105
| Method of CYP testing or product used:; - Oligonucleotide microarrays; - Scored by 2 observers blind to clinical data | | 2) Efficacy (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6: 16 alleles, deletion, duplication, and *41 allele | | For both meds, no differences between PM + IM vs. EM + UM groups in depression measures (exact p-values not reported).
| SSRI(s): Paroxetine (and mirtazapine) | | Same results for Caucasian patients when analyzed alone.
| | | ANOVA showed no effect of concurrent medication that was a 2D6 inhibitor or substrate
Rau, Wohlleben, Wuttke, et al., 2004 | Geographical location: Germany | Age: Mean (SD): | 1) Genotypes/phenotypes in patient population: | Comments:; - Limitations: Race not specified, retrospective, mainly TCAs, low numbers, no comment on co-medications
#11550 | Dates: 2000-2002 | Adverse effects group: 50 (12) | Adverse effects group: 29% PM, 7% IM, 64% EM, 0% UM | Quality assessment: 3b
| Size of population: 28 with adverse effects associated with antidepressants; 16 non-responders to antidepressants | Non-responders: 45 (11) | Non-responders: 6% PM, 0% IM, 75% EM, 19% UM
| Method of CYP testing or product used:; - PCR-RFLP; - Long-range allele-specific PCR used for *5 allele | Weight: Mean (SD): | 2) Efficacy (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6 *3, *4, *6, *2, *8, *10, *14, *41, *5 | Adverse effects group: 75 kg (17) | [underlined: Non-responders:]
| SSRI(s): Various | Non-responders: 75 kg (13) | Various diagnoses (depression, dysthymia, adjustment disorder, etc.).
| | Race/ethnicity: NR (alludes to White) | Of the 16, 11 were treated with non-selective RIs, 5 with SSRIs.
| | Inclusion criteria: Marked adverse effects, or non-responders to 2D6-metabolized antidepressants (non-response requires sufficient dose for at least 4 weeks) | Of the 16, 4 (25%) had 2D6 gene duplication, i.e., 4/32 (12.5%) amplified functional alleles compared to 1.8% in German population (7-fold higher; p-value NR).
| | Exclusion criteria: NR | Of these, 3 were UM (18%), compared to 2.5 to 3% in the German population (5-fold increase; p = 0.0013)

Evidence Table 4. Question 3c: How well does CYP450 testing predict adverse drug reactions? Do factors such as race/ethnicity, diet, or other medications, affect this association?

Study | Study Design | Patient Characteristics | Results | | | | Comments/Quality Scoring
Allgulander and Nilsson, 2001 | Geographical location: Sweden | Age: Mean (SD): 40 (10) | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - The main objective of the study was to determine prognosis in newly diagnosed social anxiety disorder; - CYP2D6 genotype was analyzed in subjects randomized to paroxetine with the purpose of relating adverse effects to PM genotype.; - Limitations: Very small n, no comment on co-meds, diet, role of other CYP enzymes
#1490 | Dates: 1997-2000 | Weight: NR | 3 of 42 were PMs by this definition (*3, *4, *5). | | | | Quality assessment: 3b
| Size of population: 42 | Race/ethnicity: NR | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: Allele-specific PCR | Inclusion criteria: DSM-IV social anxiety disorder | Only outcome reported as comparison between PM and EM groups was rate of termination due to adverse events: 1/3 PMs and 2/39 EMs dropped out due to adverse events (p-value NR)
| Cytochromes (and specific mutations) tested for: 2D6 *3 *4 *5 | Exclusion criteria: Subjects with prior psychiatric treatment
| SSRI(s): Paroxetine 20–50 mg
Chen, Chou, Blouin, et al., 1996 | Geographical location: Kentucky | Age: NR | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Non-randomized, retrospective; - Article mainly deals with optimizing the time and cost associated with genotyping and phenotyping
#5970 | Dates: NR | Weight: NR | The frequency of A, B, D, E, and T alleles in a random group (n = 56) of depressed outpatients (21%) was similar to that in the general population (20%, p > 0.50). | | | | Quality assessment: 4
| Size of population: 74 | Race/ethnicity: NR | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: Multiple methods of DNA extraction, PCR | Inclusion criteria: Depressed outpatients (n = 56) and a smaller group of depressed patients who had adverse effects associated with 2D6-metabolized antidepressants (n = 18) | The frequency of alleles associated with deficient 2D6 gene expression (A, B, D, E, T) was significantly higher in depressed patients (44%) reporting adverse effects with antidepressants “known or suspected to be a substrate of” 2D6 (n = 18), compared to the random group (n = 56) of depressed patients (21%), p < 0.05
| Cytochromes (and specific mutations) tested for: 2D6 - A, B, D, E, and T alleles | Exclusion criteria: NR
| SSRI(s): Various, including paroxetine, fluoxetine, sertraline, fluvoxamine (and TCAs)
Gerstenberg, Aoshima, Fukasawa, et al., 2003 | Geographical location: Japan | Age: Median: 45 | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Heterogeneous group of patients, including inpatients, outpatients, different subtypes of depression; - Small numbers; - The same group reported in another study that 2D6 genotypes do not affect steady-state concentration of fluvoxamine and its metabolite, probably because of saturation of the enzyme.; - Effect of plasma concentration on response is not concordant with effect of genotype on response
#790 | Dates: NR | Range: 24–69 | Number of patients with no mutated alleles (EMs): 12 | | | | Quality assessment: 3b
| Size of population: 49 | Weight: Median: 55 kg | Number of patients with 1 mutated allele (IMs): 27
| Method of CYP testing or product used:; - Allele-specific PCR; - Long PCR, 2-step PCR; - Blinded to clinical ratings | Range: 40–84 kg | Number of patients with 2 mutated alleles (PMs): 10
| Cytochromes (and specific mutations) tested for: 2D6 *1, *3, *4, *5, *10 | Race/ethnicity: Japanese | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| SSRI(s): Fluvoxamine (50 mg 1^st^ week, 100 mg 2^nd^ week, and 200 mg in remaining 4 weeks) | Inclusion criteria: DSM-IV major depressive episode, no psychotic/atypical features; no other psychiatric disorders; MADRS ≥ 21; benzodiazepines permitted | Incidence of adverse effects (nausea) was not significantly different across the 3 groups
| | Exclusion criteria: Current antidepressant treatment, medical illness, medications in past 2 weeks
Grasmader, Verwohlt, Rietschel, et al., 2004 | Geographical location: Germany | Age: Mean (SD): 49 (14) | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Accounted for co-meds that are substrates/inhibitors/inducers of 5 major CYP enzymes; - HAMD and CGI used; - Cut-off for therapeutic plasma concentration (weekly trough levels measured); - UKU side effect rating scale used; - SSRIs and other meds (including TCAs, venlafaxine, mirtazapine); most results reported for entire group, not just for SSRIs; - Other treatments allowed (e.g., psychotherapy), some patients on multiple antidepressants. Numbers reported in analyses don't add up.; - Therapeutic levels not wellestablished for SSRIs.
#450 | Dates: 2000-2003 | Weight: Mean (SD): 76.3 kg (17.5) | Testing for CYP2C9 and 2C19 showed no significant differences with respect to allele frequencies and number of carriers of none, one, or two functional alleles (p = 0.445, p = 0.847. respectively) when compared with other Caucasian control groups. | | | | Quality assessment: 4
| Size of population: 136 total | Race/ethnicity: NR (refers to Caucasians in conclusion) | 2D6 PMs were underrepresented in the sample (p = 0.05) compared to 195 healthy volunteers (in literature).
| 70 (SSRIs) (68 blood concentrations?) | Inclusion criteria: ICD-10 diagnosis F3, CGI > 4, antidepressant therapy (including SSRIs) | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used:; - RFLP-PCR; - Positive and negative control samples | Exclusion criteria: Substance abuse/dependency, prior treatment with fluoxetine, acute suicidality, pregnancy, admission by legal commitment or for crisis intervention | 5/6 (83%) CYP2D6 PMs developed side effects at their first visit compared to 52/136 (38%) of the whole sample.
| Cytochromes (and specific mutations) tested for: CYP2C9 *1 to *3, CYP2C19*1 and *2, 2D6 *1 to *9 and gene duplication | | 2/4 (50%) CYP2C9 PMs developed side effects at their first visit.
| SSRI(s): Fluvoxamine, paroxetine, sertraline, citalopram | | 2/5 (40%) CYP2C19 PMs developed side effects at their first visit
Murphy, Kremer, Rodrigues, et al., 2003 | Geographical location: Multicenter, USA | Age: NR (reported for subgroups) | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Numbers do not add up for paroxetine or mirtazapine total N; - Patients grouped to improve strength, IMs may not be very different from EMs
#680 | Dates: NR | Weight: NR (reported for subgroups) | Frequency of common 2D6 alleles did not differ significantly from that reported in Caucasian populations. *10B was overrepresented in the sample (possibly because 15 ethnic minority patients in the sample). | | | | Quality assessment: 3b
| Size of population: | Race/ethnicity: NR | PM n = 16, IM n = 26, UM n = 10, EM n = 94.
| 124 paroxetine | Inclusion criteria: DSM-IV major depressive episode; 17-item HAMD score ≥ 18 | Because of small number of PMs and UMs, groups combined as follows for analyses: PM + IM vs. EM + UM.
| 122 mirtazapine | Exclusion criteria: < 65 yrs, major medical problems, MMSE < 25% percentile for age, clinically significant lab abnormalities, unstable medical conditions, drug or alcohol abuse, psychosis, recent suicide attempt, other psychiatric problems, antidepressant treatment within 7 days of starting study | For paroxetine: PM + IM n = 15, EM + UM, n = 105
| Method of CYP testing or product used:; - Oligonucleotide microarrays; - Scored by 2 observers blind to clinical data | | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6: 16 alleles, deletion, duplication, and *41 allele | | For both meds, no differences between PM + IM vs. EM + UM groups in severity of adverse events or frequency of discontinuation (exact p-values not reported).
| SSRI(s): Paroxetine (and mirtazapine) | | Same results for Caucasian patients when analyzed alone.
| | | ANOVA showed no effect of concurrent medication that was a 2D6 inhibitor or substrate
Rau, Wohlleben, Wuttke, et al., 2004 | Geographical location: Germany | Age: Mean (SD): | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Limitations: Race not specified, retrospective, mainly TCAs, low numbers, no comment on co-medications
#11550 | Dates: 2000-2002 | Adverse effects group: 50 (12) | Adverse effects group: 29% PM, 7% IM, 64% EM, 0% UM | | | | Quality assessment: 3b
| Size of population: 28 with adverse effects associated with antidepressants; 16 non-responders to antidepressants | Non-responders: 45 (11) | Non-responders: 6% PM, 0% IM, 75% EM, 19% UM
| Method of CYP testing or product used:; - PCR-RFLP; - Long-range allele-specific PCR used for *5 allele | Weight: Mean (SD): | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: 2D6 *3, *4, *6, *2, *8, *10, *14, *41, *5 | Adverse effects group: 75 kg (17) | [underlined: Adverse effects group]:
| SSRI(s): Various | Non-responders: 75 kg (13) | Various diagnoses (depression, dysthymia, adjustment disorder, etc.).
| | Race/ethnicity: NR (alludes to White) | Of the 28, 19 were treated with non-selective RIs, 9 with SSRIs.
| | Inclusion criteria: Marked adverse effects, or non-responders to 2D6-metabolized antidepressants (non-response requires sufficient dose for at least 4 weeks) | Of the 28, 8 (29%) were PMs compared to 7% in the German population (4-fold higher; p < 0.0001).
| | Exclusion criteria: NR | There were no differences between PMs, IMs, and EMs on frequency of dose reduction (p = 0.14), stopping treatment (p = 0.51), reducing or terminating antidepressant (p = 0.39), or number of adverse effects (p = 0.12)
Roberts, Mulder, Joyce, et al., 2004 | Geographical location: New Zealand | Age: Range: 18–64 | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - Strengths: No concurrent meds; 66% had no prior exposure to antidepressants; - Limitations: Small number of PMs; doses adjusted based on response and adverse effects; - Some subjects with ETOH/drug dependence still included
#600 | Dates: NR | Weight: NR | Of 125 patients, 115 were EMs and 10 were PMs. | | | | Quality assessment: 2b
| Size of population: 125 | Race/ethnicity: NR | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: PCR, RFLP, deletion/ duplication/rearrangement detected with southern blot, and long PCR | Inclusion criteria: Current major depressive episode | Of 125, 15% (10/65) of the fluoxetine group, and 30% (18/60) of the nortriptyline group did not complete an adequate 6-week trial (p = 0.05).
| Cytochromes (and specific mutations) tested for: 2D6 alleles *1 to * 16, *19, *20 | Exclusion criteria: Current moderate/severe alcohol/drug dependence (if it was the principal diagnosis); history of mania or schizophrenia; major medical illness; psychotropic medication in past 2 weeks (except occasional hypnotic) | Metabolizer status had no impact on dropping out of the trial (p-value NR): EM dropouts 22% (25/115), PM dropouts 30% (3/10).
| SSRI(s): Fluoxetine, (randomized to fluoxetine or nortriptyline) | | PMs (n = 10) were no more likely to develop adverse effects than EMs (n = 115; p-value NR).
| | | 17% of PMs (1/6) and 41% of EMs (24/59) in fluoxetine groups experienced adverse effects
Suzuki, Sawamura, and Someya, 2006 | Geographical location: Nigatta, Japan | Age: Mean (SD): 40 (15.7) | 1) Genotypes/ phenotypes in patient population: | | | | Comments:; - Data missing for 3 subjects; - Study further showed that 5HT2A receptor gene polymorphism and CYP2D6 polymorphism had a synergistic effect for predicting fluvoxamine-induced GI side effects.
#13770 | Dates: NR | Weight: NR | EM: 75 (77%) | | | | Quality assessment: 3b
| Size of population: 100 | Race/ethnicity (n [%]): Japanese 100% | PM: 22 (23%)
| Method of CYP testing or product used: PCR, long PCR | Inclusion criteria: Mood disorder (depressive disorder not otherwise specified, major depression, bipolar disorder, depressed, adjustment disorder, depressed) | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Cytochromes (and specific mutations) tested for: CYP2D6 *5, *10 | Exclusion criteria: Obvious physical illness, psychotropic medication in 14 days before study entry, additional Axis I or II diagnoses | Greater prevalence of GI side effects in PMs compared to EMs (p = 0.043, CI 1.019 to 3.254). No significant difference in cumulative number of GI side effects or all side effects between the groups.
| SSRI(s): Fluvoxamine 25–200 mg | | Discontinuation rates similar between PMs and EMs (p = 0.310).
| | | Combination of 5HT2A receptor polymorphism and CYP 4502D6 polymorphism in predicting GI side effects:
| | | Polymorphisms | Hazard ratio | 95% CI | P-value
| | | PM, AA | 0.859 | 0.179 to 4.122 | 0.849
| | | EM, AG | 1.681 | 0.717 to 3.939 | 0.234
| | | PM, AG | 4.147 | 1.558 to 11.038 | 0.004
| | | EM, GG | 2.491 | 0.997 to 6.223 | 0.051
| | | PM, GG | 4.242 | 1.444 to 12.459 | 0.009
| | | PM +GG and PM +AG had a significantly greater risk of developing GI side effects compared to EM + AA
Wang, Liu, Wang, et al., 2001 | Geographical location: China | Age: Mean (SD): 20 (1) | 1) Genotypes/phenotypes in patient population: | | | | Comments:; - CYP2C19 PMs more common in Asians (13–23%) compared to Caucasians (2–5%); - Did not take into account the role of other CYPs in sertraline metabolism
#1450 | Dates: NR | Range: 19–22 | Of 77 young, healthy Chinese Han subjects tested, 14.3% were PMs and 85.7% EMs. Of these, 6 PMs and 6 EMs were selected by stratified random sampling. | | | | Quality assessment: 4
| Size of population: 12 unrelated healthy males | Weight: Mean (SD): 65 kg (7) | 2) Adverse drug reactions (including effect of race/ethnicity, diet, and other medications):
| Method of CYP testing or product used: RFLP-PCR | Range: 54–80 kg | 2 of 6 homozygous PMs had severe GI side effects (nausea, vomiting, diarrhea) and CNS dry mouth and dizziness 2 hours after a single 100-mg sertraline dose
| Cytochromes (and specific mutations) tested for: 2C19 *1, *2, *3 | Race/ethnicity: Chinese Han - 100%
| SSRI(s): Sertraline 100 mg | Inclusion criteria: Healthy (by history, physical exam, and labs), male, non-smokers
| | Exclusion criteria: Medication, ethanol 2 weeks before study

## References Cited in the Evidence Tables

Allgulander C, Nilsson B. A prospective study of 86 new patients with social anxiety disorder. Acta Psychiatr Scand. 2001;103(6):447-52. [pmid: 11401659].
Berle JO, Steen VM, Aamo TO, et al. Breastfeeding during maternal antidepressant treatment with serotonin reuptake inhibitors: infant exposure, clinical symptoms, and cytochrome p450 genotypes. J Clin Psychiatry. 2004;65(9):1228-34. [pmid: 15367050].
Charlier C, Broly F, Lhermitte M, et al. Polymorphisms in the CYP 2D6 gene: association with plasma concentrations of fluoxetine and paroxetine. Ther Drug Monit. 2003;25(6):738-42. [pmid: 14639062].
Chen S, Chou WH, Blouin RA, et al. The cytochrome P450 2D6 (CYP2D6) enzyme polymorphism: screening costs and influence on clinical outcomes in psychiatry. Clin Pharmacol Ther. 1996;60(5):522-34. [pmid: 8941025].
Chou WH, Yan FX, Robbins-Weilert DK, et al. Comparison of two CYP2D6 genotyping methods and assessment of genotype-phenotype relationships. Clin Chem. 2003;49(4):542-51. [pmid: 12651805].
Eap CB, Bondolfi G, Zullino D, et al. Concentrations of the enantiomers of fluoxetine and norfluoxetine after multiple doses of fluoxetine in cytochrome P4502D6 poor and extensive metabolizers. J Clin Psychopharmacol. 2001;21(3):330-4. [pmid: 11386497].
Eriksson S, Berg LM, Wadelius M, et al. Cytochrome p450 genotyping by multiplexed real-time DNA sequencing with pyrosequencing technology. Assay Drug Dev Technol. 2002;1(1 Pt 1):49-59. [pmid: 15090156].
Gerstenberg G, Aoshima T, Fukasawa T, et al. Relationship between clinical effects of fluvoxamine and the steady-state plasma concentrations of fluvoxamine and its major metabolite fluvoxamino acid in Japanese depressed patients. Psychopharmacology (Berl). 2003;167(4):443-8. [pmid: 12682708].
Grasmader K, Verwohlt PL, Rietschel M, et al. Impact of polymorphisms of cytochrome-P450 isoenzymes 2C9, 2C19 and 2D6 on plasma concentrations and clinical effects of antidepressants in a naturalistic clinical setting. Eur J Clin Pharmacol. 2004;60(5):329-36. [pmid: 15168101].
Hersberger M, Marti-Jaun J, Rentsch K, et al. Rapid detection of the CYP2D6*3, CYP2D6*4, and CYP2D6*6 alleles by tetra-primer PCR and of the CYP2D6*5 allele by multiplex long PCR. Clin Chem. 2000;46(8 Pt 1):1072-7. [pmid: 10926885].
Kawanishi C, Lundgren S, Agren H, et al. Increased incidence of CYP2D6 gene duplication in patients with persistent mood disorders: ultrarapid metabolism of antidepressants as a cause of nonresponse. A pilot study. Eur J Clin Pharmacol. 2004;59(11):803-7. [pmid: 14652703].
Liu ZQ, Cheng ZN, Huang SL, et al. Effect of the CYP2C19 oxidation polymorphism on fluoxetine metabolism in Chinese healthy subjects. Br J Clin Pharmacol. 2001;52(1):96-9. [pmid: 11453896]. [pmcid: 2014504].
LLerena A, Dorado P, Berecz R, et al. Effect of CYP2D6 and CYP2C9 genotypes on fluoxetine and norfluoxetine plasma concentrations during steady-state conditions. Eur J Clin Pharmacol. 2004;59(12):869-73. [pmid: 14726986].
Mizugaki M, Hiratsuka M, Agatsuma Y, et al. Rapid detection of CYP2C18 genotypes by real-time fluorescence polymerase chain reaction. J Pharm Pharmacol. 2000;52(2):199-205. [pmid: 10714950].
Muller B, Zopf K, Bachofer J, et al. Optimized strategy for rapid cytochrome P450 2D6 genotyping by real-time long PCR. Clin Chem. 2003;49(10):1624-31. [pmid: 14500587].
Murphy GM Jr, Kremer C, Rodrigues HE, et al. Pharmacogenetics of antidepressant medication intolerance. Am J Psychiatry. 2003;160(10):1830-5. [pmid: 14514498].
Muthiah YD, Lee WL, Teh LK, et al. A simple multiplex PCR method for the concurrent detection of three CYP2C8 variants. Clin Chim Acta. 2004;349(12):191-8. [pmid: 15469873].
Neville M, Selzer R, Aizenstein B, Characterization of cytochrome P450 2D6 alleles using the Invader system. Biotechniques 2002;Suppl:34–8, 40–3.
Ohara K, Tanabu S, Ishibashi K, et al. CYP2D6*10 alleles do not determine plasma fluvoxamine concentration/dose ratio in Japanese subjects. Eur J Clin Pharmacol. 2003;58(10):659-61. [pmid: 12610741].
Ozdemir V, Tyndale RF, Reed K, et al. Paroxetine steady-state plasma concentration in relation to CYP2D6 genotype in extensive metabolizers. J Clin Psychopharmacol. 1999;19(5):472-5. [pmid: 10505591].
Rau T, Wohlleben G, Wuttke H, et al. CYP2D6 genotype: impact on adverse effects and nonresponse during treatment with antidepressants-a pilot study. Clin Pharmacol Ther. 2004;75(5):386-93. [pmid: 15116051].
Roberts RL, Mulder RT, Joyce PR, et al. No evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline. Hum Psychopharmacol. 2004;19(1):17-23. [pmid: 14716707].
Roche Molecular Systems, Inc. U.S. Food and Drug Administration 510(k) Substantial Equivalence Determination Decision Summary for Roche AmpliChip CYP450 microarray for identifying CYP2D6 genotype (510(k) Number k042259). December 2004. Available at: www.fda.gov/cdrh/reviews/k042259.pdf. Accessed 19 April 2006.
Roche Molecular Systems, Inc. U.S. Food and Drug Administration 510(k) Substantial Equivalence Determination Decision Summary for Roche AmpliChip CYP450 microarray for identifying CYP2C19 genotype (510(k) Number k043576). January 2005. Available at: www.fda.gov/cdrh/reviews/k043576.pdf. Accessed 19 April 2006.
Sawamura K, Suzuki Y, Someya T. Effects of dosage and CYP2D6-mutated allele on plasma concentration of paroxetine. Eur J Clin Pharmacol. 2004;60(8):553-7. [pmid: 15349705].
Schaeffeler E, Schwab M, Eichelbaum M, et al. CYP2D6 genotyping strategy based on gene copy number determination by TaqMan real-time PCR. Hum Mutat. 2003;22(6):476-85. [pmid: 14635107].
Scordo MG, Spina E, Dahl ML, et al. Influence of CYP2C9, 2C19 and 2D6 genetic polymorphisms on the steady-state plasma concentrations of the enantiomers of fluoxetine and norfluoxetine. Basic Clin Pharmacol Toxicol. 2005;97(5):296-301. [pmid: 16236141].
Soderback E, Zackrisson AL, Lindblom B, et al. Determination of CYP2D6 gene copy number by pyrosequencing. Clin Chem. 2005;51(3):522-31. [pmid: 15650034].
Stamer UM, Bayerer B, Wolf S, et al. Rapid and reliable method for cytochrome P450 2D6 genotyping. Clin Chem. 2002;48(9):1412-7. [pmid: 12194916].
Stedman CA, Begg EJ, Kennedy MA, et al. Cytochrome P450 2D6 genotype does not predict SSRI (fluoxetine or paroxetine) induced hyponatraemia. Hum Psychopharmacol. 2002;17(4):187-90. [pmid: 12404686].
Suzuki Y, Sawamura K, Someya T. Polymorphisms in the 5-hydroxytryptamine 2A receptor and cytochromeP4502d6 genes synergistically predict fluvoxamine-induced side effects in Japanese depressed patients. Neuropsychopharmacology. 2006;31(4):825-31. [pmid: 16205777].
Ueda M, Hirokane G, Morita S, et al. The impact of CYP2D6 genotypes on the plasma concentration of paroxetine in Japanese psychiatric patients. Prog Neuropsychopharmacol Biol Psychiatry. 2006;30(3):486-91. [pmid: 16423440].
Wang JH, Liu ZQ, Wang W, et al. Pharmacokinetics of sertraline in relation to genetic polymorphism of CYP2C19. Clin Pharmacol Ther. 2001;70(1):42-7. [pmid: 11452243].
Weise A, Grundler S, Zaumsegel D, et al. Development and evaluation of a rapid and reliable method for cytochrome P450 2C8 genotyping. Clin Lab. 2004;50(34):141-8. [pmid: 15074466].
Wu X, Zhou Y, Xu S. Detection of CYP I A1 polymorphisms with a colorimetric method based on mismatch hybridization. Clin Chim Acta. 2002;323(12):103-9. [pmid: 12135810].
Yoon YR, Cha IJ, Shon JH, et al. Relationship of paroxetine disposition to metoprolol metabolic ratio and CYP2D6*10 genotype of Korean subjects. Clin Pharmacol Ther. 2000;67(5):567-76. [pmid: 10824636].
Yu BN, Chen GL, He N, et al. Pharmacokinetics of citalopram in relation to genetic polymorphism of CYP2C19. Drug Metab Dispos. 2003;31(10):1255-9. [pmid: 12975335].