# Appendix B. List of Excluded Studies

All excluded studies listed below were reviewed in their full-text version. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## References

Alderman J, Preskorn SH, Greenblatt DJ, et al. Desipramine pharmacokinetics when coadministered with paroxetine or sertraline in extensive metabolizers. J Clin Psychopharmacol. 1997;17(4):284-91. Exclude: falls outside study scope. [pmid: 9241008].
Arias B, Catalan R, Gasto C, et al. Evidence for a combined genetic effect of the 5-HT(1A) receptor and serotonin transporter genes in the clinical outcome of major depressive patients treated with citalopram. J Psychopharmacol. 2005;19(2):166-72. Exclude: falls outside study scope. [pmid: 15728438].
Baker SC, Bauer SR, Beyer RP, et al. The external RNA controls consortium: a progress report. Nat Methods. 2005;2(10):731-4. Exclude: falls outside study scope. [pmid: 16179916].
Ball C, Brazma A, Causton H, et al. Standards for microarray data: an open letter. Environ Health Perspect. 2004;112(12):A666-7. Exclude: falls outside study scope. [pmid: 15121508]. [pmcid: 1241959].
Ball SE, Scatina J, Kao J, et al. Population distribution and effects on drug metabolism of a genetic variant in the 5′ promoter region of CYP3A4. Clin Pharmacol Ther. 1999;66(3):288-94. Exclude: falls outside study scope. [pmid: 10511065].
Bartoletti RA, Belpaire FM, Rosseel MT. High performance liquid chromatography determination of dextromethorphan and its metabolites in urine using solid-phase extraction. J Pharm Biomed Anal. 1996;14(810):1281-86. Exclude: falls outside study scope. [pmid: 8818046].
Bertilsson L, Dahl ML, Tybring G. Pharmacogenetics of antidepressants: clinical aspects. Acta Psychiatr Scand Suppl. 1997;391:14-21. Exclude: falls outside study scope. [pmid: 9265947].
Bramness JG, Skurtveit S, Fauske L, et al. Association between blood carisoprodol:meprobamate concentration ratios and CYP2C19 genotype in carisoprodol-drugged drivers: decreased metabolic capacity in heterozygous CYP2C19*1/CYP2C19*2 subjects?. Pharmacogenetics. 2003;13(7):383-8. Exclude: falls outside study scope. [pmid: 12835613].
Britzi M, Bialer M, Arcavi L, et al. Genetic polymorphism of CYP2D6 and CYP2C19 metabolism determined by phenotyping Israeli ethnic groups. Ther Drug Monit. 2000;22(5):510-6. Exclude: falls outside study scope. [pmid: 11034254].
Brosen K, Hansen JG, Nielsen KK, et al. Inhibition by paroxetine of desipramine metabolism in extensive but not in poor metabolizers of sparteine. Eur J Clin Pharmacol. 1993;44(4):349-55. Exclude: falls outside study scope. [pmid: 8513845].
Brosen K, Nielsen PN, Brusgaard K, et al. CYP2D6 genotype determination in the Danish population. Eur J Clin Pharmacol. 1994;47(3):221-5. Exclude: falls outside study scope. [pmid: 7867674].
Butcher LM, Meaburn E, Dale PS, et al. Association analysis of mild mental impairment using DNA pooling to screen 432 brain-expressed single-nucleotide polymorphisms. Mol Psychiatry. 2005;10(4):384-92. Exclude: falls outside study scope. [pmid: 15452586].
Cardoso J, Molenaar L, de Menezes RX, et al. Genomic profiling by DNA amplification of laser capture microdissected tissues and array CGH. Nucleic Acids Res. 2004;32(19):e146. Exclude: falls outside study scope. [pmid: 15514107].
Carter DE, Robinson JF, Allister EM, et al. Quality assessment of microarray experiments. Clin Biochem. 2005;38(7):639-42. Exclude: falls outside study scope. [pmid: 15923000].
Chen DT. A graphical approach for quality control of oligonucleotide array data. J Biopharm Stat. 2004;14(3):591-606. Exclude: falls outside study scope. [pmid: 15468754].
Chrimes D. How can data quality and automation enhance confidence in microarray data?. Drug Discov Today. 2005;10(10):675-7. Exclude: falls outside study scope. [pmid: 15896675].
Cronin M, Ghosh K, Sistare F, et al. Universal RNA reference materials for gene expression.[see comment]. Clin Chem. 2004;50(8):1464-71. Exclude: falls outside study scope. [pmid: 15155546].
Daly TM, Dumaual CM, Dotson CA, et al. Precision profiling and components of variability analysis for Affymetrix microarray assays run in a clinical context. J Mol Diagn. 2005;7(3):404-12. Exclude: falls outside study scope. [pmid: 16049313]. [pmcid: 1867543].
Datta S, Satten GA, Benos DJ, et al. An empirical Bayes adjustment to increase the sensitivity of detecting differentially expressed genes in microarray experiments. Bioinformatics. 2004;20(2):235-42. Exclude: falls outside study scope. [pmid: 14734315].
DeVane CL. Pharmacogenetics and drug metabolism of newer antidepressant agents.[see comment]. J Clin Psychiatry. 1994;55(Suppl):38-45. discussion 46–7. Exclude: falls outside study scope. [pmid: 7814357].
Dombkowski AA, Thibodeau BJ, Starcevic SL, et al. Gene-specific dye bias in microarray reference designs. FEBS Lett. 2004;560(13):120-4. Exclude: falls outside study scope. [pmid: 14988009].
Dorne JL. Impact of inter-individual differences in drug metabolism and pharmacokinetics on safety evaluation. Fundam Clin Pharmacol. 2004;18(6):609-20. Exclude: falls outside study scope. [pmid: 15548231].
Dozmorov I, Knowlton N, Tang Y, et al. Statistical monitoring of weak spots for improvement of normalization and ratio estimates in microarrays. BMC Bioinformatics. 2004;5(1):53. Exclude: falls outside study scope. [pmid: 15128432]. [pmcid: 415561].
Futschik M, Crompton T. Model selection and efficiency testing for normalization of cDNA microarray data. Genome Biol. 2004;5(8):R60. Exclude: falls outside study scope. [pmid: 15287982].
Gautier L, Moller M, Friis-Hansen L, et al. Alternative mapping of probes to genes for Affymetrix chips. BMC Bioinformatics. 2004;5(1):111. Exclude: falls outside study scope. [pmid: 15310390]. [pmcid: 514699].
Gillman PK. Re: no evidence of increased adverse drug reactions in cytochrome P450 CYP2D6 poor metabolizers treated with fluoxetine or nortriptyline.[comment]. Hum Psychopharmacol. 2005;20(1):61-2. author reply 63–4. Exclude: falls outside study scope. [pmid: 15614840].
Gingeras TR. RNA reference materials for gene expression studies. Difficult first steps.[see comment][comment]. Clin Chem. 2004;50(8):1289-90. Exclude: falls outside study scope. [pmid: 15277341].
Ginsberg DL. Pharmacogenomics: genetic markers predict intolerance to paroxetine. Prim Psychiatry. 2003;10(12):17-8. Exclude: review.
Griese EU, Lapple F, Eichelbaum M. Detection of CYP2C19 alleles *1, *2 and *3 by multiplex polymerase chain reaction. Pharmacogenetics. 1999;9(3):389-91. Exclude: falls outside study scope. [pmid: 10471071].
Hesse LM, Venkatakrishnan K, Court MH, et al. CYP2B6 mediates the in vitro hydroxylation of bupropion: potential drug interactions with other antidepressants. Drug Metab Dispos. 2000;28(10):1176-83. Exclude: falls outside study scope. [pmid: 10997936].
Hoerndli FJ, Toigo M, Schild A, et al. Reference genes identified in SH-SY5Y cells using custom-made gene arrays with validation by quantitative polymerase chain reaction. Anal Biochem. 2004;335(1):30-41. Exclude: falls outside study scope. [pmid: 15519568].
Ishiguro A, Kubota T, Soya Y, et al. High-throughput detection of multiple genetic polymorphisms influencing drug metabolism with mismatch primers in allele-specific polymerase chain reaction.[erratum appears in Anal Biochem. 2005 Aug 15;343(2):359]. Anal Biochem. 2005;337(2):256-61. Exclude: no reference standard. [pmid: 15691505].
Jan MW, ZumBrunnen TL, Kazmi YR, et al. Pharmacokinetics of fluvoxamine in relation to CYP2C19 phenotype and genotype. Drug Metabol Drug Interact. 2002;19(1):1-11. Exclude: probe drug metabolism defined CYP status. [pmid: 12222750].
Jarvinen AK, Hautaniemi S, Edgren H, et al. Are data from different gene expression microarray platforms comparable?. Genomics. 2004;83(6):1164-8. Exclude: falls outside study scope. [pmid: 15177569].
Jeppesen U, Gram LF, Vistisen K, et al. Dose-dependent inhibition of CYP1A2, CYP2C19 and CYP2D6 by citalopram, fluoxetine, fluvoxamine and paroxetine. Eur J Clin Pharmacol. 1996;51(1):73-8. Exclude: falls outside study scope. [pmid: 8880055].
Jin P, Zhao Y, Ngalame Y, et al. Selection and validation of endogenous reference genes using a high throughput approach. BMC Genomics. 2004;5(1):55. Exclude: falls outside study scope. [pmid: 15310404]. [pmcid: 516027].
Joseph LJ. RNA reference materials for gene expression studies. RNA metrology: forecast calls for partial clearing.[comment]. Clin Chem. 2004;50(8):1290-2. Exclude: falls outside study scope. [pmid: 15277342].
Kaneda Y, Kawamura I, Fujii A, et al. Serotonin syndrome - ‘potential’ role of the CYP2D6 genetic polymorphism in Asians. Int J Neuropsychopharmacol. 2002;5(1):105-6. Exclude: single case. [pmid: 12057035].
Kawanishi C, Hanihara T, Maruyama Y, et al. Neuroleptic malignant syndrome and hydroxylase gene mutations: no association with CYP2D6A or CYP2D6B. Psychiatr Genet. 1997;7(3):127-9. Exclude: falls outside study scope. [pmid: 9323326].
Kirchheiner J, Bertilsson L, Bruus H, et al. Individualized medicine - implementation of pharmacogenetic diagnostics in antidepressant drug treatment of major depressive disorders. Pharmacopsychiatry. 2003;36(Suppl 3):S235-43. Exclude: falls outside study scope. [pmid: 14677085].
Kirchheiner J, Brosen K, Dahl ML, et al. CYP2D6 and CYP2C19 genotype-based dose recommendations for antidepressants: a first step towards subpopulation-specific dosages.[erratum appears in Acta Psychiatr Scand 2001 Dec;104(6):475]. Acta Psychiatr Scand. 2001;104(3):173-92. Exclude: falls outside study scope. [pmid: 11531654].
Kirchheiner J, Meineke I, Muller G, et al. Contributions of CYP2D6, CYP2C9 and CYP2C19 to the biotransformation of E- and Z-doxepin in healthy volunteers. Pharmacogenetics. 2002;12(7):571-80. Exclude: falls outside study scope. [pmid: 12360109].
Kitagawa K, Kunugita N, Katoh T, et al. The significance of the homozygous CYP2A6 deletion on nicotine metabolism: a new genotyping method of CYP2A6 using a single PCR-RFLP. Biochem Biophys Res Commun. 1999;262(1):146-51. Exclude: falls outside study scope. [pmid: 10448083].
Kohler D, Hartter S, Fuchs K, et al. CYP2D6 genotype and phenotyping by determination of dextromethorphan and metabolites in serum of healthy controls and of patients under psychotropic medication. Pharmacogenetics. 1997;7(6):453-61. Exclude: drug interaction between SSRIs and CYP genotypes. [pmid: 9429230].
Kraus RP, Diaz P, McEachran A. Managing rapid metabolizers of antidepressants. Depress Anxiety 1996-1997;4(6):32–7. Exclude: probe drug metabolism defined CYP status.
Kuhn K, Baker SC, Chudin E, et al. A novel, high-performance random array platform for quantitative gene expression profiling. Genome Res. 2004;14(11):2347-56. Exclude: falls outside study scope. [pmid: 15520296]. [pmcid: 525694].
Lam YW, Gaedigk A, Ereshefsky L, et al. CYP2D6 inhibition by selective serotonin reuptake inhibitors: analysis of achievable steady-state plasma concentrations and the effect of ultrarapid metabolism at CYP2D6. Pharmacotherapy. 2002;22(8):1001-6. Exclude: probe drug metabolism defined CYP status. [pmid: 12173784].
Le Meur N, Lamirault G, Bihouee A, et al. A dynamic, web-accessible resource to process raw microarray scan data into consolidated gene expression values: importance of replication. Nucleic Acids Res. 2004;32(18):5349-58. Exclude: falls outside study scope. [pmid: 15475389]. [pmcid: 524282].
Lee AJ, Chan WK, Harralson AF, et al. The effects of grapefruit juice on sertraline metabolism: an in vitro and in vivo study. Clin Ther. 1999;21(11):1890-9. Exclude: falls outside study scope. [pmid: 10890261].
Lessard E, Yessine MA, Hamelin BA, et al. Influence of CYP2D6 activity on the disposition and cardiovascular toxicity of the antidepressant agent venlafaxine in humans. Pharmacogenetics. 1999;9(4):435-43. Exclude: falls outside study scope. [pmid: 10780263].
Liston HL, DeVane CL, Boulton DW, et al. Differential time course of cytochrome P450 2D6 enzyme inhibition by fluoxetine, sertraline, and paroxetine in healthy volunteers. J Clin Psychopharmacol. 2002;22(2):169-73. Exclude: falls outside study scope. [pmid: 11910262].
Liu ZQ, Shu Y, Huang SL, et al. Effects of CYP2C19 genotype and CYP2C9 on fluoxetine N-demethylation in human liver microsomes. Acta Pharmacol Sin. 2001;22(1):85-90. Exclude: falls outside study scope. [pmid: 11730569].
Malhotra AK, Murphy GM Jr, Kennedy JL. Pharmacogenetics of psychotropic drug response. Am J Psychiatry. 2004;161(5):780-96. Exclude: falls outside study scope. [pmid: 15121641].
McConnachie L, Bodor M, Kowdley K, et al. Human liver cytochrome P450 2D6 genotype, full-length messenger ribonucleic acid, and activity assessed with a novel cytochrome P450 2D6 substrate. Clin Pharmacol Ther. 2004;75(4):282-97. Exclude: falls outside study scope. [pmid: 15060507].
McGall GH, Christians FC. High-density genechip oligonucleotide probe arrays. Adv Biochem Eng Biotechnol. 2002;77:21-42. Exclude: falls outside study scope. [pmid: 12227735].
Meyer UA, Amrein R, Balant LP, et al. Antidepressants and drug-metabolizing enzymes—expert group report. Acta Psychiatr Scand. 1996;93(2):71-9. Exclude: falls outside study scope. [pmid: 8686486].
Mihara K, Otani K, Suzuki A, et al. Relationship between the CYP2D6 genotype and the steady-state plasma concentrations of trazodone and its active metabolite m-chlorophenylpiperazine. Psychopharmacology (Berl). 1997;133(1):95-8. Exclude: falls outside study scope. [pmid: 9335086].
Nannya Y, Sanada M, Nakazaki K, et al. A robust algorithm for copy number detection using high-density oligonucleotide single nucleotide polymorphism genotyping arrays. Cancer Res. 2005;65(14):6071-9. Exclude: falls outside study scope. [pmid: 16024607].
Neuhaus T, Geisen G, Bolt HM, et al. Reliability of non-invasively acquired human genomic DNA as a substrate for real-time PCR-assisted analysis of genetic polymorphisms. Arch Toxicol. 2004;78(7):390-6. Exclude: falls outside study scope. [pmid: 15007541].
Nguyen LT, Ramanathan M, Weinstock-Guttman B, et al. Detection of cytochrome P450 and other drug-metabolizing enzyme mRNAs in peripheral blood mononuclear cells using DNA arrays. Drug Metab Dispos. 2000;28(8):987-93. Exclude: falls outside study scope. [pmid: 10901711].
Nishimura M, Yaguti H, Yoshitsugu H, et al. Tissue distribution of mRNA expression of human cytochrome P450 isoforms assessed by high-sensitivity real-time reverse transcription PCR. Yakugaku Zasshi. 2003;123(5):369-75. Exclude: falls outside study scope. [pmid: 12772594].
Nishimura M, Yoshitsugu H, Naito S, et al. Evaluation of gene induction of drug-metabolizing enzymes and transporters in primary culture of human hepatocytes using high-sensitivity real-time reverse transcription PCR. Yakugaku Zasshi. 2002;122(5):339-61. Exclude: falls outside study scope. [pmid: 12040753].
Novoradovskaya N, Whitfield ML, Basehore LS, et al. Universal reference RNA as a standard for microarray experiments. BMC Genomics. 2004;5(1):20. Exclude: falls outside study scope. [pmid: 15113400]. [pmcid: 394318].
Oba S, Sato MA, Takemasa I, et al. A Bayesian missing value estimation method for gene expression profile data. Bioinformatics. 2003;19(16):2088-96. Exclude: falls outside study scope. [pmid: 14594714].
Obach RS, Cox LM, Tremaine LM. Sertraline is metabolized by multiple cytochrome P450 enzymes, monoamine oxidases, and glucuronyl transferases in human: an in vitro study. Drug Metab Dispos. 2005;33(2):262-70. Exclude: falls outside study scope. [pmid: 15547048].
Olesen OV, Linnet K. Studies on the stereoselective metabolism of citalopram by human liver microsomes and cDNA-expressed cytochrome P450 enzymes. Pharmacology. 1999;59(6):298-309. Exclude: falls outside study scope. [pmid: 10575324].
Olesen OV, Linnet K. Fluvoxamine-clozapine drug interaction: inhibition in vitro of five cytochrome P450 isoforms involved in clozapine metabolism.[see comment]. J Clin Psychopharmacol. 2000;20(1):35-42. Exclude: falls outside study scope. [pmid: 10653206].
Ozdemir V, Naranjo CA, Herrmann N, et al. The extent and determinants of changes in CYP2D6 and CYP1A2 activities with therapeutic doses of sertraline. J Clin Psychopharmacol. 1998;18(1):55-61. Exclude: falls outside study scope. [pmid: 9472843].
Ozminkowski RJ, Hylan TR, Melfi CA, et al. Economic consequences of selective serotonin reuptake inhibitor use with drugs also metabolized by the cytochrome P-450 system. Clin Ther. 1998;20(4):780-96. Exclude: falls outside study scope. [pmid: 9737837].
Pavlidis P, Li Q, Noble WS. The effect of replication on gene expression microarray experiments. Bioinformatics. 2003;19(13):1620-7. Exclude: falls outside study scope. [pmid: 12967957].
Perucca E, Marchioni E, Soragna D, et al. Fluoxetine-induced movement disorders and deficient CYP2D6 enzyme activity.[comment]. Mov Disord. 1997;12(4):624-5. Exclude: falls outside study scope. [pmid: 9251094].
Preskorn SH. Effects of antidepressants on the cytochrome P450 system.[comment]. Am J Psychiatry. 1996;153(12):1655-7. Exclude: falls outside study scope. [pmid: 8942473].
Rai AJ, Gelfand CA, Haywood BC, et al. HUPO Plasma Proteome Project specimen collection and handling: towards the standardization of parameters for plasma proteome samples. Proteomics. 2005;5(13):3262-77. Exclude: falls outside study scope. [pmid: 16052621].
Raimundo S, Toscano C, Klein K, et al. A novel intronic mutation, 2988G>A, with high predictivity for impaired function of cytochrome P450 2D6 in white subjects.[see comment]. Clin Pharmacol Ther. 2004;76(2):128-38. Exclude: falls outside study scope. [pmid: 15289790].
Ramamoorthy Y, Tyndale RF, Sellers EM. Cytochrome P450 2D6.1 and cytochrome P450 2D6.10 differ in catalytic activity for multiple substrates. Pharmacogenetics. 2001;11(6):477-87. Exclude: falls outside study scope. [pmid: 11505218].
Rodriguez-Antona C, Jover R, Gomez-Lechon MJ, et al. Quantitative RT-PCR measurement of human cytochrome P-450s: application to drug induction studies. Arch Biochem Biophys. 2000;376(1):109-16. Exclude: falls outside study scope. [pmid: 10729196].
Sallee FR, DeVane CL, Ferrell RE. Fluoxetine-related death in a child with cytochrome P-450 2D6 genetic deficiency. J Child Adolesc Psychopharmacol. 2000;10(1):27-34. Exclude: review. [pmid: 10755579].
Sato A, Okura Y, Minagawa S, et al. Life-threatening serotonin syndrome in a patient with chronic heart failure and CYP2D6*1/*5. Mayo Clin Proc. 2004;79(11):1444-8. Exclude: single case. [pmid: 15544025].
Saviozzi S, Iazzetti G, Caserta E, et al. Microarray data analysis and mining. Methods Mol Med. 2004;94:67-90. Exclude: falls outside study scope. [pmid: 14959823].
Schur BC, Bjerke J, Nuwayhid N, et al. Genotyping of cytochrome P450 2D6*3 and *4 mutations using conventional PCR. Clin Chim Acta. 2001;308(12):25-31. Exclude: no reference standard. [pmid: 11412814].
Sindrup SH, Brosen K, Gram LF. Pharmacokinetics of the selective serotonin reuptake inhibitor paroxetine: nonlinearity and relation to the sparteine oxidation polymorphism. Clin Pharmacol Ther. 1992;51(3):288-95. Exclude: probe drug metabolism defined CYP status. [pmid: 1531951].
Sindrup SH, Brosen K, Gram LF, et al. The relationship between paroxetine and the sparteine oxidation polymorphism. Clin Pharmacol Ther. 1992;51(3):278-87. Exclude: probe drug metabolism defined CYP status. [pmid: 1531950].
Sindrup SH, Brosen K, Hansen MG, et al. Pharmacokinetics of citalopram in relation to the sparteine and the mephenytoin oxidation polymorphisms. Ther Drug Monit. 1993;15(1):11-7. Exclude: probe drug metabolism defined CYP status. [pmid: 8451774].
Spigset O, Hedenmalm K, Dahl ML, et al. Seizures and myoclonus associated with antidepressant treatment: assessment of potential risk factors, including CYP2D6 and CYP2C19 polymorphisms, and treatment with CYP2D6 inhibitors. Acta Psychiatr Scand. 1997;96(5):379-84. Exclude: drug interaction between SSRIs and CYP genotypes. [pmid: 9395157].
Sproule BA, Otton SV, Cheung SW, et al. CYP2D6 inhibition in patients treated with sertraline. J Clin Psychopharmacol. 1997;17(2):102-6. Exclude: falls outside study scope. [pmid: 10950472].
Stahl SM. Not so selective serotonin reuptake inhibitors. J Clin Psychiatry. 1998;59(7):343-4. Exclude: falls outside study scope. [pmid: 9714261].
Stahl SM. Using secondary binding properties to select a not so selective serotonin reuptake inhibitor. J Clin Psychiatry. 1998;59(12):642-3. Exclude: falls outside study scope. [pmid: 9921697].
Steimer W, Zopf K, von Amelunxen S, et al. Allele-specific change of concentration and functional gene dose for the prediction of steady-state serum concentrations of amitriptyline and nortriptyline in CYP2C19 and CYP2D6 extensive and intermediate metabolizers.[see comment]. Clin Chem. 2004;50(9):1623-33. Exclude: falls outside study scope. [pmid: 15205367].
Tenneze L, Tarral E, Ducloux N, et al. Pharmacokinetics and electrocardiographic effects of a new controlled-release form of flecainide acetate: comparison with the standard form and influence of the CYP2D6 polymorphism. Clin Pharmacol Ther. 2002;72(2):112-22. Exclude: falls outside study scope. [pmid: 12189358].
Tong W, Cao X, Harris S, et al. ArrayTrack—supporting toxicogenomic research at the U.S. Food and Drug Administration National Center for Toxicological Research. Environ Health Perspect. 2003;111(15):1819-26. Exclude: falls outside study scope. [pmid: 14630514]. [pmcid: 1241745].
Topic E, Stefanovic M, Ivanisevic AM, et al. CYP2D6 genotyping in patients on psychoactive drug therapy. Clin Chem Lab Med. 2000;38(9):921-7. Exclude: falls outside study scope. [pmid: 11097351].
Tuominen R, Warholm M, Moller L, et al. Constitutive CYP1B1 mRNA expression in human blood mononuclear cells in relation to gender, genotype, and environmental factors. Environ Res. 2003;93(2):138-48. Exclude: falls outside study scope. [pmid: 12963398].
Vermeesch JR, Melotte C, Froyen G, et al. Molecular karyotyping: array CGH quality criteria for constitutional genetic diagnosis. J Histochem Cytochem. 2005;53(3):413-22. Exclude: falls outside study scope. [pmid: 15750031].
Wandel C, Witte JS, Hall JM, et al. CYP3A activity in African American and European American men: population differences and functional effect of the CYP3A4*1B5′-promoter region polymorphism. Clin Pharmacol Ther. 2000;68(1):82-91. Exclude: falls outside study scope. [pmid: 10945319].
Wang J, Hu L, Hamilton SR, et al. RNA amplification strategies for cDNA microarray experiments. Biotechniques. 2003;34(2):394-400. Exclude: falls outside study scope. [pmid: 12613262].
Wanwimolruk S, Bhawan S, Coville PF, et al. Genetic polymorphism of debrisoquine (CYP2D6) and proguanil (CYP2C19) in South Pacific Polynesian populations. Eur J Clin Pharmacol. 1998;54(5):431-5. Exclude: falls outside study scope. [pmid: 9754989].
Yamakawa H, Yokoyama S, Hirano T, et al. A simple and robust method for preparation of cDNA nylon microarrays. DNA Res. 2004;11(5):353-60. Exclude: falls outside study scope. [pmid: 15747583].
Yang M, Kunugita N, Kitagawa K, et al. Individual differences in urinary cotinine levels in Japanese smokers: relation to genetic polymorphism of drug-metabolizing enzymes. Cancer Epidemiol Biomarkers Prev. 2001;10(6):589-93. Exclude: falls outside study scope. [pmid: 11401907].
Yao TW, Zeng S, Wang TW, et al. Phenotype analysis of cytochrome P450 2C19 in Chinese subjects with mephenytoin S/R enantiomeric ratio in urine measured by chiral GC. Biomed Chromatogr. 2001;15(1):9-13. Exclude: falls outside study scope. [pmid: 11180294].
Zourkova A. Effect of mirtazapine and paroxetine on residual symptoms of depressive disorders and their effect on P450 CYP 2D6 activity. Homeost Health Dis. 2001;41(6):242-8. Exclude: probe drug metabolism defined CYP status.
Zourkova A. Clinical significance of CYP 2D6 during treatment with recent antidepressants [Czech]. Ceska a Slovenska Psychiatrie. 2002;98(5):273-7. Exclude: foreign language.
Zourkova A, Hadasova E. Relationship between CYP 2D6 metabolic status and sexual dysfunction in paroxetine treatment. J Sex Marital Ther. 2002;28(5):451-61. Exclude: probe drug metabolism defined CYP status. [pmid: 12378847].
Zourkova A, Hadasova E. Paroxetine-induced conversion of cytochrome P450 2D6 phenotype and occurence of adverse effects. Gen Physiol Biophys. 2003;22(1):103-13. Exclude: probe drug metabolism defined CYP status. [pmid: 12870705].