# Appendix A. Exact Search String

Database: Ovid MEDLINE(R) <1966 to November Week 3 2005> [last updated May Week 2 2006]

Search Strategy:

1 cytochrome p-450 enzyme system/ or aryl hydrocarbon hydroxylases/ or cytochrome p-450 cyp2d6/
2 (cyp2c19 or cyp2c9 or cyp2cd6 or cyp 2c19 or cyp 2c9 or cyp 2d6).mp.
3 amplichip.mp.
4 microarray analysis/ or oligonucleotide array sequence analysis/
5 or/1–4
6 serotonin uptake inhibitors/ or citalopram/ or fluoxetine/ or fluvoxamine/ or paroxetine/ or sertraline/
7 (escitalopram or citalopram or fluoxetine or fluvoxamine or paroxetine or sertraline).mp.
8 (celexa or lexapro or prozac or luvox or paxil or zoloft).mp.
9 or/6–8
10 5 and 9
11 limit 10 to humans
12 limit 11 to english language
13 “Sensitivity and Specificity”/
14 “REPRODUCIBILITY OF RESULTS”/
15 13 or 14
16 5 and 15
17 limit 16 to humans
18 limit 17 to english language
19 18 not 12
20 (3 or 4) and 15
21 limit 20 to humans
22 limit 21 to english language
23 (1 or 2) and (3 or 4)
24 1 or (2 and 4) or 3
25 24 and 15
26 limit 25 to humans
27 limit 26 to english language
28 22 not 27
29 from 27 keep 1–219
30 cyp2d6.mp.
31 30 and 9
32 31 not 10
33 limit 32 to (humans and english language)
34 30 and 15
35 30 not 16
36 limit 35 to (humans and english language)
37 Reference Standards/
38 Quality Control/
39 Reference Values/
40 30 or 5
41 or/37–39
42 40 and 41
43 limit 42 to (humans and english language)
44 33 or 36
45 from 44 keep 1–42
46 from 43 keep 1–481