# Appendixes

Appendix A. Exact Search String

Appendix B. List of Excluded Studies

Appendix C. Sample Data Abstraction Forms

Appendix D. Evidence Tables

Appendix E. Quality Assessment Tools

Appendix F. Peer Reviewers