# List of Acronyms/Abbreviations

AHRQ | Agency for Healthcare Research and Quality
β-hCG | Beta human chorionic gonadotropin
Bcl-2 | (Anti-apoptosis protein)
BRCA1/2 | Breast cancer gene 1/2
CA-125 | Cancer antigen 125
CA-15-3 | Cancer antigen 15-3
CA-19-9 | Cancer antigen 19-9
CA-27-29 | Cancer antigen 27-29
CA-72-4 | Cancer antigen 72-4
CASA | Cancer-associated serum antigen
CDC | Centers for Disease Control and Prevention
CEA | Carcinoembryonic antigen
c-erb-B2 | (Same as HER-2)
c-erb-2 | (Same as HER-2)
CI | Confidence interval
CK19 | Cytokeratin 19
CYFRA 21-1 | Cytokeratin fragment 21
EGAPP | Evaluation of Genomic Applications in Practice and Prevention
EGFR | Epidermal growth factor receptor
FAS | Fatty acid synthase
FIGO | International Federation of Obstetrics and Gynecology
GAT | Galactosyltransferase associated with tumor
G-CSF | Granulocyte-colony stimulating factor
HE4 | Human epididymis protein 4
HER-2 | Human epidermal growth factor receptor 2
hK6 | Human kallikrein 6
hK10 | Human kallikrein 10
IL-2 | Interleukin 2
IL-6 | Interleukin 6
IL-8 | Interleukin 8
LASA | Lipid-associated sialic acid
LMP | Low malignant potential
LRP | Low-density lipoprotein receptor-related protein
LSA | Lysophospholipids
M-CSF | Macrophage colony stimulating factor
Mdm2 | Murine double minute protein
MDR-1 | Multidrug resistance gene 1
MeSH | Medical Subject Headings
MMP | Matrix metalloproteinases
MRP1/2 | Multidrug resistance protein 1/2
MW | Molecular weight
M/Z | Mass-to-charge
nm23 | (Metastasis suppressor)
OVX1 | (Monoclonal antibody raised against a human ovarian carcinoma cell line)
p53 | (Transcription factor)
p55, p75 | (Tumor necrosis factor receptors)
Pgp | P-glycoprotein
PLCO | Prostate, Lung, Colon, and Ovarian screening trial (National Cancer Institute)
RCT | Randomized controlled trial
RIA | Radioimmunoassay
ROC | Receiver operating characteristic
SAX2 | Strong anionic exchanger
SEER | Surveillance, Epidemiology, and End Results
SELDI-TOF | Surfance-enhanced laser desorption inonization time-of-flight
SLL | Second-look laparotomy
SVM-GA | Support vector machine with genetic algorithm
SVM-ST | Support vector machine statistical testing
TATI | Tumor-associated trypsin inhibitor
TN | Tetranectin
TP53 | (Same as p53)
TPA | Tissue plasminogen activator
TPS | Tissue polypeptide-specific antigen
USCS | United States Cancer Statistics
USPSTF | U.S. Preventive Services Task Force
VEGF | Vascular endothelial growth factor
WCX2 | Weak cationic exchanger