# List of Included Studies (alphabetical)

Abdel-Aleem H, Ahmed A, Sabra AM, et al. Serum alpha L-fucosidase enzyme activity in ovarian and other female genital tract tumors. Int J Gynaecol Obstet. 1996;55(3):273-9. [pmid: 9003953].
Ayhan A, Tuncer ZS, Ayhan A. p53 expression in ovarian carcinoma with regard to second-look findings. Eur J Gynaecol Oncol. 1998;19(5):501-2. [pmid: 9863925].
Baekelandt M, Holm R, Trope CG, et al. The significance of metastasis-related factors cathepsin-D and nm23 in advanced ovarian cancer. Ann Oncol. 1999;10(11):1335-41. [pmid: 10631462].
Baekelandt M, Kristensen GB, Nesland JM, et al. Clinical significance of apoptosis-related factors p53, Mdm2, and Bcl-2 in advanced ovarian cancer. J Clin Oncol. 1999;17(7):2061. [pmid: 10561259].
Balbi GC, Cardone A, Passaro M, et al. Comparative evaluation of standard criteria and CA-125 in ovarian cancers treated with platinum or paclitaxel. Eur J Gynaecol Oncol. 2005;26(3):285-7. [pmid: 15991527].
Baron AT, Boardman CH, Lafky JM, et al. Soluble epidermal growth factor receptor (SEG-FR) and cancer antigen 125 (CA125) as screening and diagnostic tests for epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(2):306-18. [pmid: 15734951].
Baron AT, Cora EM, Lafky JM, et al. Soluble epidermal growth factor receptor (sEGFR/sErbB1) as a potential risk, screening, and diagnostic serum biomarker of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(2):103-13. [pmid: 12582019].
Benetkiewicz M, Wang Y, Schaner M, et al. High-resolution gene copy number and expression profiling of human chromosome 22 in ovarian carcinomas. Genes Chromosom Cancer. 2005;42(3):228-37. [pmid: 15578687].
Berchuck A, Iversen ES, Lancaster JM, et al. Prediction of optimal versus suboptimal cytoreduction of advanced-stage serous ovarian cancer with the use of microarrays. Am J Obstet Gynecol. 2004;190(4):910-25. [pmid: 15118612].
Berek JS, Chung C, Kaldi K, et al. Serum interleukin-6 levels correlate with disease status in patients with epithelial ovarian cancer. Am J Obstet Gynecol. 1991;164(4):1038-42. discussion 1042–3. [pmid: 2014824].
Bish A, Sutton S, Jacobs C, et al. Changes in psychological distress after cancer genetic counselling: a comparison of affected and unaffected women. Br J Cancer. 2002;86(1):43-50. [pmid: 11857010].
Bon GG, Verheijen RH, Zuetenhorst JM, et al. Mucin-like carcinoma-associated antigen serum levels in patients with adenocarcinomas originating from ovary, breast and colon. Gynecol Obstet Invest. 1996;42(1):58-62. [pmid: 8840180].
Brinkmann D, Ryan A, Ayhan A, et al. A molecular genetic and statistical approach for the diagnosis of dual-site cancers. J Natl Cancer Inst. 2004;96(19):1441-6. [pmid: 15467033].
Centers for Disease Control and Prevention (CDC). Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing—Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. Morb Mortal Wkly Rep Surveill Summ. 2004;53(27):603-6.
Chang HW, Lee SM, Goodman SN, et al. Assessment of plasma DNA levels, allelic imbalance, and CA 125 as diagnostic tests for cancer. J Natl Cancer Inst. 2002;94(22):1697-703. [pmid: 12441325].
Cherchi PL, Capobianco G, Ambrosini G, et al. Intracystic evaluation of tumor markers in benign and malignant ovarian pathology. Eur J Gynaecol Oncol. 2002;23(2):163-5. [pmid: 12013118].
Claes E, Evers-Kiebooms G, Denayer L, et al. Predictive genetic testing for hereditary breast and ovarian cancer: psychological distress and illness representations 1 year following disclosure. J Genet Couns. 2005;14(5):349-63. [pmid: 16195942].
Conrads TP, Fusaro VA, Ross S, et al. High-resolution serum proteomic features for ovarian cancer detection. Endocr Relat Cancer. 2004;11(2):163-78. [pmid: 15163296].
Cooper BC, Ritchie JM, Broghammer CL, et al. Preoperative serum vascular endothelial growth factor levels: significance in ovarian cancer. Clin Cancer Res. 2002;8(10):3193-7. [pmid: 12374688].
Czekierdowski A. Studies on angiogenesis in the benign and malignant ovarian neoplasms with the use of color and pulsed Doppler sonography and serum CA-125, CA-19.9, CA-72.4 and vascular endothelial growth factor measurements. Ann Univ Mariae Curie Sklodowska [Med]. 2002;57(1):113-31.
Darai E, Bringuier AF, Walker-Combrouze F, et al. Soluble adhesion molecules in serum and cyst fluid from patients with cystic tumours of the ovary. Hum Reprod. 1998;13(10):2831-5. [pmid: 9804241].
Diamandis EP, Scorilas A, Fracchioli S, et al. Human kallikrein 6 (hK6): a new potential serum biomarker for diagnosis and prognosis of ovarian carcinoma. J Clin Oncol. 2003;21(6):1035-43. [pmid: 12637468].
Fayed ST, Ahmad SM, Kassim SK, et al. The value of CA 125 and CA72-4 in management of patients with epithelial ovarian cancer. Dis Markers. 1998;14(3):155-60. [pmid: 10427474].
Filella X, Ballesta AM, Fox M, et al. Multicentre clinical evaluation of the COBAS CORE CEA, CA 125 II and PSA tumor marker assays. Int J Biol Markers. 1996;11(1):40-5. [pmid: 8740641].
Folk JJ, Botsford M, Musa AG. Monitoring cancer antigen 125 levels in induction chemotherapy for epithelial ovarian carcinoma and predicting outcome of second-look procedure. Gynecol Oncol. 1995;57(2):178-82. [pmid: 7729730].
Gadducci A, Baicchi U, Marrai R, et al. Preoperative evaluation of D-dimer and CA 125 levels in differentiating benign from malignant ovarian masses. Gynecol Oncol. 1996;60(2):197-202. [pmid: 8631538].
Gadducci A, Cosio S, Fanucchi A, et al. The predictive and prognostic value of serum CA 125 half-life during paclitaxel/platinum-based chemotherapy in patients with advanced ovarian carcinoma. Gynecol Oncol. 2004;93(1):131-6. [pmid: 15047226].
Gadducci A, Ferdeghini M, Cosio S, et al. The clinical relevance of serum CYFRA 21-1 assay in patients with ovarian cancer. Int J Gynecol Cancer. 2001;11(4):277-82. [pmid: 11520365].
Gemer O, Lurian M, Gdalevich M, et al. A multicenter study of CA 125 level as a predictor of non-optimal primary cytoreduction of advanced epithelial ovarian cancer. Eur J Surg Oncol. 2005;31(9):1006-10. [pmid: 16005601].
Gemer O, Segal S, Kopmar A. Preoperative CA-125 level as a predictor of non optimal cytoreduction of advanced epithelial ovarian cancer. Acta Obstet Gynecol Scand. 2001;80(6):583-5. [pmid: 11380298].
Gorelik E, Landsittel DP, Marrangoni AM, et al. Multiplexed immunobead-based cytokine profiling for early detection of ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(4):981-7. [pmid: 15824174].
Gronlund B, Hansen HH, Hogdall C, et al. Do CA125 response criteria overestimate tumour response in second-line treatment of epithelial ovarian carcinoma?. Br J Cancer. 2004;90(2):377-82. [pmid: 14735180].
Hasholzner U, Baumgartner L, Stieber P, et al. Clinical significance of the tumour markers CA 125 II and CA 72-4 in ovarian carcinoma. Int J Cancer. 1996;69(4):329-34. [pmid: 8797878].
Hefler L, Mayerhofer K, Nardi A, et al. Serum soluble Fas levels in ovarian cancer. Obstet Gynecol. 2000;96(1):65-9. [pmid: 10862844].
Heinrich JK, Bottcher-Luiz F, Andrade LL, et al. HER-2 and cancer antigen 125 evaluation in ovarian borderline tumors by immunohistochemistry and fluorescence in situ hybridization. Int J Gynecol Cancer. 2004;14(6):1078-85. [pmid: 15571613].
Heinzelmann-Schwarz VA, Gardiner-Garden M, Henshall SM, et al. Overexpression of the cell adhesion molecules DDR1, Claudin 3, and Ep-CAM in metaplastic ovarian epithelium and ovarian cancer. Clin Cancer Res. 2004;10(13):4427-36. [pmid: 15240533].
Hellström I, Raycraft J, Hayden-Ledbetter M, et al. The HE4 (WFDC2) protein is a biomarker for ovarian carcinoma. Cancer Res. 2003;63(13):3695-700. [pmid: 12839961].
Hibbs K, Skubitz KM, Pambuccian SE, et al. Differential gene expression in ovarian carcinoma: identification of potential biomarkers. Am J Pathol. 2004;165(2):397-414. [pmid: 15277215]. [pmcid: 1618570].
Hofmann M, Ruschenburg I. mRNA detection of tumor-rejection genes BAGE, GAGE, and MAGE in peritoneal fluid from patients with ovarian carcinoma as a potential diagnostic tool. Cancer. 2002;96(3):187-93. [pmid: 12115308].
Hogdall CK, Hogdall EV, Hording U, et al. Use of tetranectin, CA-125 and CASA to predict residual tumor and survival at second- and third-look operations for ovarian cancer. Acta Oncol. 1996;35(1):63-9. [pmid: 8619942].
Hubl W, Chan DW, Van Ingen HE, et al. Multicenter evaluation of the Elecsys CA 125 II assay. Anticancer Res. 1999;19(4A):2727-33. [pmid: 10470230].
Hurteau JA, Woolas RP, Jacobs IJ, et al. Soluble interleukin-2 receptor alpha is elevated in sera of patients with benign ovarian neoplasms and epithelial ovarian cancer. Cancer. 1995;76(9):1615-20. [pmid: 8635066].
Inaba N, Negishi Y, Fukasawa I, et al. Cytokeratin fragment 21-1 in gynecologic malignancy: comparison with cancer antigen 125 and squamous cell carcinoma-related antigen. Tumour Biol. 1995;16(6):345-52. [pmid: 7569681].
Izquierdo MA, van der Zee AG, Vermorken JB, et al. Drug resistance-associated marker Lrp for prediction of response to chemotherapy and prognoses in advanced ovarian carcinoma. J Natl Cancer Inst. 1995;87(16):1230-7. [pmid: 7563169].
Janatova M, Pohlreich P, Matous B. Detection of the most frequent mutations in BRCA1 gene on polyacrylamide gels containing Spreadex Polymer NAB. Neoplasma. 2003;50(4):246-50. [pmid: 12937835].
Kamazawa S, Kigawa J, Kanamori Y, et al. Multidrug resistance gene-1 is a useful predictor of Paclitaxel-based chemotherapy for patients with ovarian cancer. Gynecol Oncol. 2002;86(2):171-6. [pmid: 12144824].
Kenemans P, Verstraeten AA, van Kamp GJ, et al. The second generation CA 125 assays. Ann Med. 1995;27(1):107-13. [pmid: 7741988].
Kierkegaard O, Mogensen O, Mogensen B, et al. Predictive and prognostic values of cancer-associated serum antigen (CASA) and cancer antigen 125 (CA 125) levels prior to second-look laparotomy for ovarian cancer. Gynecol Oncol. 1995;59(2):251-4. [pmid: 7590482].
Kim JH, Herlyn D, Wong KK, et al. Identification of epithelial cell adhesion molecule autoantibody in patients with ovarian cancer. Clin Cancer Res. 2003;9(13):4782-91. [pmid: 14581349].
Kozak KR, Amneus MW, Pusey SM, et al. Identification of biomarkers for ovarian cancer using strong anion-exchange ProteinChips: potential use in diagnosis and prognosis. Proc Natl Acad Sci U S A. 2003;100(21):12343-8. [pmid: 14523236]. [pmcid: 218760].
Kupryjanczyk J, Szymanska T, Madry R, et al. Evaluation of clinical significance of TP53, BCL-2, BAX and MEK1 expression in 229 ovarian carcinomas treated with platinum-based regimen. Br J Cancer. 2003;88(6):848-54. [pmid: 12644821].
Lassus H, Leminen A, Vayrynen A, et al. ERBB2 amplification is superior to protein expression status in predicting patient outcome in serous ovarian carcinoma. Gynecol Oncol. 2004;92(1):31-9. [pmid: 14751135].
Lee H, Park G, Jung JH, et al. Diagnostic approach using the expression profiling of the P53 tumor suppressor gene and its related proteins in ovarian epithelial tumors. Int J Gynecol Cancer. 2005;15(3):453-61. [pmid: 15882169].
Li L, Tang H, Wu Z, et al. Data mining techniques for cancer detection using serum proteomic profiling. Artif Intell Med. 2004;32(2):71-83. [pmid: 15364092].
Liu Y. Serum proteomic pattern analysis for early cancer detection. Technology in Cancer Research & Treatment. 2006;5(1):61-6. [pmid: 16417403].
Luo LY, Bunting P, Scorilas A, et al. Human kallikrein 10: a novel tumor marker for ovarian carcinoma?. Clin Chim Acta. 2001;306(12):111-8. [pmid: 11282101].
Luo LY, Katsaros D, Scorilas A, et al. The serum concentration of human kallikrein 10 represents a novel biomarker for ovarian cancer diagnosis and prognosis. Cancer Res. 2003;63(4):807-11. [pmid: 12591730].
Mabrouk RA, Ali-Labib R. Detection of urokinase plasminogen activator receptor and c-erbB-2 in sera of patients with breast and ovarian carcinoma. Clin Biochem. 2003;36(7):537-43. [pmid: 14563447].
Makhlouf AM, Fathalla MM, Zakhary MA, et al. Sulfatides in ovarian tumors: clinicopathological correlates. Int J Gynecol Cancer. 2004;14(1):89-93. [pmid: 14764034].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. Am J Med Genet A. 2004;130(3):221-7. [pmid: 15378542].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families II: impact on relationships. Am J Med Genet A. 2005;133(2):165-9. [pmid: 15633195].
McIntosh MW, Drescher C, Karlan B, et al. Combining CA 125 and SMR serum markers for diagnosis and early detection of ovarian carcinoma. Gynecol Oncol. 2004;95(1):9-15. [pmid: 15385104].
Medl M, Ogris E, Peters-Engl C, et al. TATI (tumour-associated trypsin inhibitor) as a marker of ovarian cancer. Br J Cancer. 1995;71(5):1051-4. [pmid: 7734298].
Meinhold-Heerlein I, Bauerschlag D, Hilpert F, et al. Molecular and prognostic distinction between serous ovarian carcinomas of varying grade and malignant potential. Oncogene. 2005;24(6):1053-65. [pmid: 15558012].
Memarzadeh S, Lee SB, Berek JS, et al. CA125 levels are a weak predictor of optimal cytoreductive surgery in patients with advanced epithelial ovarian cancer. Int J Gynecol Cancer. 2003;13(2):120-4. [pmid: 12657110].
Mok SC, Chao J, Skates S, et al. Prostasin, a potential serum marker for ovarian cancer: identification through microarray technology. J Natl Cancer Inst. 2001;93(19):1458-64. [pmid: 11584061].
Mor G, Visintin I, Lai Y, et al. Serum protein markers for early detection of ovarian cancer. Proc Natl Acad Sci U S A. 2005;102(21):7677-82. [pmid: 15890779]. [pmcid: 1140439].
Mouchawar J, Hensley-Alford S, Laurion S, et al. Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005;7(3):191-7. [pmid: 15775755].
Obeidat B, Latimer J, Crawford R. Can optimal primary cytoreduction be predicted in advanced stage epithelial ovarian cancer? Role of preoperative serum CA-125 level. Gynecol Obstet Invest. 2004;57(3):153-6. [pmid: 14726621].
Obermair A, Tempfer C, Hefler L, et al. Concentration of vascular endothelial growth factor (VEGF) in the serum of patients with suspected ovarian cancer. Br J Cancer. 1998;77(11):1870-4. [pmid: 9667661].
Oehler MK, Caffier H. Diagnostic value of serum VEGF in women with ovarian tumors. Anticancer Res. 1999;19(4A):2519-22. [pmid: 10470186].
Onsrud M, Shabana A, Austgulen R. Soluble tumor necrosis factor receptors and CA 125 in serum as markers for epithelial ovarian cancer. Tumour Biol. 1996;17(2):90-6. [pmid: 8658018].
Opala T, Drews K, Rzymski P, et al. Evaluation of soluble intracellular adhesion molecule-1 (sICAM-1) in benign and malignant ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):255-7. [pmid: 12807235].
Opala T, Rzymski P, Wilczak M, et al. Evaluation of soluble tumour necrosis factor alpha receptors p55 and p75 in ovarian cancer patients. Eur J Gynaecol Oncol. 2005;26(1):43-6. [pmid: 15754999].
Peters-Engl C, Medl M, Ogris E, et al. Tumor-associated trypsin inhibitor (TATI) and cancer antigen 125 (CA125) in patients with epithelial ovarian cancer. Anticancer Res. 1995;15(6B):2727-30. [pmid: 8669854].
Petricoin EF, Ardekani AM, Hitt BA, et al. Use of proteomic patterns in serum to identify ovarian cancer. Lancet. 2002;359(9306):572-7. [pmid: 11867112].
Rai AJ, Zhang Z, Rosenzweig J, et al. Proteomic approaches to tumor marker discovery. Arch Pathol Lab Med. 2002;126(12):1518-26. [pmid: 12456215].
Riisbro R, Stephens RW, Brunner N, et al. Soluble urokinase plasminogen activator receptor in preoperatively obtained plasma from patients with gynecological cancer or benign gynecological diseases. Gynecol Oncol. 2001;82(3):523-31. [pmid: 11520150].
Rustin GJ, Marples M, Nelstrop AE, et al. Use of CA-125 to define progression of ovarian cancer in patients with persistently elevated levels. J Clin Oncol. 2001;19(20):4054-7. [pmid: 11600607].
Rustin GJ, Nelstrop AE, Tuxen MK, et al. Defining progression of ovarian carcinoma during follow-up according to CA 125: a North Thames Ovary Group Study. Ann Oncol. 1996;7(4):361-4. [pmid: 8805927].
Santillan A, Garg R, Zahurak ML, et al. Risk of epithelial ovarian cancer recurrence in patients with rising serum CA-125 levels within the normal range. J Clin Oncol. 2005;23(36):9338-43. [pmid: 16361633].
Sapi E, Okpokwasili NI, Rutherford T. Detection of telomerase-positive circulating epithelial cells in ovarian cancer patients. Cancer Detect Prev. 2002;26(2):158-67. [pmid: 12102151].
Saygili U, Guclu S, Uslu T, et al. Can serum CA-125 levels predict the optimal primary cytoreduction in patients with advanced ovarian carcinoma?. Gynecol Oncol. 2002;86(1):57-61. [pmid: 12079301].
Schutter EM, Mijatovic V, Kok A, et al. Urinary gonadotropin peptide (UGP) and serum CA 125 in gynaecologic practice, a clinical prospective study. Anticancer Res. 1999;19(6C):5551-7. [pmid: 10697615].
Schutter EM, Sohn C, Kristen P, et al. Estimation of probability of malignancy using a logistic model combining physical examination, ultrasound, serum CA 125, and serum CA 72-4 in postmenopausal women with a pelvic mass: an international multicenter study. Gynecol Oncol. 1998;69(1):56-63. [pmid: 9570999].
Sedlaczek P, Frydecka I, Gabrys M, et al. Comparative analysis of CA125, tissue polypeptide specific antigen, and soluble interleukin-2 receptor alpha levels in sera, cyst, and ascitic fluids from patients with ovarian carcinoma. Cancer. 2002;95(9):1886-93. [pmid: 12404282].
Senapad S, Neungton S, Thirapakawong C, et al. Predictive value of the combined serum CA 125 and TPS during chemotherapy and before second-look laparotomy in epithelial ovarian cancer. Anticancer Res. 2000;20(2B):1297-300. [pmid: 10810438].
Skates SJ, Horick N, Yu Y, et al. Preoperative sensitivity and specificity for early-stage ovarian cancer when combining cancer antigen CA-125II, CA 15-3, CA 72-4, and macrophage colony-stimulating factor using mixtures of multivariate normal distributions. J Clin Oncol. 2004;22(20):4059-66. [pmid: 15381683].
Sorace JM, Zhan M. A data review and re-assessment of ovarian cancer serum proteomic profiling. BMC Bioinformatics. 2003;4(1):24. [pmid: 12795817]. [pmcid: 165662].
Takano H, Okamoto A, Fukushima K, et al. Low specificity of cytokeratin 19 mRNA expression in the peripheral blood cells from patients with ovarian tumors. Oncol Rep. 2000;7(5):1023-5. [pmid: 10948333].
Tamakoshi K, Kikkawa F, Hasegawa N, et al. Clinical value of a new serum tumor marker, CA125II, in gynecologic disease: comparison with CA125. Gynecol Obstet Invest. 1995;39(2):125-9. [pmid: 7737582].
Tanir HM, Ozalp S, Yalcin OT, et al. Preoperative serum vascular endothelial growth factor (VEGF) in ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):271-4. [pmid: 12807238].
Tempfer C, Hefler L, Heinzl H, et al. CYFRA 21-1 serum levels in women with adnexal masses and inflammatory diseases. Br J Cancer. 1998;78(8):1108-12. [pmid: 9792159].
Thougaard AV, Hogdall CK, Kjaer SK, et al. Determination of serum tetranectin: technical and clinical evaluation of three sandwich immunoassays. Clin Chim Acta. 1998;276(1):19-34. [pmid: 9760017].
Tsukishiro S, Suzumori N, Nishikawa H, et al. Use of serum secretory leukocyte protease inhibitor levels in patients to improve specificity of ovarian cancer diagnosis. Gynecol Oncol. 2005;96(2):516-9. [pmid: 15661245].
Tuxen MK, Soletormos G, Petersen PH, et al. Interpretation of sequential measurements of cancer antigen 125 (CA 125), carcinoembryonic antigen (CEA), and tissue polypeptide antigen (TPA) based on analytical imprecision and biological variation in the monitoring of ovarian cancer. Clin Chem Lab Med. 2001;39(6):531-8. [pmid: 11506467].
Tuxen MK, Soletormos G, Rustin GJ, et al. Biological variation and analytical imprecision of CA 125 in patients with ovarian cancer. Scand J Clin Lab Invest. 2000;60(8):713-21. [pmid: 11218154].
Udagawa Y, Aoki D, Ito K, et al. Clinical characteristics of a newly developed ovarian tumour marker, galactosyltransferase associated with tumour (GAT). Eur J Cancer. 1998;34(4):489-95. [pmid: 9713298].
van Haaften-Day C, Shen Y, Xu F, et al. OVX1, macrophage-colony stimulating factor, and CA-125-II as tumor markers for epithelial ovarian carcinoma: a critical appraisal. Cancer. 2001;92(11):2837-44. [pmid: 11753957].
van Ingen HE, Chan DW, Hubl W, et al. Analytical and clinical evaluation of an electrochemiluminescence immunoassay for the determination of CA 125. Clin Chem. 1998;44(12):2530-6. [pmid: 9836722].
Wakahara F, Kikkawa F, Nawa A, et al. Diagnostic efficacy of tumor markers, sonography, and intraoperative frozen section for ovarian tumors. Gynecol Obstet Invest. 2001;52(3):147-52. [pmid: 11598354].
Warwas M, Haczynska H, Gerber J, et al. Cathepsin B-like activity as a serum tumour marker in ovarian carcinoma. Eur J Clin Chem Clin Biochem. 1997;35(4):301-4. [pmid: 9166974].
Weitzel JN, Ding S, Larson GP, et al. The HRAS1 minisatellite locus and risk of ovarian cancer. Cancer Res. 2000;60(2):259-61. [pmid: 10667571].
Wen WH, Bernstein L, Lescallett J, et al. Comparison of TP53 mutations identified by oligonucleotide microarray and conventional DNA sequence analysis. Cancer Res. 2000;60(10):2716-22. [pmid: 10825146].
Wong C, Dai ZM, Lele SB, et al. Comparison of CA 125 after three courses of chemotherapy and results of second-look surgery. Eur J Gynaecol Oncol. 2000;21(1):70-3. [pmid: 10726624].
Wu B, Abbott T, Fishman D, et al. Comparison of statistical methods for classification of ovarian cancer using mass spectrometry data. Bioinformatics. 2003;19(13):1636-43. [pmid: 12967959].
Yu JK, Zheng S, Tang Y, et al. An integrated approach utilizing proteomics and bioinformatics to detect ovarian cancer. J Zhejiang Univ Sci B. 2005;6(4):227-31. [pmid: 15754417]. [pmcid: 1389728].
Yu JS, Ongarello S, Fiedler R, et al. Ovarian cancer identification based on dimensionality reduction for high-throughput mass spectrometry data. Bioinformatics. 2005;21(10):2200-9. [pmid: 15784749].
Yuce K, Baykal C, Genc C, et al. Diagnostic and prognostic value of serum and peritoneal fluid lactate dehydrogenase in epithelial ovarian cancer. Eur J Gynaecol Oncol. 2001;22(3):228-32. [pmid: 11501779].
Zakrzewska I, Borawska R, Poznanski J, et al. Significance of some tumor markers in differential diagnosis of ovarian tumor. Rocz Akad Med Bialymst. 1999;44:235-43. [pmid: 10697438].
Zarrinkar PP, Mainquist JK, Zamora M, et al. Arrays of arrays for high-throughput gene expression profiling. Genome Res. 2001;11(7):1256-61. [pmid: 11435408]. [pmcid: 311063].
Zhang Z, Bast RC Jr, Yu Y, et al. Three biomarkers identified from serum proteomic analysis for the detection of early stage ovarian cancer. Cancer Res. 2004;64(16):5882-90. [pmid: 15313933].
Zhu W, Wang X, Ma Y, et al. Detection of cancer-specific markers amid massive mass spectral data. Proc Natl Acad Sci U S A. 2003;100(25):14666-71. [pmid: 14657331]. [pmcid: 299756].