# References

1 Jemal A, Murray T, Samuels A, et al. Cancer statistics, 2003. Ca: Cancer J Clin. 2003;53(1):5-26. [pmid: 12568441].
2 Anonymous. Surveillance, Epidemiology, and End Results (SEER) Program (www.seer.cancer.gov) SEER*Stat Database: Incidence - SEER 9 Regs Public-Use, Nov 2004 Sub for Expanded Races (1992-2002) and Incidence - SEER 13 Regs excluding AK Public-Use Nov 2004 Sub for Hispanics (1992-2002), National Cancer Institute, DCCPS, Surveillance Research Program, Cancer Statistics Branch, released April 2005, based on November 2004 submission. Available at: www.seer.cancer.gov. Accessed May 25, 2005.
3 Anonymous. Cancer Registry Public Information Data: 1999-2002, WONDER On-line Database. United States Department of Health and Human Services, National Program of Cancer Registries, Centers for Disease Control and Prevention; November 2005.
4 Russell P, Robboy S, Anderson M. Ovarian tumors: classification and clinical perspective. In: Robboy SJ, Anderson MC, and Russell P, editors. Pathology of the female reproductive tract. London: Churchill Livingstone; 2002. p. 527–38.
5 Riman T, Nilsson S, Persson IR. Review of epidemiological evidence for reproductive and hormonal factors in relation to the risk of epithelial ovarian malignancies. Acta Obstet Gynecol Scand. 2004;83(9):783-95. [pmid: 15315588].
6 Chen LM, Yamada SD, Fu YS, et al. Molecular similarities between primary peritoneal and primary ovarian carcinomas. Int J Gynecol Cancer. 2003;13(6):749-55. [pmid: 14675310].
7 Gotlieb WH, Barchana M, Ben-Baruch G, et al. Malignancies following bilateral salpingo-oophorectomy (BSO). Eur J Surg Oncol 2006 Apr 18; Epub ahead of print.
8 Parker WH, Broder MS, Liu Z, et al. Ovarian conservation at the time of hysterectomy for benign disease. Obstet Gynecol. 2005;106(2):219-26. [pmid: 16055568].
9 Domcheck SM, Friebel TM, Neuhausen SL, et al. Mortality after bilateral salpingo-oophorectomy in BRCA1 and BRCA2 mutation carriers: a prospective cohort study. Lancet Oncol. 2006;7(3):223-9. [pmid: 16510331].
10 Schmeler KM, Lynch HT, Chen LM, et al. Prophylactice surgery to reduce the risk of gynecologic cancers in the Lynch syndrome. N Engl J Med. 2006;354(3):261-9. [pmid: 16421367].
11 Madalinska JB, Hollenstein J, Bleiker E, et al. Quality-of-life effects of prophylactic salpingo-oophorectomy versus gynecologic screening among women at increased risk of hereditary ovarian cancer. J Clin Oncol. 2005;23(28):6890-8. [pmid: 16129845].
12 Narod SA, Risch H, Moslehi R, et al. Oral contraceptives and the risk of hereditary ovarian cancer. Hereditary Ovarian Cancer Clinical Study Group. N Engl J Med. 1998;339(7):424-8. [pmid: 9700175].
13 Whittemore AS, Balise RR, Pharoah PD, et al. Oral contraceptive use and ovarian cancer risk among carriers of BRCA1 or BRCA2 mutations. Br J Cancer. 2004;91(11):1911-5. [pmid: 15545966].
14 Myers ER, Bastian LA, Havrilesky LJ, et al. Management of Adnexal Mass. Evidence Report/Technology Assessment No. 130 (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025.) AHRQ Publication No. 06-E004. Rockville, MD: Agency for Healthcare Research and Quality. February 2006. Available at: www.ahrq.gov/clinic/tp/adnextp.htm#Report. Accessed April 30, 2006.
15 U.S. Preventive Services Task Force. Screening for Ovarian Cancer: Recommendation Statement. May 2004. Agency for Healthcare Research and Quality, Rockville, MD. Available at: www.ahrq.gov/clinic/3rduspstf/ovariancan/ovcanrs.htm. Accessed May 2, 2006.
16 Oei AL, Massuger LF, Bulten J, et al. Surveillance of women at high risk for hereditary ovarian cancer is inefficient. Br J Cancer. 2006;94(6):814-9. [pmid: 16495917].
17 Gaarenstroom KN, vander Hiel B, Tollenaar RA, et al. Efficacy for screening women at high risk of hereditary ovarian cancer: results of an 11-year cohort study. Int J Gynecol Cancer. 2006;16(Suppl 1):54-9. [pmid: 16515568].
18 Liede A, Karlan BY, Baldwin RL, et al. Cancer incidence in a population of Jewish women at risk of ovarian cancer. J Clin Oncol. 2002;20(6):1570-7. [pmid: 11896106].
19 Olivier RI, Lubsen-Brandsma MA, Verhoef S, et al. CA125 and transvaginal ultrasound monitoring in high-risk women cannot prevent the diagnosis of advanced ovarian cancer. Gynecol Oncol. 2006;100(1):20-6. [pmid: 16188302].
20 Plosker GL, Keam SJ. Trastuzumab: a review of its use in the management of HER2-positive metastatic and early-stage breast cancer. Drugs. 2006;66(4):449-75. [pmid: 16597163].
21 Feltmate CM, Lee KR, Johnson M, et al. Whole-genome allelotyping identified distinct loss-of-heterozygosity patterns in mucinous ovarian and appendiceal carcinomas. Clin Cancer Res. 2005;11(21):7651-7. [pmid: 16278384].
22 Balch C, Huang TH, Brown R, et al. The epigenetics of ovarian cancer drug resistance and resensitization. Am J Obstet Gynecol. 2004;191(5):1552-72. [pmid: 15547525].
23 Wei SH, Balch C, Paik HH, et al. Prognostic DNA methylation biomarkers in ovarian cancer. Clin Cancer Res. 2006;12(9):2788-94. [pmid: 16675572].
24 Esteller M. The necessity of a human epigenome project. Carcinogenesis. 2006;27(6):1121-5. [pmid: 16699174].
25 Garner EI. Advances in the early detection of ovarian carcinoma. J Reprod Med. 2005;50(6):447-53. [pmid: 16050569].
26 Society of Gynecologic Oncologists. Statement regarding Ovacheck™. February 7, 2004. Available at: www.sgo.org/policy/OvaCheck_positionstatement.pdf. Accessed August 27, 2006.
27 Society of Gynecologic Oncologists. Statement on early detection markers for ovarian cancer. March 19, 2005. Available at: www.sgo.org/policy/Earlydetection_statement.pdf. Accessed August 27, 2006.
28 Chin KM, Wessler B, Chew P, et al. Genetic tests for cancer. Technology Assessment. Prepared by the Tufts-New England Medical Center Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality (AHRQ), Rockville, MD (Contract No. 290-02-0022). January 9, 2006. Available at: www.ahrq.gov/clinic/ta/gentests/gentests.pdf. Accessed August 27, 2006.
29 ACOG Committee on Gynecologic Practice. The role of the generalist obstetrician-gynecologist in the early detection of ovarian cancer. Int J Gynaecol Obstet. 2003;80(2):235-8. [pmid: 12627605].
30 Nelson HD, Westhoff C, Piepert J, et al. Screening for Ovarian Cancer: Brief Evidence Update. May 2004. Agency for Healthcare Research and Quality, Rockville, MD. Available at: www.ahrq.gov/clinic/3rduspstf/ovariancan/ovcanup.htm. Accessed April 30, 2006.
31 Nelson HD, Huffman LH, Fu R, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: systematic evidence review for the U.S. Preventive Services Task Force.[erratum appears in Ann Intern Med. 2005 Oct 4;143(7):547]. Ann Intern Med. 2005;143(5):362-79. [pmid: 16144895].
32 Wang C, Chung M, Lichtenstein A, et al. Effects of Omega-3 Fatty Acids on Cardiovascular Disease. Evidence Report/Technology Assessment No. 94 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 04-E009-2. Rockville, MD: Agency for Healthcare Research and Quality. March 2004. Available at: www.ahcpr.gov/clinic/tp/o3cardtp.htm. Accessed May 2, 2006.
33 Benedet JL, Bender H, Jones H 3rd, et al. FIGO staging classifications and clinical practice guidelines in the management of gynecologic cancers. FIGO Committee on Gynecologic Oncology. Int J Gynaecol Obstet. 2000;70(2):209-62. [pmid: 11041682].
34 Hubl W, Chan DW, Van Ingen HE, et al. Multicenter evaluation of the Elecsys CA 125 II assay. Anticancer Res. 1999;19(4A):2727-33. [pmid: 10470230].
35 Kenemans P, Verstraeten AA, van Kamp GJ, et al. The second generation CA 125 assays. Ann Med. 1995;27(1):107-13. [pmid: 7741988].
36 Hasholzner U, Baumgartner L, Stieber P, et al. Clinical significance of the tumour markers CA 125 II and CA 72-4 in ovarian carcinoma. Int J Cancer. 1996;69(4):329-34. [pmid: 8797878].
37 Tamakoshi K, Kikkawa F, Hasegawa N, et al. Clinical value of a new serum tumor marker, CA125II, in gynecologic disease: comparison with CA125. Gynecol Obstet Invest. 1995;39(2):125-9. [pmid: 7737582].
38 Filella X, Ballesta AM, Fox M, et al. Multicentre clinical evaluation of the COBAS CORE CEA, CA 125 II and PSA tumor marker assays. Int J Biol Markers. 1996;11(1):40-5. [pmid: 8740641].
39 van Ingen HE, Chan DW, Hubl W, et al. Analytical and clinical evaluation of an electrochemiluminescence immunoassay for the determination of CA 125. Clin Chem. 1998;44(12):2530-6. [pmid: 9836722].
40 Tuxen MK, Soletormos G, Rustin GJ, et al. Biological variation and analytical imprecision of CA 125 in patients with ovarian cancer. Scand J Clin Lab Invest. 2000;60(8):713-21. [pmid: 11218154].
41 Tuxen MK, Soletormos G, Petersen PH, et al. Interpretation of sequential measurements of cancer antigen 125 (CA 125), carcinoembryonic antigen (CEA), and tissue polypeptide antigen (TPA) based on analytical imprecision and biological variation in the monitoring of ovarian cancer. Clin Chem Lab Med. 2001;39(6):531-8. [pmid: 11506467].
42 Riisbro R, Stephens RW, Brunner N, et al. Soluble urokinase plasminogen activator receptor in preoperatively obtained plasma from patients with gynecological cancer or benign gynecological diseases. Gynecol Oncol. 2001;82(3):523-31. [pmid: 11520150].
43 Thougaard AV, Hogdall CK, Kjaer SK, et al. Determination of serum tetranectin: technical and clinical evaluation of three sandwich immunoassays. Clin Chim Acta. 1998;276(1):19-34. [pmid: 9760017].
44 Mok SC, Chao J, Skates S, et al. Prostasin, a potential serum marker for ovarian cancer: identification through microarray technology. J Natl Cancer Inst. 2001;93(19):1458-64. [pmid: 11584061].
45 Hellström I, Raycraft J, Hayden-Ledbetter M, et al. The HE4 (WFDC2) protein is a biomarker for ovarian carcinoma. Cancer Res. 2003;63(13):3695-700. [pmid: 12839961].
46 Sapi E, Okpokwasili NI, Rutherford T. Detection of telomerase-positive circulating epithelial cells in ovarian cancer patients. Cancer Detect Prev. 2002;26(2):158-67. [pmid: 12102151].
47 Janatova M, Pohlreich P, Matous B. Detection of the most frequent mutations in BRCA1 gene on polyacrylamide gels containing Spreadex Polymer NAB. Neoplasma. 2003;50(4):246-50. [pmid: 12937835].
48 Wen WH, Bernstein L, Lescallett J, et al. Comparison of TP53 mutations identified by oligonucleotide microarray and conventional DNA sequence analysis. Cancer Res. 2000;60(10):2716-22. [pmid: 10825146].
49 Zarrinkar PP, Mainquist JK, Zamora M, et al. Arrays of arrays for high-throughput gene expression profiling. Genome Res. 2001;11(7):1256-61. [pmid: 11435408]. [pmcid: 311063].
50 Wu B, Abbott T, Fishman D, et al. Comparison of statistical methods for classification of ovarian cancer using mass spectrometry data. Bioinformatics. 2003;19(13):1636-43. [pmid: 12967959].
51 Yu JK, Zheng S, Tang Y, et al. An integrated approach utilizing proteomics and bioinformatics to detect ovarian cancer. J Zhejiang Univ Sci B. 2005;6(4):227-31. [pmid: 15754417]. [pmcid: 1389728].
52 Yu JS, Ongarello S, Fiedler R, et al. Ovarian cancer identification based on dimensionality reduction for high-throughput mass spectrometry data. Bioinformatics. 2005;21(10):2200-9. [pmid: 15784749].
53 Zhang Z, Bast RC Jr, Yu Y, et al. Three biomarkers identified from serum proteomic analysis for the detection of early stage ovarian cancer. Cancer Res. 2004;64(16):5882-90. [pmid: 15313933].
54 Zhu W, Wang X, Ma Y, et al. Detection of cancer-specific markers amid massive mass spectral data. Proc Natl Acad Sci U S A. 2003;100(25):14666-71. [pmid: 14657331]. [pmcid: 299756].
55 Sorace JM, Zhan M. A data review and reassessment of ovarian cancer serum proteomic profiling. BMC Bioinformatics. 2003;4(1):24. [pmid: 12795817]. [pmcid: 165662].
56 Rai AJ, Zhang Z, Rosenzweig J, et al. Proteomic approaches to tumor marker discovery. Arch Pathol Lab Med. 2002;126(12):1518-26. [pmid: 12456215].
57 Petricoin EF, Ardekani AM, Hitt BA, et al. Use of proteomic patterns in serum to identify ovarian cancer. Lancet. 2002;359(9306):572-7. [pmid: 11867112].
58 Conrads TP, Fusaro VA, Ross S, et al. High-resolution serum proteomic features for ovarian cancer detection. Endocr Relat Cancer. 2004;11(2):163-78. [pmid: 15163296].
59 Li L, Tang H, Wu Z, et al. Data mining techniques for cancer detection using serum proteomic profiling. Artif Intell Med. 2004;32(2):71-83. [pmid: 15364092].
60 Kozak KR, Amneus MW, Pusey SM, et al. Identification of biomarkers for ovarian cancer using strong anion-exchange ProteinChips: potential use in diagnosis and prognosis. Proc Natl Acad Sci U S A. 2003;100(21):12343-8. [pmid: 14523236]. [pmcid: 218760].
61 Buys SS, Partridge E, Greene MH, et al. Ovarian cancer screening in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial: findings from the initial screen of a randomized trial. Am J Obstet Gynecol. 2005;193(5):1630-9. [pmid: 16260202].
62 Czekierdowski A. Studies on angiogenesis in the benign and malignant ovarian neoplasms with the use of color and pulsed Doppler sonography and serum CA-125, CA-19.9, CA-72.4 and vascular endothelial growth factor measurements. Ann Univ Mariae Curie Sklodowska [Med]. 2002;57(1):113-31.
63 Wakahara F, Kikkawa F, Nawa A, et al. Diagnostic efficacy of tumor markers, sonography, and intraoperative frozen section for ovarian tumors. Gynecol Obstet Invest. 2001;52(3):147-52. [pmid: 11598354].
64 Schutter EM, Sohn C, Kristen P, et al. Estimation of probability of malignancy using a logistic model combining physical examination, ultrasound, serum CA 125, and serum CA 72-4 in postmenopausal women with a pelvic mass: an international multicenter study. Gynecol Oncol. 1998;69(1):56-63. [pmid: 9570999].
65 Fayed ST, Ahmad SM, Kassim SK, et al. The value of CA 125 and CA72-4 in management of patients with epithelial ovarian cancer. Dis Markers. 1998;14(3):155-60. [pmid: 10427474].
66 Zakrzewska I, Borawska R, Poznanski J, et al. Significance of some tumor markers in differential diagnosis of ovarian tumor. Rocz Akad Med Bialymst. 1999;44:235-43. [pmid: 10697438].
67 Tanir HM, Ozalp S, Yalcin OT, et al. Preoperative serum vascular endothelial growth factor (VEGF) in ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):271-4. [pmid: 12807238].
68 Gorelik E, Landsittel DP, Marrangoni AM, et al. Multiplexed immunobead-based cytokine profiling for early detection of ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(4):981-7. [pmid: 15824174].
69 Obermair A, Tempfer C, Hefler L, et al. Concentration of vascular endothelial growth factor (VEGF) in the serum of patients with suspected ovarian cancer. Br J Cancer. 1998;77(11):1870-4. [pmid: 9667661].
70 Cooper BC, Ritchie JM, Broghammer CL, et al. Preoperative serum vascular endothelial growth factor levels: significance in ovarian cancer. Clin Cancer Res. 2002;8(10):3193-7. [pmid: 12374688].
71 Oehler MK, Caffier H. Diagnostic value of serum VEGF in women with ovarian tumors. Anticancer Res. 1999;19(4A):2519-22. [pmid: 10470186].
72 Abdel-Aleem H, Ahmed A, Sabra AM, et al. Serum alpha L-fucosidase enzyme activity in ovarian and other female genital tract tumors. Int J Gynaecol Obstet. 1996;55(3):273-9. [pmid: 9003953].
73 Cherchi PL, Capobianco G, Ambrosini G, et al. Intracystic evaluation of tumor markers in benign and malignant ovarian pathology. Eur J Gynaecol Oncol. 2002;23(2):163-5. [pmid: 12013118].
74 Mabrouk RA, Ali-Labib R. Detection of urokinase plasminogen activator receptor and c-erbB-2 in sera of patients with breast and ovarian carcinoma. Clin Biochem. 2003;36(7):537-43. [pmid: 14563447].
75 Inaba N, Negishi Y, Fukasawa I, et al. Cytokeratin fragment 21-1 in gynecologic malignancy: comparison with cancer antigen 125 and squamous cell carcinoma-related antigen. Tumour Biol. 1995;16(6):345-52. [pmid: 7569681].
76 Tempfer C, Hefler L, Heinzl H, et al. CYFRA 21-1 serum levels in women with adnexal masses and inflammatory diseases. Br J Cancer. 1998;78(8):1108-12. [pmid: 9792159].
77 Kim JH, Herlyn D, Wong KK, et al. Identification of epithelial cell adhesion molecule autoantibody in patients with ovarian cancer. Clin Cancer Res. 2003;9(13):4782-91. [pmid: 14581349].
78 Hefler L, Mayerhofer K, Nardi A, et al. Serum soluble Fas levels in ovarian cancer. Obstet Gynecol. 2000;96(1):65-9. [pmid: 10862844].
79 Diamandis EP, Scorilas A, Fracchioli S, et al. Human kallikrein 6 (hK6): a new potential serum biomarker for diagnosis and prognosis of ovarian carcinoma. J Clin Oncol. 2003;21(6):1035-43. [pmid: 12637468].
80 Luo LY, Bunting P, Scorilas A, et al. Human kallikrein 10: a novel tumor marker for ovarian carcinoma?. Clin Chim Acta. 2001;306(12):111-8. [pmid: 11282101].
81 Berek JS, Chung C, Kaldi K, et al. Serum interleukin-6 levels correlate with disease status in patients with epithelial ovarian cancer. Am J Obstet Gynecol. 1991;164(4):1038-42. discussion 1042–3. [pmid: 2014824].
82 van Haaften-Day C, Shen Y, Xu F, et al. OVX1, macrophage-colony stimulating factor, and CA-125-II as tumor markers for epithelial ovarian carcinoma: a critical appraisal. Cancer. 2001;92(11):2837-44. [pmid: 11753957].
83 Bon GG, Verheijen RH, Zuetenhorst JM, et al. Mucin-like carcinoma-associated antigen serum levels in patients with adenocarcinomas originating from ovary, breast and colon. Gynecol Obstet Invest. 1996;42(1):58-62. [pmid: 8840180].
84 Onsrud M, Shabana A, Austgulen R. Soluble tumor necrosis factor receptors and CA 125 in serum as markers for epithelial ovarian cancer. Tumour Biol. 1996;17(2):90-6. [pmid: 8658018].
85 Opala T, Rzymski P, Wilczak M, et al. Evaluation of soluble tumour necrosis factor alpha receptors p55 and p75 in ovarian cancer patients. Eur J Gynaecol Oncol. 2005;26(1):43-6. [pmid: 15754999].
86 Tsukishiro S, Suzumori N, Nishikawa H, et al. Use of serum secretory leukocyte protease inhibitor levels in patients to improve specificity of ovarian cancer diagnosis. Gynecol Oncol. 2005;96(2):516-9. [pmid: 15661245].
87 Darai E, Bringuier AF, Walker-Combrouze F, et al. Soluble adhesion molecules in serum and cyst fluid from patients with cystic tumours of the ovary. Hum Reprod. 1998;13(10):2831-5. [pmid: 9804241].
88 Baron AT, Cora EM, Lafky JM, et al. Soluble epidermal growth factor receptor (sEGFR/sErbB1) as a potential risk, screening, and diagnostic serum biomarker of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(2):103-13. [pmid: 12582019].
89 Baron AT, Boardman CH, Lafky JM, et al. Soluble epidermal growth factor receptor (SEG-FR) and cancer antigen 125 (CA125) as screening and diagnostic tests for epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(2):306-18. [pmid: 15734951].
90 Udagawa Y, Aoki D, Ito K, et al. Clinical characteristics of a newly developed ovarian tumour marker, galactosyltransferase associated with tumour (GAT). Eur J Cancer. 1998;34(4):489-95. [pmid: 9713298].
91 Sedlaczek P, Frydecka I, Gabrys M, et al. Comparative analysis of CA125, tissue polypeptide specific antigen, and soluble interleukin-2 receptor alpha levels in sera, cyst, and ascitic fluids from patients with ovarian carcinoma. Cancer. 2002;95(9):1886-93. [pmid: 12404282].
92 Hurteau JA, Woolas RP, Jacobs IJ, et al. Soluble interleukin-2 receptor alpha is elevated in sera of patients with benign ovarian neoplasms and epithelial ovarian cancer. Cancer. 1995;76(9):1615-20. [pmid: 8635066].
93 Opala T, Drews K, Rzymski P, et al. Evaluation of soluble intracellular adhesion molecule-1 (sICAM-1) in benign and malignant ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):255-7. [pmid: 12807235].
94 McIntosh MW, Drescher C, Karlan B, et al. Combining CA 125 and SMR serum markers for diagnosis and early detection of ovarian carcinoma. Gynecol Oncol. 2004;95(1):9-15. [pmid: 15385104].
95 Medl M, Ogris E, Peters-Engl C, et al. TATI (tumour-associated trypsin inhibitor) as a marker of ovarian cancer. Br J Cancer. 1995;71(5):1051-4. [pmid: 7734298].
96 Peters-Engl C, Medl M, Ogris E, et al. Tumor-associated trypsin inhibitor (TATI) and cancer antigen 125 (CA125) in patients with epithelial ovarian cancer. Anticancer Res. 1995;15(6B):2727-30. [pmid: 8669854].
97 Schutter EM, Mijatovic V, Kok A, et al. Urinary gonadotropin peptide (UGP) and serum CA 125 in gynaecologic practice, a clinical prospective study. Anticancer Res. 1999;19(6C):5551-7. [pmid: 10697615].
98 Hofmann M, Ruschenburg I. mRNA detection of tumor-rejection genes BAGE, GAGE, and MAGE in peritoneal fluid from patients with ovarian carcinoma as a potential diagnostic tool. Cancer. 2002;96(3):187-93. [pmid: 12115308].
99 Hibbs K, Skubitz KM, Pambuccian SE, et al. Differential gene expression in ovarian carcinoma: identification of potential biomarkers. Am J Pathol. 2004;165(2):397-414. [pmid: 15277215]. [pmcid: 1618570].
100 Takano H, Okamoto A, Fukushima K, et al. Low specificity of cytokeratin 19 mRNA expression in the peripheral blood cells from patients with ovarian tumors. Oncol Rep. 2000;7(5):1023-5. [pmid: 10948333].
101 Bourne TH, Campbell S, Reynolds KM, et al. Screening for early familial ovarian cancer with transvaginal ultrasonography and colour blood flow imaging. BMJ. 1993;306(6884):1025-9. [pmid: 8490496]. [pmcid: 1677026].
102 Balbi GC, Cardone A, Passaro M, et al. Comparative evaluation of standard criteria and CA-125 in ovarian cancers treated with platinum or paclitaxel. Eur J Gynaecol Oncol. 2005;26(3):285-7. [pmid: 15991527].
103 Gadducci A, Cosio S, Fanucchi A, et al. The predictive and prognostic value of serum CA 125 half-life during paclitaxel/platinum-based chemotherapy in patients with advanced ovarian carcinoma. Gynecol Oncol. 2004;93(1):131-6. [pmid: 15047226].
104 Rustin GJ, Marples M, Nelstrop AE, et al. Use of CA-125 to define progression of ovarian cancer in patients with persistently elevated levels. J Clin Oncol. 2001;19(20):4054-7. [pmid: 11600607].
105 Rustin GJ, Nelstrop AE, Tuxen MK, et al. Defining progression of ovarian carcinoma during follow-up according to CA 125: a North Thames Ovary Group Study. Ann Oncol. 1996;7(4):361-4. [pmid: 8805927].
106 Gronlund B, Hansen HH, Hogdall C, et al. Do CA125 response criteria overestimate tumour response in second-line treatment of epithelial ovarian carcinoma?. Br J Cancer. 2004;90(2):377-82. [pmid: 14735180].
107 Izquierdo MA, van der Zee AG, Vermorken JB, et al. Drug resistance-associated marker Lrp for prediction of response to chemotherapy and prognoses in advanced ovarian carcinoma. J Natl Cancer Inst. 1995;87(16):1230-7. [pmid: 7563169].
108 Kamazawa S, Kigawa J, Kanamori Y, et al. Multidrug resistance gene-1 is a useful predictor of Paclitaxel-based chemotherapy for patients with ovarian cancer. Gynecol Oncol. 2002;86(2):171-6. [pmid: 12144824].
109 Kupryjanczyk J, Szymanska T, Madry R, et al. Evaluation of clinical significance of TP53, BCL-2, BAX and MEK1 expression in 229 ovarian carcinomas treated with platinum-based regimen. Br J Cancer. 2003;88(6):848-54. [pmid: 12644821].
110 Lassus H, Leminen A, Vayrynen A, et al. ERBB2 amplification is superior to protein expression status in predicting patient outcome in serous ovarian carcinoma. Gynecol Oncol. 2004;92(1):31-9. [pmid: 14751135].
111 Luo LY, Katsaros D, Scorilas A, et al. The serum concentration of human kallikrein 10 represents a novel biomarker for ovarian cancer diagnosis and prognosis. Cancer Res. 2003;63(4):807-11. [pmid: 12591730].
112 Folk JJ, Botsford M, Musa AG. Monitoring cancer antigen 125 levels in induction chemotherapy for epithelial ovarian carcinoma and predicting outcome of second-look procedure. Gynecol Oncol. 1995;57(2):178-82. [pmid: 7729730].
113 Hogdall CK, Hogdall EV, Hording U, et al. Use of tetranectin, CA-125 and CASA to predict residual tumor and survival at second- and third-look operations for ovarian cancer. Acta Oncol. 1996;35(1):63-9. [pmid: 8619942].
114 Kierkegaard O, Mogensen O, Mogensen B, et al. Predictive and prognostic values of cancer-associated serum antigen (CASA) and cancer antigen 125 (CA 125) levels prior to second-look laparotomy for ovarian cancer. Gynecol Oncol. 1995;59(2):251-4. [pmid: 7590482].
115 Senapad S, Neungton S, Thirapakawong C, et al. Predictive value of the combined serum CA 125 and TPS during chemotherapy and before second-look laparotomy in epithelial ovarian cancer. Anticancer Res. 2000;20(2B):1297-300. [pmid: 10810438].
116 Wong C, Dai ZM, Lele SB, et al. Comparison of CA 125 after three courses of chemotherapy and results of second-look surgery. Eur J Gynaecol Oncol. 2000;21(1):70-3. [pmid: 10726624].
117 Baekelandt M, Holm R, Trope CG, et al. The significance of metastasis-related factors cathepsin-D and nm23 in advanced ovarian cancer. Ann Oncol. 1999;10(11):1335-41. [pmid: 10631462].
118 Baekelandt M, Kristensen GB, Nesland JM, et al. Clinical significance of apoptosis-related factors p53, Mdm2, and Bcl-2 in advanced ovarian cancer. J Clin Oncol. 1999;17(7):2061. [pmid: 10561259].
119 Gadducci A, Ferdeghini M, Cosio S, et al. The clinical relevance of serum CYFRA 21-1 assay in patients with ovarian cancer. Int J Gynecol Cancer. 2001;11(4):277-82. [pmid: 11520365].
120 Ayhan A, Tuncer ZS, Ayhan A. p53 expression in ovarian carcinoma with regard to second-look findings. Eur J Gynaecol Oncol. 1998;19(5):501-2. [pmid: 9863925].
121 Hoskins WJ, Bundy BN, Thigpen JT, et al. The influence of cytoreductive surgery on recurrence-free interval and survival in small-volume stage III epithelial ovarian cancer: a Gynecologic Oncology Group study. Gynecol Oncol. 1992;47(2):159-66. [pmid: 1468693].
122 Berchuck A, Iversen ES, Lancaster JM, et al. Prediction of optimal versus suboptimal cytoreduction of advanced-stage serous ovarian cancer with the use of microarrays. Am J Obstet Gynecol. 2004;190(4):910-25. [pmid: 15118612].
123 Gemer O, Segal S, Kopmar A. Preoperative CA-125 level as a predictor of non optimal cytoreduction of advanced epithelial ovarian cancer. Acta Obstet Gynecol Scand. 2001;80(6):583-5. [pmid: 11380298].
124 Memarzadeh S, Lee SB, Berek JS, et al. CA125 levels are a weak predictor of optimal cytoreductive surgery in patients with advanced epithelial ovarian cancer. Int J Gynecol Cancer. 2003;13(2):120-4. [pmid: 12657110].
125 Obeidat B, Latimer J, Crawford R. Can optimal primary cytoreduction be predicted in advanced stage epithelial ovarian cancer? Role of preoperative serum CA-125 level. Gynecol Obstet Invest. 2004;57(3):153-6. [pmid: 14726621].
126 Saygili U, Guclu S, Uslu T, et al. Can serum CA-125 levels predict the optimal primary cytoreduction in patients with advanced ovarian carcinoma?. Gynecol Oncol. 2002;86(1):57-61. [pmid: 12079301].
127 Gemer O, Lurian M, Gdalevich M, et al. A multicenter study of CA 125 level as a predictor of non-optimal primary cytoreduction of advanced epithelial ovarian cancer. Eur J Surg Oncol. 2005;31(9):1006-10. [pmid: 16005601].
128 Greer BE, Bundy BN, Ozols RF, et al. Implications of second-look laparotomy in the context of optimally resected stage III ovarian cancer: a non-randomized comparison using an explanatory analysis: a Gynecologic Oncology Group study. Gynecol Oncol. 2005;99(1):71-9. [pmid: 16039699].
129 Vergote I, van Gorp T, Amant F, et al. Neoadjuvant chemotherapy for ovarian cancer. Oncology (Huntingt). 2005;19(12):1615-22. discussion 1623–30. [pmid: 16396153].
130 McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. Am J Med Genet A. 2004;130(3):221-7. [pmid: 15378542].
131 McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families II: impact on relationships. Am J Med Genet A. 2005;133(2):165-9. [pmid: 15633195].
132 Bish A, Sutton S, Jacobs C, et al. Changes in psychological distress after cancer genetic counselling: a comparison of affected and unaffected women. Br J Cancer. 2002;86(1):43-50. [pmid: 11857010].
133 Claes E, Evers-Kiebooms G, Denayer L, et al. Predictive genetic testing for hereditary breast and ovarian cancer: psychological distress and illness representations 1 year following disclosure. J Genet Couns. 2005;14(5):349-63. [pmid: 16195942].
134 Centers for Disease Control and Prevention (CDC). Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing—Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. Morb Mortal Wkly Rep Surveill Summ. 2004;53(27):603-6.
135 Mouchawar J, Hensley-Alford S, Laurion S, et al. Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005;7(3):191-7. [pmid: 15775755].
136 Berchuck A, Iversen ES, Lancaster JM, et al. Patterns of gene expression that characterize long-term survival in advanced stage serous ovarian cancers. Clin Cancer Res. 2005;11(10):3686-96. [pmid: 15897565].
137 Jacobs IJ, Menon U. Progress and challenges in screening for early detection of ovarian cancer. Mol Cell Proteomics. 2004;3(4):355-66. [pmid: 14764655].
138 Drescher CW, Nelson J, Peacock S, et al. Compliance of average- and intermediate-risk women to semiannual ovarian cancer screening. Cancer Epidemiol Biomarkers Prev. 2004;13(4):600-6. [pmid: 15066925].