# Executive Summary

## Introduction

Ovarian cancer is the leading cause of cancer death from gynecologic malignancies in the United States, with an annual incidence of over 25,000 and an annual mortality of approximately 14,000. Cancer incidence increases dramatically with age.

The high case-fatality rate has largely been attributed to the fact that most ovarian cancers are diagnosed in advanced stages (Stage III, where the cancer has spread beyond the pelvis to the organs of the upper abdominal cavity, and Stage IV, where the cancer has spread outside the peritoneal cavity). Stage I cancer (limited to the ovaries) has a survival rate of over 90 percent.

There are five potential strategies for prevention of the morbidity and mortality from ovarian cancer. One is primary prevention through either medical or surgical therapy in the general population. Although observational studies suggest that the risk of developing ovarian cancer is reduced in women who used oral contraceptives or underwent tubal ligation, there are no prospective trials to allow estimation of the risks and benefits of these options specifically for ovarian cancer prevention. Although in theory prophylactic oophorectomy at the time of hysterectomy for other diseases should almost eliminate the chances of developing ovarian cancer, there are also no prospective studies of the benefits of this approach, and a recent decision analysis suggested that the harms in terms of other effects might outweigh the benefits. An alternative strategy for primary prevention is identifying groups of women at particularly high risk of developing ovarian cancer, and then using primary prevention strategies. Observational studies suggest that use of oral contraceptives reduces risk of ovarian cancer in women with inherited predisposition to ovarian cancer, but this has not been tested prospectively. Prophylactic oophorectomy does appear to reduce the risk of ovarian cancer in high-risk groups.

Another strategy for prevention of ovarian cancer mortality is screening to detect early stage cancers, either in the general population or in high-risk groups. To date, screening using the available technologies of physical examination, ultrasound, and/or cancer antigen 125 (CA-125) has not been shown to be effective in either situation.

Finally, use of targeted therapy based on the results of tests may identify subgroups of patients for whom specific therapies are likely to be effective; for example, identification of overexpression of human epidermal growth factor 2 (HER 2) in some breast cancers has led to improved survival with the use of a monoclonal antibody targeted against the receptor. To date, similar breakthroughs have not occurred in ovarian cancer.

Continued developments in technology have led to rapidly expanding knowledge about genes, gene expression, and protein patterns in a variety of disease processes. Because currently available strategies for the prevention of ovarian cancer have not proven as effective as interventions targeted against other cancers in women, there has been tremendous interest in using the tools of genomics and proteomics to identify potential new markers which can be used in any of the five classes of strategies. Although the term “genomics” has been used in many different ways, for the purposes of this report we define “genomic tests” as one of the following broad categories: (1) tests for the presence or quantity of the product of a single gene - the classic example of this is radioimmunoassay for CA-125; (2) tests for inherited or acquired mutations in genes which convey an increased risk of developing ovarian cancer, or which predict differential responses to therapy - the classic example is testing for polymorphisms of breast cancer genes 1 and 2 (BRCA 1/2); (3) tests for quantitative expression of either single genes or multiple genes - differential patterns of expression between normal patients and ovarian cancer patients may aid in diagnosis and management, or help identify potential new single gene products for evaluation as screening and diagnostic tools; and (4) tests for protein expression, particularly in serum, which identify differential patterns between normal patients and patients with ovarian cancer.

This report focuses on the current evidence for the clinical utility of genomic tests, as defined above, in any of the five potential strategies for reducing ovarian cancer morbidity and mortality. Because evidence on the use of CA-125 for screening and diagnosis of ovarian cancer and the use of BRCA1/2 testing for identification of high-risk patients has been covered in recent evidence reports, we do not review that evidence directly; we do summarize the results of the earlier reports and discuss relevant studies subsequently published. The results of the present report are intended primarily to: (a) provide a resource for the Evaluation of Genomics Applications in Practice and Prevention (EGAPP) project of the Centers for Disease Control and Prevention (CDC); (b) provide a resource for other clinicians and policymakers developing guidelines on the use of genomic tests in ovarian cancer prevention; and (c) provide a resource for researchers and funding agencies in identifying gaps in our knowledge and research priorities.

## Methods

Working with the Agency for Healthcare Research and Quality (AHRQ), the CDC, the EGAPP working group, and members of the technical expert panel, we refined six research questions to be addressed, using an analytic framework which incorporated probability of developing ovarian cancer, test results, and management based on those tests results.

We searched MEDLINE^®^ (1966–May 2006). Searches of the databases were supplemented by reviews of reference lists of included articles, relevant review articles, and meta-analyses. We also searched the Food and Drug Administration web site for relevant documents. The searches yielded a total of 1,303 citations. Pairs of readers reviewed each abstract and selected 552 articles for full text review. Specific inclusion criteria were developed for each question, and both readers were required to agree on inclusion. After this review, a total of 113 articles were included for abstraction.

We developed tables to abstract each article, and quality criteria were adapted from the evidence report on omega-3 fatty acids for coronary heart disease prevention. For studies of diagnostic test performance, 2-by-2 tables were constructed for each included article, and sensitivity, specificity, and positive and negative predictive values, with 95 percent confidence intervals, were calculated.

We also further refined a Markov model of the natural history of ovarian cancer; the model is able to closely approximate age-specific incidence and mortality from ovarian cancer under two different assumptions about natural history - one that requires a stepwise progression through all four stages of the disease, and one which allows some cancers to spread directly from the ovaries (Stage I) to the upper abdomen (Stage III). The model is then used to estimate the implications of these different assumptions on the relative effectiveness of different prevention strategies.

## Results

### Literature on Key Questions

Question 1: What is the evidence that ovarian cancer genomic tests performed in a typical clinical laboratory actually measure what they are purported to measure? The published data on clinical laboratory performance suggests that currently available radioimmunoassays for single gene products have acceptable reproducibility and reliability, although even this level of variability may have some impact on clinical interpretation of results, especially when comparing relatively small serial changes, or levels close to the discriminatory threshold.

There is insufficient evidence to estimate how newer technologies such as microarrays or protein profiles would perform in a “typical clinical laboratory.”

Question 2: What is the sensitivity and specificity of genomic tests in detecting ovarian cancer in asymptomatic and symptomatic women, including high-risk women? In general, single gene products other than CA-125 have not been shown to be useful in the diagnosis of ovarian cancer, either in symptomatic or asymptomatic women; the sensitivity of CA-125 in screening populations is approximately 80 percent. Small sample sizes, lack of detail on the prediagnosis history of patients, and an unrealistically high prevalence of ovarian cancer in the majority of studies make it difficult to assess how any of these tests would perform in clinical practice.

Estimating the clinical value of more complex tests, using multiple gene and/or protein markers, is even more difficult. Studies of protein expression, in particular, are limited by lack of consensus on appropriate statistical methods, small sample sizes with substantially higher prevalences of ovarian cancer than would be found in the general population, spectrum bias, lack of reproducibility, and uncertainty about the specificity of the biological processes resulting in the observed protein patterns.

Question 3: What is the evidence that genomic testing to detect ovarian cancer in asymptomatic women, including high-risk women, changes clinical management and leads to improved clinical outcomes? We did not identify any evidence on the value of tests other than CA-125 to detect ovarian cancer in asymptomatic women. CA-125 has not been shown to improve ovarian cancer mortality or quality of life; in series of women with mutations of BRCA1 and BRCA2, screening with CA-125 and transvaginal ultrasound does not appear to prevent development of advanced stage ovarian cancer.

Question 4: What is the evidence that genomic testing in women with clinical suspicion of ovarian cancer or with already-diagnosed ovarian cancer changes clinical management and leads to improved health outcomes? Although there is a reasonable amount of data on the association between genomic tests, particularly CA-125, and the likelihood of different clinical outcomes, we did not identify any studies which provided evidence for changes in management leading to improved outcomes based on the results of the tests, other than for CA-125. Based on the results of another evidence report, CA-125 is helpful in distinguishing malignant from benign masses in postmenopausal women.

Question 5: What are the harms of using genomic tests for ovarian cancer prevention and management? The majority of the available literature focuses on BRCA1/2 testing and rarely describes results specifically for ovarian cancer. In the few studies that did, concerns about the risk of ovarian cancer were considerably less than for breast cancer; it is unclear whether testing for genetic markers of ovarian cancer susceptibility alone has different implications compared to testing for genes which affect both breast and ovarian cancer risk.

Conceptually, the harms of testing for genetic susceptibility for ovarian cancer should be no different than testing for genetic susceptibility of other cancers; the main issues are the effectiveness and potential risks of prevention strategies in those who are identified as high risk (primarily the risks of prophylactic oophorectomy), and issues related to reproduction. Similarly, the qualitative harms of the use of genomic tests for screening, diagnosis, and management - the psychological effect of a potential cancer diagnosis, the risks of diagnostic and therapeutic procedures including laparotomy, the harms of a false negative result leading to delayed or inappropriate management - are not conceptually different for genomic tests than for other types of tests, such as imaging; the main difference lies in the quantitative risks of these events, which in turn are determined by the sensitivity and specificity of the test and the pretest probability of disease.

Question 6: Has direct-to-consumer and direct-to-physician marketing of genomic tests for ovarian cancer increased the “appropriate” use of these tests? We identified two studies which compared utilization of BRCA1/2 tests for breast and ovarian cancer susceptibility before and after an advertising campaign; in both cases, utilization was compared in cities where the campaign was put in place to geographically distant cities where there was no formal campaign. The studies suggested increased utilization of testing, and one study found that the positive predictive value of testing declined after the campaign, but there was no way to judge whether the changes in testing were “appropriate.”

### Modeling Results

The model is able to approximate reported age-specific incidence and mortality from ovarian cancer under both assumptions about natural history. At a given value for test sensitivity, screening was less effective in reducing mortality in a model assuming direct transition from Stage I to Stage III than one assuming that all cancers progress to Stage II prior to Stage III. However, screening frequency was much more important than test sensitivity; even at a test sensitivity of 99 percent, screening frequencies of less than 12 months are needed to reduce ovarian cancer mortality by more than 50 percent. At these high screening frequencies, positive predictive values are less than three percent, even for a test with specificity of 99 percent.

## Discussion

### Limitations of the Report

The report did not include non-English publications. We did not formally attempt to estimate pooled sensitivity and specificity for tests because of heterogeneity of study design. Because many of the parameters in the natural history of ovarian cancer are unknown, any model will require assumptions and imputation of key parameters; calibrating a cohort model to cross-sectional data may result in errors in the imputation of these parameters because of unmeasured cohort effects in the cross-sectional data.

### Limitations of the Literature

Common limitations of the literature included: failure to adequately describe relevant patient characteristics; small sample size with subsequent wide confidence intervals for estimates of sensitivity and specificity; unrealistically high prevalences of ovarian cancer; a spectrum of disease severity which does not reflect screening populations; lack of reproducibility for complex statistical algorithms; potentially inappropriate choices for cases and controls in initial developmental studies; and underlying assumptions about the natural history of ovarian cancer that may not reflect the actual biology of the disease.

## Future Research

Research priorities include:

- A minimal consensus data set on key patient characteristics, with results presented with stratification by those characteristics as appropriate;
- Consensus reporting of key laboratory performance characteristics such as reproducibility, with estimates of the impact of reproducibility on test performance in practice;
- Documentation of the effect of any biological variability in test results within subjects on interpretation of results, especially for tests designed to be used in a serial fashion;
- Better characterization of true “negative” results, with documentation of followup;
- Evaluation of tests in realistic clinical situations, especially with regards to pretest probability;
- Explicit evaluation of the effect of management changes based on test results on patient outcomes; and
- Better understanding of the natural history of ovarian cancer in order to help prioritize research into better prevention strategies.

## Conclusions

Despite intensive research efforts, ovarian cancer remains a leading cause of cancer death in women, and efforts at reducing its impact have been noticeably less successful than those for other cancers in women.

The prospect of new strategies for the prevention of ovarian cancer morbidity and mortality based on greater understanding of the molecular biology of the disease is exciting; unfortunately, we did not find any evidence that currently available tests have had a substantial impact on improving patient outcomes. Our modeling work suggests that the natural history of ovarian cancer may make substantial mortality reductions difficult using a strategy based primarily on screening. Although research remains promising, adaptation of genomic tests into clinical practice must await appropriately designed and powered studies in relevant clinical settings.