# Acknowledgments

The authors gratefully acknowledge R. Julian Irvine for assistance with project management and copy-editing, Udita Patel for assistance with project management, and Dr. Gurvaneet Randhawa, AHRQ Task Order Officer, for overall assistance.

The authors also acknowledge the contributions of Dr. Ralph Coates of the Centers for Disease Control and Prevention's (CDC) Division of Cancer Prevention and Control and Dr. Linda Bradley in the CDC's Office of Genomics.