# Conclusions

Ovarian cancer remains a significant cause of morbidity and mortality in women, and efforts at reducing its toll have been relatively unsuccessful, especially when compared with other causes of cancer death in women. Unlike lung cancer or cervical cancer, there does not appear to be a common causal exposure which can be addressed through various public health interventions; unlike cervical, breast, or colorectal cancer, effective screening methods have not yet been identified; unlike breast cancer, markers of response to specific treatments have not yet been discovered and proven to improve patient outcomes.

The ever-increasing knowledge of the role of genes in health and disease offers the promise of greater understanding of the biology of ovarian cancer, and evidence-based strategies for prevention based on that understanding. Understanding of the causal mechanisms could potentially lead to population-based primary prevention strategies which preserve ovarian function, while identification of markers of increased risk in addition to breast cancer genes 1/2 (BRCA 1/2) offers the potential for more radical preventive measures such as prophylactic oophorectomy. Improved understanding of the molecular changes leading to cancer may lead to screening tests of very high sensitivity and specificity. Identification of markers of response to therapy could lead to improved survival, or reduced side effects from current treatment.

Unfortunately, our review found that there is limited evidence for the utility of genomic tests other than cancer antigen 125 (CA-125) or BRCA1/2 in the prevention of ovarian cancer. Other than commercially approved radioimmunoassay tests for single gene products, there is little available literature on the analytic validity of potential genomic tests in typical clinical laboratories. There are almost no data on the sensitivity and specificity of genomic tests for screening or diagnosis in clinically realistic settings. Although results of some genomic tests have been shown to be associated with certain outcomes of treatment, there are no data on how changes in management based on those test results would lead to improved patient outcomes.

New genomic tests do not appear to have any qualitative risks beyond those of other tests for inherited susceptibility for cancer, or other tests used in screening, management, and treatment. Depending on the ultimate sensitivity and specificity of the tests in typical practice, the quantitative probability of these harms may differ from existing tests.

The use of direct-to-consumer advertising has the potential to increase utilization of these tests, but, in the absence of criteria for “appropriate use,” it is unclear how to evaluate this increased utilization.

Ultimately, the clinical utility of genomic tests in the prevention of morbidity and mortality from ovarian cancer will depend not only on the sensitivity and specificity of a given test in a specific clinical situation, but on the underlying natural history of ovarian cancer. If the biological features of ovarian cancer predispose most cancers to rapid dissemination within the abdominal cavity, then strategies which emphasize primary prevention and/or improved treatment efficacy may ultimately be more effective than the most sensitive and specific test.