# Discussion

## Limitations of the Report

There are several limitations to this evidence report:

- We did not review articles published in languages other than English because of a lack of resources for translation. It is possible that this led to failure to include some relevant studies.
- We did not attempt to perform meta-analysis of specific tests, because of the considerable heterogeneity in design and patient populations.
- Although we attempted to provide some sense of study quality, the validity and reproducibility of measures of study quality is uncertain.
- Many of the key parameters used in modeling ovarian cancer incidence and mortality are unknown, and, in some cases, unknowable. In particular, this is true for the probability of progression between stages, and the probability that a woman with ovarian cancer at a given stage will have her cancer detected on the basis of symptoms. Although the model can be calibrated to provide a good fit to current data, it is possible that choices about the imputed values used for these parameters are incorrect in ways that affect the validity of the model.
- The model is calibrated against reported age-specific incidence. Because the model simulates a cohort but is calibrated against cross-sectional age-specific data, it is possible that cohort effects in important variables, such as exposure to causes of ovarian cancer, exposure to risk modifiers such as pregnancy or contraceptive use, or competing risks such as other cause mortality or oophorectomy rates, play important roles in the observed incidence in specific age groups. Failure to take these into account during calibration may result in errors in the model (this is a common but rarely discussed issue with almost all cohort models of cancer incidence).

## Methodological Issues in the Literature

### Description of the Patient Population

Many of the issues identified in the evidence report on adnexal mass ^14^ were found in this literature as well. The majority of the papers reviewed failed to adequately describe the patient population; in particular, for those studies that included women with both benign and malignant ovarian disease, the manner in which the mass was originally detected and the subsequent evaluation can affect the probability of underlying disease, and thus predictive values. Depending on study design, prevalence may also indirectly affect estimates of sensitivity and specificity, especially in cases where women who have a negative test do not undergo the reference standard evaluation. Thus, even though the performance of a given test may vary depending on whether the patient is symptomatic or asymptomatic, the failure of studies to describe this aspect of their population makes drawing inference about applicability in specific clinical settings difficult.

Another common shortcoming was the failure of many studies to describe potential differences in results stratified by age or menopausal status. Given the clear and widely recognized relationship between age and ovarian cancer risk, as well as the effect of menopausal status on the prevalence of biological processes that may affect the levels of some tumor markers such as cancer antigen 125 (CA-125), we believe that this should be standard in all studies of potential ovarian cancer tests. This is especially true for studies of complex phenomena such as multiple gene or protein expression patterns, where the discovery process is based on identifying differences in patterns between populations; if some of the identified differences between cancer patients and controls in gene expression or protein profiles are in fact differences related to aging, menopausal status, or other processes unrelated to ovarian cancer, the ultimate sensitivity and specificity of tests based on these pattern recognitions may be substantially worse than in preliminary reports.

### Sample Size

Few of the studies we reviewed included a priori sample size calculations, and use of confidence intervals for parameter estimates was uncommon. Our calculated confidence intervals were, for the most part, quite wide.

### Prevalence of Ovarian Cancer in Samples

The majority of the studies we reviewed included prevalence of ovarian cancer of 30 to 60 percent. In a screening setting, this is several orders of magnitude higher than the observed prevalence in screening studies in the U.S. of 0.05 to 0.2 percent. ^14^ This higher prevalence leads to falsely decreased confidence intervals for the estimates of sensitivity. Even more importantly, as only one author ^59^ pointed out, this prevalence lowers the positive predictive value of tests to substantially less than 5 percent.

The prevalence in studies of the diagnostic use of a test would be expected to be higher, but, as discussed above, how much higher is dependent on the age, menopausal status, symptom status, etc., of the patient. Failure to describe these characteristics prevents assessment of how closely the study population reflects a likely clinical population.

### Stage Distribution within Samples

Given that most ovarian cancer presents in later stages, the stage distribution of samples used for test development and validation is likely to be skewed towards later stages. Any abnormalities identified may be more common in advanced cancers than early cancers; since the goal of screening is to identify early stage (or even preinvasive cancers), the sensitivity for tests derived from these types of samples may be quite lower in real-world settings. This is especially true for tests which identify simultaneous multiple changes in a variety of markers (such as gene arrays or studies of protein patterns) without a clear understanding of the underlying biological significance of the changes. Changes associated with late stage cancer may not be seen in early cancers.

### Biological and Observer Variability in Test Results

Many studies, especially of tests for single gene products, reported measures of assay reproducibility. However, we identified only one series of studies ^40,^ ^41^ that reported on the impact of both test and biological variability on interpretation of test results, in this case the significance of changes in CA-125 levels. Since both test reproducibility and biological variations may affect test characteristics (especially in applications where serial measurements are used to make clinical decisions), documentation of these effects for other tests should be required.

Similarly, for studies of multiple gene or protein expression, demonstration of reproducibility of results by different groups using similar analytic approaches is necessary; the available evidence suggests that reproducibility is still an issue. ^55,^ ^59^

### Use of Tests for Decisionmaking in Management

The majority of the studies we identified on the use of genomic tests in patients already diagnosed with ovarian cancer reported on associations between test results and certain clinical outcomes, such as lack of response to chemotherapy, positive second look laparotomy, or length of overall or disease-free survival. We did not identify any studies which explicitly discussed how these results could be used, let alone any studies which formally tested the impact of use of the tests on patient outcomes. For example, if the results of a genomic test indicate a greater likelihood of failure to respond to standard chemotherapy, should that patient be offered only experimental therapies, or comfort care, rather than undergoing the effects of therapy which is unlikely to work? There are obvious ethical and feasibility issues involved in designing studies of such an approach, but if a patient will undergo the same therapy regardless of the results of the genomic tests, there seems to be little clinical value to performing the test. It is possible that there is some value to the patient and her family in having greater information about the probability of various outcomes, even if therapy is not affected, but this should be demonstrated using appropriate study designs and instruments.

### Selection of Cases and Controls in Initial Test Development

The most common approach to initial test development in the studies we reviewed was to use serum or tissue from patients with cancer and compare results to a comparison group with no disease, or with non-ovarian cancer disease. In some cases, an attempt was made to discriminate between normal women, women with early stage ovarian cancer, and women with late stage ovarian cancer, in the hopes of identifying markers of early stage disease.

There are several implicit assumptions involved with this type of study design:

- If attempts are not made to discriminate between stages, then the assumption is that all cancers, regardless of stage, exhibit a similar pattern. However, if there are changes in gene and/or protein patterns which are associated with advancing stage, failure to examine differences between stages may affect test accuracy.
- If stages are examined differently, then the assumption is that all of the advanced stage cancers must have “looked” like the early stage cancers at some point. However, if “early” stage cancers represent cancers which are biologically different, rather than an early, necessary step in the development of ovarian cancer, ^136^ then identification of markers of early stage cancer may not result in substantial reductions in mortality.
- There are no other factors other than ovarian cancer itself which can explain observed differences between cancers and controls. The effect of potential confounders such as age, menopausal status, or other factors on gene or protein patterns would affect test specificity substantially.

Ultimately, the ideal approach is to use prospectively collected sera to attempt to identify markers for those patients who subsequently developed advanced stage ovarian cancer, an approach which may be achievable in some of the large ongoing studies of ovarian cancer screening. ^137^

### Natural History of Ovarian Cancer

The search for better screening tests for ovarian cancer has been based on the implicit assumption that ovarian cancer progresses through a series of stages in a fashion analogous to that of cervical cancer. Alternative models are biologically plausible, and, as demonstrated by our simulation models, mathematical models can be “fitted” to match reported data under both alternatives. Our modeling suggests that, even under a model that assumes that all cancers progress through Stage II, screening at intervals more frequent than every 12 months is needed to reduce mortality by greater than 50 percent, even with a highly sensitive test, and that such screening would have a very low positive predictive value, even with a highly specific test.

If this is the case, then alternative methods for reducing ovarian cancer morbidity and mortality, such as improved methods for primary prevention and improved therapies, may ultimately offer more promise than the search for the Pap test equivalent in ovarian cancer.

## Implications of Findings

### Question 1 (Analytic Validity)

With the exception of studies of radioimmunoassay, there is little available literature on the analytic validity of genomic tests for ovarian cancer, especially for use in commercial or clinical laboratories.

### Question 2 (Sensitivity and Specificity)

Sensitivity and specificity of genomic tests in clinical practice are difficult to estimate, since there have been few well-designed studies in typical clinical situations, and estimates for available tests have wide confidence intervals. In particular, studies of proteomic tests have not been performed in realistic clinical scenarios; even with high specificity, positive predictive values in a screening setting are likely to be very low.

### Question 3 (Clinical Management of Asymptomatic Women)

We did not identify any articles which provided evidence on the use of genomic tests in asymptomatic women.

### Question 4 (Clinical Management of Diagnosed Women)

Although we identified articles reporting an association with various genomic test results and different clinical outcomes, we did not identify any studies which evaluated any change in management based on those test results.

### Question 5 (Potential Harms)

The potential harms of genomic testing fall into two categories: (1) those related to identification of inherited susceptibility to ovarian cancer, which include the psychological impact of test results, decisionmaking regarding reproduction, and decisionmaking regarding prophylaxis; and (2) those related to test results in a screening, diagnostic, or clinical setting, which primarily include the risks of diagnosis for false-positive results and the risks of delayed or inappropriate treatment of false-negative results. We did not identify any studies of the potential harms of testing for genetic susceptibility for genes uniquely associated with ovarian cancer; data from two small studies suggest that, among women at risk for breast cancer gene 1/2 (BRCA1/2) mutations, psychosocial/quality-of-life implications of testing are different for ovarian cancer compared with breast cancer. We also did not identify any literature on the harms of the use of genomic testing in screening, diagnosis, and treatment. Conceptually, there is no reason to think that these harms would be qualitatively any different for genomic tests than for other modalities such as pelvic examination, CA-125, or ultrasound; any differences between genomics-based tests and other would lie in the quantitative risks of false-positive and false-negative results.

### Question 6 (Direct Marketing)

We identified two studies on the impact of direct-to-consumer advertising for BRCA1 and 2 testing for susceptibility to both breast and ovarian cancer, which suggested increased utilization by both physicians and patients. Although one of the studies suggested that there was an increased use of the test among lower-risk women (as evidenced by a decrease in test positive predictive value), it is unclear whether this was truly “inappropriate.”

### Modeling

We were able to closely approximate reported ovarian cancer incidence and mortality using a simulation model. This model can be used to identify test and treatment characteristics that would result in substantial reductions in ovarian cancer mortality. The most striking finding of the model is that the effect of screening frequency in achieving large-scale reductions in ovarian cancer mortality is greater than that of test sensitivity; achieving mortality reductions greater than 50 percent requires screening frequencies of less than 12 months. This is problematic for several reasons. First, a pilot study suggests that women are unlikely to be compliant with more frequent screening intervals. ^138^ Second, more frequent screening results in lower overall positive predictive value, even with a highly specific test. Finally, if effective primary prevention strategies are identified which lower the incidence of ovarian cancer, the positive predictive value of screening will be lowered to an even larger extent.