# Results

## Question 1: Analytic Validity of Testing

Question 1 is: What is the evidence that the ovarian cancer genomic tests performed in a typical clinical laboratory actually measure what they are purported to measure?

### Approach

We sought to identify articles that provided details on the performance of genomic tests in a laboratory setting, with an emphasis on laboratories providing results for clinical care. Because data on sensitivity and specificity are covered under Question 2, our emphasis in this question was on evidence related to analytic performance, such as:

- Test reproducibility, as measured by inter- and intra-assay coefficients of variation for quantitative tests, or measurements of observer variability for tests that require human observation (such as immunohistochemistry).
- Measurements of correlation with other tests, including previous generations of other tests.
- Quantification of variability between laboratories.
- Analytic sensitivity and specificity in comparison to a recognized reference standard.

We included only articles that specifically addressed the laboratory performance of genomic tests for ovarian cancer. Although specific assays may have documented analytic validity when used for other cancers, or other conditions, our focus was on ovarian cancer.

### Results

Articles included for Question 1 are summarized in Evidence Table 1 (Appendix D *).

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/genovctp.htm.

Radioimmunoassays for single gene products - cancer antigen 125 (CA-125). We identified six articles that compared the performance of a next-generation radioimmunoassay (RIA) for CA-125 (CA-125 II) from various manufacturers to earlier generation tests or to other RIAs for other tumor markers. ^34^ – ^39^ All six studies reported high correlation coefficients with previous assays. All studies reported low inter- and intra-assay coefficients of variation (values generally less than 10 percent for inter-assay, less than 5 percent for intra-assay). Of note, two studies examined coefficients of variation at different levels of CA-125 and found changing variability with CA-125 levels. Fillela et al., ^38^ using an automated analyzer, found coefficients of variation of 2.8 to 6.4 percent for “level 2” values of CA-125 (mean 47.1 U/mL), with values of 1.8 to 4 percent for “level 3” (mean 164.3 U/mL). Hubl et al. ^34^ reported slightly higher intra-assay coefficients of variation in mid-range (40 U/mL) compared to low-range values (10 to 20 U/mL). A third study ^39^ did not find an effect of concentration in the clinically relevant range. Because 35 U/mL is the most commonly used threshold for considering a CA-125 value suspicious for cancer, these results suggest that random variation in test results may have some impact on sensitivity and specificity at values close to the threshold. The clinical impact of this variability would ultimately depend on how values close to the threshold are managed.

Tuxen and colleagues performed serial measurements of CA-125 over the course of a year in 26 women with known ovarian cancer ^40^ and 31 healthy controls ^41^ to assess the relative effect of analytic variability and inter- and intra-individual biologic variation on CA-125 levels. In women with cancer, analytic imprecision accounted for 12 percent of the variability in levels, intra-individual variations 24.0 percent, and inter-individual variations 43.6 percent; after accounting for this imprecision, the investigators estimated that a change of greater than 62.6 percent in the reference value would be needed in order to be statistically significant. Similar values were found in healthy controls, with imprecision being greater in premenopausal women (69.5 percent) compared with postmenopausal women (35.7 percent) due to variability in levels over the course of the menstrual cycle. The change in reference value required for significance after accounting for variation in the entire group was 50 percent.

One study ^37^ compared sensitivity and specificity of the new generation and first generation assays using 138 stored samples and found slightly higher sensitivity with the new assay (89.8 vs. 84.7 percent), and lower specificity (83.5 vs. 84.7 percent). However, the prevalence of cancer in the samples was much higher than would be expected in a typical clinical population, and the confidence intervals for the sensitivity and specificity estimates overlapped.

Radioimmunoassays for other single gene products. Few studies of other markers were performed in clinical laboratories. Hasholzner and colleagues ^36^ evaluated clinical laboratory performance of an RIA for cancer antigen 72-4 (CA-72-4); intra-assay coefficients of variation were 3.5 to 4 percent, and inter-assay coefficients of variation were 5 to 7.4 percent. Correlation between CA-125 levels and CA-72-4 levels was good for healthy controls (-0.066), but poor for serous ovarian cancer patients (0.576).

Tuxen and colleagues ^41^ measured carcinoembryonic antigen (CEA) and tissue plasminogen activator (TPA) along with CA-125 in healthy controls in the study described above. For CEA, the change in reference values needed for significance after accounting for imprecision was 44.8 percent; for TPA, the value was 67.9 percent. Unlike with CA-125, menopausal status did not affect the degree of intra-individual variability.

Two studies reported research laboratory performance of two other single gene products and preliminary clinical validation. Riisbro and colleagues ^42^ reported an inter-assay coefficient of variation of 7.6 percent, and an intra-assay coefficient of variation of 4.6 percent for an RIA for soluble urokinase plasminogen activator receptor. Using 129 stored serum samples, levels were correlated with malignancy and stage of disease, but not after adjusting for other variables. Thougaard and colleagues ^43^ compared three different antibodies targeted against tetranectin, with similar performance in terms of assay variability, differences in absolute levels of 10 percent or less, and similar correlations in ovarian cancer patients (n = 43); levels were observed to decrease as cancer stage worsened.

Two studies ^44,^ ^45^ reported on the performance of RIAs developed after identification of candidate single gene products identified after using microarrays to identify overexpressed genes. These studies will be discussed below under “Microarrays.”

Other assays. Sapi and colleagues ^46^ reported a method for removing peripheral lymphocytes from blood samples or ascitic fluid in order to measure telomerase activity. After this method, telomerase activity was observed in 8 of 8 patients with Stage IV ovarian cancer, 7 of 20 patients with Stage III, and 0 of 30 controls. CA-125 levels were higher in patients with positive telomerase assays.

Single gene mutation/polymorphism. Janatova and colleagues ^47^ evaluated the performance of Spreadex Polymer NAB (electrophoresis gels) in patients with known breast cancer gene 1/2 (BRCA1/2) mutations (n = 13) and 13 controls; the technique successfully identified mutations only in those subjects with known mutations; all patients with known mutations had mutations detected.

Wen and colleagues ^48^ compared microarray with gel-based DNA sequencing for identifying mutations in the p53 gene in 108 patients with ovarian cancer. Mutations were detected by both methods in 57 cancers, and no mutations by both methods, for a concordance of 81 percent.

Microarrays. Only one study specifically examined test performance in a clinical laboratory. Zarrinkar et al. ^49^ compared high-throughput microarray using parallel analysis to single sample assays in specimens from 31 patients with known ovarian cancer and found a high level of correlation (0.980).

Two studies reported preliminary data from research laboratories on candidate single-gene products identified initially through microarray studies. ^44,^ ^45^ Hellstrom and colleagues ^45^ compared the performance of an antibody to human epididymis protein 4 (HE4) to CA-125 in 121 subjects, of whom 37 (30.6 percent) had ovarian cancer. Reported sensitivities for HE4 were better for HE4 then for CA-125 at a fixed specificity of 96 percent, but confidence intervals were quite wide. Mok and colleagues ^44^ examined the performance of prostatin in 201 subjects, 64 (31.8 percent) of whom had ovarian cancer. Prostatin levels correlated poorly with CA-125 levels; sensitivity of prostatin was less than that of CA-125 at the same specificity of 94 percent, but the combination of the two markers had a sensitivity of 92 percent at the same level of specificity.

Proteomics. Although we identified 10 studies that looked at protein expression in serum as a potential biomarker for ovarian cancer, ^50^ – ^59^ all were performed in research laboratories. Because several of these studies have attracted wide attention in the media, we will discuss them in more detail here.

Petricoin et al., ^57^ created a proteomics-based genetic algorithm with cluster analysis to distinguish between ovarian cancer and non-ovarian cancer serum samples using a training set of 50 ovarian cancers and 50 healthy controls from a high-risk population. The new algorithm was then tested using a validation set consisting of 50 ovarian cancers and 66 non-cancers, some with benign ovarian cysts, benign gynecologic disease, or benign non-gynecologic disease. The algorithm successfully classified 50/50 cancers (sensitivity = 100 percent) and 63/66 non-cancers (specificity = 95 percent) in the validation set. The study has two major limitations. First, the proteins used to distinguish cancers from non-cancers were not identified, leading to questions of whether proteins of interest were actually produced by tumor cells or by other inflammatory responses in the tumor's microenvironment. Although the reported positive predictive value is 94 percent in the study, the low prevalence of ovarian cancer (1 in 2,500) in the general population would reduce the positive predictive value of proteomic screening to less than one percent in a screening population.

These investigators subsequently published three datasets online as the Clinical Proteomics Program Databank (http://home.ccr.cancer.gov/ncifdaproteomics/ppatterns.asp). The first dataset (2-16-02) consists of 100 control, 100 ovarian cancer, and 16 benign disease samples run on a Ciphergen H4 ProteinChip array. Ovarian Dataset 4-3-02 consists of the same samples run on Ciphergen WCX2 ProteinChip array. Ovarian Dataset 8-7-02 contains serum profiles run on Ciphergen WCX2 ProteinChip array of 162 ovarian cancer patients subdivided into stages and 91 non-cancer control subjects.

Sorace et al. ^55^ analyzed Ovarian Dataset 8-7-02 using a training set containing 45 controls and 80 cancers. A 2-sided Wilcoxon test was used to compare intensity between controls and cancers at different mass-to-charge (M/Z) values. A subset of M/Z values that resulted in the lowest Wilcoxon p-values was selected, and stepwise discriminant analysis was used to determine the subset of M/Z values that best discriminated cancers from controls. Classification rules were then used on the remainder of the patient data (test set). Three classification rules were developed, all with sensitivity > 90 percent and specificity > 90 percent when applied to the test set. The authors expressed concerns over the existence of highest discriminatory ability in the M/Z < 500 range, where data are traditionally discarded due to increased “noise.” They hypothesized several explanations for these findings including very low molecular weight (MW) biomarkers such as LPA, low MW degradation products of higher MW macromolecules, and systematic processing error.

Li et al. ^59^ analyzed all three Clinical Proteomics Program Datasets using two different approaches: support vector machine statistical testing (SVM-ST) and support vector machine with genetic algorithm (SVM-GA). Datasets were not split into training and validation sets; instead, a leave-out-one cross validation was used. Sensitivity and specificity for analysis of Dataset 2-16-02 were lower than in the analysis by Petricoin et al. ^57^ of the same data (0.79 and 0.80 for SVM-ST, and 0.96 and 0.948 for SVM-GA, respectively). Sensitivity and specificity were improved with analysis of the other two datasets, achieving 100 percent sensitivity and 100 percent specificity using SVM-GA to analyze Dataset 8-7-02. The authors were unable to reproduce the sensitivity and specificity reported by Petricoin et al. when training an SVM with the discriminatory features identified in the latters' paper.

Zhang et al. ^53^ performed a multicenter study to analyze serum proteomic expression profiles using Ciphergen ProteinChip in 153 patients with epithelial ovarian cancers, 42 with other ovarian cancers, 166 with benign pelvic masses, and 142 healthy controls. Results were cross-validated against different subsets of the data to identify biomarkers. Three biomarkers (apolipoprotein A1, transthyretin, both down-regulated in ovarian cancers, and a fragment of human inter-alpha trypsin inhibitor, upregulated) were identified and immunoassays performed on serum from another subset of patients. Levels of these three biomarkers were included in a multivariate model to predict malignancy, and the model was tested on a validation set consisting of 138 ovarian cancers and 63 healthy controls. The resulting model had a sensitivity and specificity of 0.775 and 0.968, respectively, in distinguishing cancer from healthy controls. The authors also created a model incorporating CA-125 with the three markers, which improved on the specificity of CA-125 alone. The discovered biomarkers were all acute phase reactants deemed unlikely to be released by tumor cells. Controls were not age-matched and were significantly younger (median test and validation sets 39 and 44) compared to cancer patients (median 52 and 57).

Kozak et al. ^60^ analyzed serum from 109 ovarian cancers, 19 patients with benign disease, and 56 healthy donors using the Ciphergen ProteinChip SAX2. Samples were divided into training and test sets. Proteins differentially expressed were identified using t-test and Wilcoxon rank sum tests. Three biomarker protein panels were then developed: SBP (five markers), VBP I (five markers), and VBP II (four markers). Multivariate logistic regression was used to develop panels with the best predictive value. Sensitivity and specificity were 0.957 and 0.826, respectively, for SBP; 0.815 and 0.949 for VBP I; and 0.728 and 0.949 for VBP II. Test sets were employed. Panels correctly identified early stage disease with variable sensitivity. Individual discriminatory proteins were not identified.

Although all studies reported good discrimination for the particular protein profile studied, there were several recurrent issues that limit the ability to draw inferences about potential clinical applicability:

- Technical issues with the assay. For example, Conrads and colleagues ^58^ noted that “comparisons...revealed that the variation in mass spectra (overall amplitude, total record count and deviation between ovarian cancer cases and control samples) was statistically indistinguishable from the variance within the process itself, as indicated by the serum reference standard.” Sorace and Zahn, ^55^ in an analysis of a dataset used by several other groups, found sensitivity and specificity of 100 percent in a training set, but noted that much of the discrimination of the profile lies in the region of the spectroscopy results with low mass-to-charge ratios. They note that this region is problematic both because of technical issues of measurement and because differences in protein profiles in this region may result from processes independent of cancer.
- Varying analytic methods. No consistent methodology was used. Given the complexity of the data and the variety of methods used, it is difficult to draw consistent conclusions about performance. Li and colleagues ^59^ found marked variability in results using similar statistical methods on different datasets, as well as using different statistical methods on the same dataset.
- Unrealistically high prevalence of ovarian cancer. The majority of the studies compared serum samples from known ovarian cancer patients to healthy controls, using relatively small datasets of 100 to 200 subjects, with a prevalence of cancer of 30 to 50 percent. Although repeated sampling and resampling was performed in all of these studies, the prevalence of cancer was still substantially higher than it would be in a screening population (approximately 0.05 percent). Only one study ^59^ provided estimates for the positive predictive value within a screening population; these estimates were in general at least an order of magnitude lower than the results based on the original dataset.

### Discussion

The majority of the literature we identified that specifically addressed issues of clinical laboratory performance in ovarian cancer dealt with radioimmunoassays of single gene products, with CA-125 being the most common product. Test reproducibility and validity is in general quite good for these assays, although a series of Danish studies by Tuxen and colleagues suggests that both inherent laboratory variation and biological variation should be considered when considering thresholds for determining clinically relevant changes in concentrations of these markers. In addition, coefficients of variation for CA-125 are generally greatest when levels are in the range of the most commonly used discriminatory threshold of 35 U/mL, suggesting that this irreducible imprecision may have some impact on sensitivity and specificity in practice.

We did not identify any relevant literature on the clinical laboratory performance of other types of genomic tests. Although there were numerous articles describing research laboratory performance, the relevance of these studies to widespread clinical practice is uncertain. In particular, the prevalence of ovarian cancer in studies of potential proteomic patterns as predictors of early stage ovarian cancer is at least an order of magnitude higher than the likely prevalence in the general population.

### Summary

The published data on clinical laboratory performance suggests that currently available radioimmunoassays for single gene products have acceptable reproducibility and reliability, although even this level of variability may have some impact on clinical interpretation of results, especially when comparing relatively small serial changes, or levels close to the discriminatory threshold.

There is insufficient evidence to estimate how newer technologies such as microarrays or protein profiles would perform in a “typical clinical laboratory.”

## Question 2: Sensitivity and Specificity of Tests

Question 2 is: What is the sensitivity and specificity of genomic tests in detecting ovarian cancer in asymptomatic and symptomatic women, including high-risk women?

### Approach

We sought to identify articles that provided details on the sensitivity and specificity of genomic tests in a clinical setting. We separately reviewed studies intended for screening purposes, both in the general population and in women identified as high risk based on family history and/or BRCA testing, and studies used for diagnostic purposes, either in women with symptoms or women with a diagnosed mass.

### Other Evidence Reports

Asymptomatic women - average risk. The systematic review conducted for the U.S. Preventive Services Task Force (USPSTF) ^30^ concluded that annual CA-125 screening had an estimated sensitivity of 80 percent, with false positive rates of 0.1 to 0.6 percent, based on three studies with small numbers of cancers and variable, relatively short, followup durations; the estimated positive predictive value for screening was 1 percent for women called for additional testing, and 15 percent for women undergoing surgery.

The evidence report on management of adnexal masses ^14^ found that the majority of studies did not report results separately for women with asymptomatic masses compared with those who had masses detected because of symptoms. Of note, the report also found an extremely low sensitivity (less than 50 percent) of the bimanual pelvic examination as both a screening test and an initial diagnostic test.

Asymptomatic women - high risk. The BRCA1 and BRCA2 systematic review for the USPSTF ^31^ did not specifically address the sensitivity and specificity of genomic tests in this setting.

Symptomatic women - average risk. Again, the literature on the use of diagnostic tests, including genomic tests, does not provide useful information on differences in test performance in symptomatic versus asymptomatic women. The evidence report on management of adnexal masses ^14^ found an approximate sensitivity of 78 percent for CA-125 in the diagnosis of cancer in adnexal masses, with an approximate specificity of 78 percent; both sensitivity and specificity were higher in postmenopausal women. Other genomic tests (all single gene products) reviewed included TAG-92, cancer antigen 19.9 (CA-19.9), and CEA; all had sensitivities lower than the pooled estimates for CA-125. There were few studies examining combination testing; those that did failed to find improved discrimination compared to CA-125 alone.

Symptomatic women - high risk. The adnexal mass evidence report ^14^ did not identify any studies uniquely in high-risk populations.

### Results

Articles included for Question 2 are summarized in Evidence Table 2 (Appendix D *).

Asymptomatic women. We did not identify any studies of genomic tests other than CA-125 that provided evidence of sensitivity and specificity as primary screening tests for ovarian cancer in asymptomatic women. The one major study published subsequent to the USPSTF review reported the initial baseline results of the National Cancer Institute Prostate, Lung, Colon, and Ovarian (PLCO) screening trial. ^61^ In this study, over 28,000 women aged 55 or older were screened with transvaginal ultrasound and CA-125; 402 women (1.4 percent) had an abnormal CA-125. Of the 19 invasive cancers, four had normal CA-125 levels for a sensitivity of 78.9 percent (95 percent confidence interval [CI], 60.6 to 97.3 percent), and a specificity of 98.7 percent (95 percent CI, 98.5 to 98.8 percent), consistent with previous studies in postmenopausal women.

Only one study ^62^ provided sufficient detail about patient characteristics to be able to ascertain test performance of a genomic test (in this case, vascular endothelial growth factor [VEGF]) as a diagnostic tool in asymptomatic women identified with a pelvic mass through screening; sensitivity was 55.9 percent, and specificity 55.3 percent, too low to be considered useful as a second line diagnostic test. All of the other studies that included women with a pelvic mass failed to report the proportion of women with a mass who had presented on the basis of symptoms, or on the basis of asymptomatic detection of a mass through a pelvic examination or imaging study; this limitation is shared by the majority of the literature on diagnosis of ovarian cancer in women with masses. ^14^

Symptomatic women - single gene products. The majority of studies identified were retrospective studies that compared serum or, in some cases, tissue from women with known ovarian cancer to serum from women with benign adnexal masses and/or asymptomatic women. There were more than two studies identified for only two markers, CA-72-4 and VEGF.

Table 6 shows results for CA-72-4. In general, sensitivity is poor. Although specificity is better (85 percent or higher), the high positive predictive values observed in these studies are a reflection of the high prevalence of cancer in the study populations. In a screening setting, where prevalence is likely to be less than one percent, positive predictive values would be much lower.

Table 6 Studies of cancer antigen 72-4 (CA-72-4)

Study | Gene product | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Prevalence
Wakahara et al. 2001 ^63^ | CA-72-4 | 20 | 20 | 18 | 108 | 50.0% (34.5 to 65.5%) | 85.7% (79.6 to 91.8%) | 52.6% (36.8 to 68.5%) | 84.4% (78.1 to 90.7%) | 24.3%
Schutter et al., 1998 ^64^ | CA-72-4 | 28 | 15 | 6 | 86 | 65.0% (50.7 to 79.3%) | 93.0% (87.8 to 98.2%) | 82.4% (69.5 to 95.2%) | 85.1% (78.2 to 92.1%) | 31.9%
Fayed et al., 1998 ^65^ | CA-72-4 | 21 | 9 | 3 | 57 | 70.0% (53.6 to 86.4%) | 95.0% (89.5 to 100%) | 87.5% (74.3 to 100%) | 86.4% (78.1 to 94.6%) | 33.3%
Zakrzewska et al., 1999 ^66^ | CA-72-4 | 39 | 31 | 0 | 26 | 55.7% (44.1 to 67.4%) | 100% (88.5 to 100%) | 100% (92.3 to 100%) | 45.6% (32.7 to 100%) | 72.9%
Hasholzner et al., 1996 ^36^ | CA-72-4 (benign vs. cancer) | 66 | 57 | 1 | 36 | 54.0% (45.2 to 62.8%) | 97.0% (91.5 to 100%) | 98.5% (95.6 to 100%) | 38.7% (28.8 to 48.6%) | 76.9%
Hasholzner et al., 1996 ^36^ | CA-72-4 (healthy vs. cancer) | 66 | 57 | 1 | 29 | 54.0% (45.2 to 62.8%) | 97.0% (90.9 to 100%) | 98.5% (95.6 to 100%) | 33.7% (23.7 to 43.7%) | 80.4%

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Table 7 shows results for VEGF. Although sensitivity was in general somewhat higher than for CA-72-4, specificity was somewhat lower.

Table 7 Studies of vascular endothelial growth factor (VEGF)

Study | Gene product | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Prevalence
Tanir et al., 2003 ^67^ | VEGF | 11 | 1 | 6 | 44 | 91.7% (76.0 to 100%) | 88.0% (79.0 to 97.0%) | 64.7% (42.0 to 87.4%) | 97.8% (93.5 to 100%) | 19.4%
Gorelik et al., 2005 ^68^ | VEGF | 35 | 9 | 27 | 55 | 79.5% (67.6 to 91.4%) | 67.4% (57.3 to 77.5%) | 56.5% (44.1 to 68.8%) | 85.9% (77.4 to 94.5%) | 34.9%
Obermair et al., 1998 ^69^ | VEGF | 24 | 20 | 19 | 62 | 54.5% (39.8 to 69.3%) | 76.5% (67.3 to 85.8%) | 55.8% (41.0 to 70.7%) | 75.6% (66.3 to 84.9%) | 35.2%
Cooper et al., 2002 ^70^ | VEGF | 75 | 26 | 16 | 34 | 74.0% (65.4 to 82.6%) | 68.0% (55.1 to 80.9%) | 82.4% (74.6 to 90.2%) | 56.7% (44.1 to 69.2%) | 66.9%
Oehler and Caffier, 1999 ^71^ | VEGF (benign mass controls) | 29 | 12 | 7 | 13 | 70.7% (56.8 to 84.7%) | 65.0% (44.1 to 85.9%) | 80.6% (67.6 to 93.5%) | 52.0% (32.4 to 71.6%) | 67.2%
Oehler and Caffier, 1999 ^71^ | VEGF (healthy controls) | 30 | 11 | 6 | 14 | 73.2% (59.6 to 86.7%) | 70.0% (49.9 to 90.1%) | 83.3% (71.2 to 95.5%) | 56.0% (36.5 to 75.5%) | 67.2%

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Table 8 shows results for other single gene products. In general, there is a trade-off between sensitivity and specificity. Common limitations of these studies included failure to adequately characterize the study population (such as underlying risk factors, menopausal status, and how the patients presented to the health system); small numbers (as reflected in the wide confidence intervals of the sensitivity and specificity estimates); and prevalence of ovarian cancer much higher than would be expected in many clinical settings, especially screening settings. These limitations preclude meaningful synthesis or direct comparisons between tests.

Table 8 Studies of other single gene products

Study | Gene product | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Prevalence
Abdel-Aleem et al., 1996 ^72^ | Alpha-L-fucosidase | 43 | 5 | 0 | 28 | 89.6% (80.9 to 98.2%) | 100% (89.3 to 100%) | 100% (93.0 to 100%) | 84.8% (72.6 to 97.1%) | 63.2%
Cherchi et al., 2002 ^73^ | CA-15-3 | 10 | 10 | 6 | 38 | 50.0% (28.1 to 71.9%) | 86.4% (76.2 to 96.5) | 62.5% (38.8% to 86.2%) | 79.2% (67.7 to 90.7%) | 31.3%
Cherchi et al., 2002 ^73^ | CA-19-9 | 13 | 7 | 2 | 42 | 65.0% (44.1 to 85.9%) | 95.5% (89.3 to 100%) | 86.7% (69.5 to 100%) | 85.7% (75.9 to 95.5%) | 31.3%
Wakahara et al., 2001 ^63^ | CA-19-9 | 24 | 42 | 78 | 127 | 36.4% (24.8 to 48.0%) | 62.0% (55.3 to 68.6%) | 23.5% (15.3 to 31.8%) | 75.1% (68.6 to 81.7%) | 24.3%
Cherich et al., 2002 ^73^ | CEA | 8 | 12 | 0 | 44 | 40.0% (18.5 to 61.5%) | 100% (93.2 to 100%) | 100% (62.5 to 100%) | 78.6% (67.8 to 89.3%) | 31.3%
Zakrzewska et al., 1999 ^66^ | CEA | 7 | 63 | 0 | 26 | 10.0% (3.0 to 17.0%) | 100% (88.5 to 100%) | 100% (57.1 to 100%) | 29.2% (19.8 to 38.7%) | 72.9%
Mabrouk and Ali-Labib, 2003 ^74^ | c-erb-2 | 4 | 16 | 4 | 16 | 20.0% (2.5 to 37.5%) | 80.0% (62.5 to 97.5%) | 50.0% (15.4 to 84.6%) | 50.0% (32.7 to 67.3%) | 50.0%
Inaba et al., 1995 ^75^ | CYFRA 21-1 | 48 | 27 | 3 | 137 | 64.0% (53.1 to 74.9%) | 97.9% (95.5 to 100%) | 94.1% (87.7 to 100%) | 83.5% (77.9 to 89.2%) | 34.9%
Tempfer et al., 1998 ^76^ | CYFRA 21-1 | 15 | 22 | 2 | 38 | 40.5% (24.7 to 56.4%) | 95.0% (88.2 to 100%) | 88.2% (72.9 to 100%) | 63.3% (51.1 to 75.5%) | 48.1%
Gorelik et al., 2005 ^68^ | EGF | 37 | 7 | 19 | 63 | 84.1% (73.3% to 94.9%) | 76.7% (67.5 to 85.9%) | 66.1% (53.7 to 78.5%) | 90.0% (83.0 to 97.0%) | 34.9%
Kim et al., 2003 ^77^ | Epithelial cell adhesion molecule | 22 | 30 | 2 | 50 | 42.3% (28.9 to 55.7%) | 96.2% (90.9 to 100%) | 91.7% (80.6 to 100%) | 62.5% (51.9 to 73.1%) | 50.0%
Hefler et al., 2000 ^78^ | FAS | 28 | 24 | 3 | 62 | 53.0% (39.4 to 66.6%) | 95.0% (89.7 to 100%) | 90.3% (79.9 to 100%) | 72.1% (62.6 to 81.6%) | 44.4%
Gorelik et al., 2005 ^68^ | G-CSF | 32 | 12 | 21 | 61 | 72.7% (59.5 to 85.9%) | 74.4% (65.0 to 83.8%) | 60.4% (47.2 to 73.5%) | 83.6% (75.1 to 92.1%) | 34.9%
Diamandis et al., 2003 ^79^ | hK6 | 69 | 77 | 12 | 226 | 47.0% (38.9 to 55.1%) | 95.0% (92.2 to 97.8%) | 85.2% (77.4 to 92.9%) | 74.6% (69.7 to 79.5%) | 38.0%
Luo et al., 2001 ^80^ | hK10 | 62 | 18 | 0 | 42 | 77.5% (68.3 to 86.7%) | 100% (92.9 to 100%) | 100% (95.2 to 100%) | 70.0% (58.4 to 81.6%) | 65.6%
Berek et al., 1991 ^81^ | IL-6 | 18 | 18 | 2 | 10 | 50.0% (33.7 to 66.3%) | 83.3% (62.2 to 100%) | 90% (76.9 to 100%) | 35.7% (18.0 to 53.5%) | 75.0%
Gorelik et al., 2005 ^68^ | IL-6 | 37 | 7 | 11 | 71 | 84.1% (73.3% to 94.9%) | 86.0% (78.5 to 93.5.%) | 77.1% (65.2 to 89.0%) | 91.0% (84.7 to 97.4%) | 34.9%
Gorelik et al., 2005 ^68^ | IL-8 | 39 | 5 | 25 | 57 | 88.6% (79.2 to 98.0%) | 69.8% (59.9 to 79.7%) | 60.9% (49.0 to 72.9%) | 91.9% (85.2 to 98.7%) | 34.9%
Gorelik et al., 2005 ^68^ | MCP | 37 | 7 | 23 | 59 | 84.1% (73.3% to 94.9%) | 72.1% (62.4 to 81.8%) | 61.7% (49.4 to 74.0%) | 89.4% (82.0 to 96.8%) | 34.9%
van Haaften-Day et al., 2001 ^82^ | M-CSF | 69 | 134 | 28 | 166 | 34.0% (27.5 to 40.0%) | 85.6% (80.6 to 90.5%) | 71.1% (62.1 to 80.2%) | 55.3% (49.7 to 61.0%) | 51.1%
Bon et al., 1996 ^83^ | Mucin-like carcinoma-associated antigen | 29 | 47 | 0 | 70 | 38.2% (27.2 to 49.1%) | 100% (95.7 to 100%) | 100% (89.7 to 100%) | 59.8% (50.9 to 68.7%) | 52.1%
van Haaften-Day et al., 2001 ^82^ | OVX1 | 38 | 165 | 16 | 178 | 18.7% (13.4 to 24.1%) | 91.8% (87.9 to 95.6%) | 70.4% (58.2 to 82.5%) | 51.9% (46.6 to 57.2%) | 51.1%
Onsrud et al., 1996 ^84^ | p55 | 26 | 19 | 3 | 24 | 57.8% (43.3 to 72.2%) | 88.9% (77.0 to 100%) | 89.7% (78.6 to 100%) | 55.8% (41.0 to 70.7%) | 62.5%
Opala et al., 2005 ^85^ | p55 | 28 | 23 | 1 | 15 | 54.9% (41.2 to 68.6%) | 93.8% (81.9 to 100%) | 96.6% (89.9 to 100%) | 39.5% (23.9 to 55.0%) | 76.1%
Onsrud et al., 1996 ^84^ | p75 | 7 | 38 | 1 | 26 | 15.6% (5.0 to 26.1%) | 96.3% (89.2 to 100%) | 87.5% (64.6 to 100%) | 40.6% (28.6 to 52.7%) | 62.5%
Opala et al., 2005 ^85^ | p75 | 22 | 29 | 3 | 13 | 43.1% (29.5 to 56.7%) | 81.3% (62.1 to 100%) | 88.0% (75.3 to 100%) | 31.0% (17.0 to 44.9%) | 76.1%
Tsukishiro et al., 2005 ^86^ | Secretory leukocyte protease inhibitor | 42 | 13 | 5 | 20 | 76.0% (64.7 to 87.3%) | 80.0% (64.3 to 95.7%) | 89.4% (80.5 to 98.2%) | 60.6% (43.9 to 77.3%) | 68.8%
Darai et al., 1998 ^87^ | Serum cadherin | 11 | 5 | 0 | 52 | 68.8% (46.0 to 91.5%) | 100% (94.2 to 100%) | 100% (72.7 to 100%) | 91.2% (83.9 to 98.6%) | 23.5%
Baron et al., 2003 ^88^ | Serum EGFR | 125 | 100 | 8 | 136 | 55.6% (49.1 to 62.0%) | 94.4% (90.7 to 98.2%) | 94.0% (89.9 to 98.0%) | 57.6% (51.3 to 63.9%) | 60.9%
Baron et al., 2005 ^89^ | Serum EGFR | 141 | 84 | 86 | 160 | 62.7% (56.3 to 69.0%) | 65.0% (59.1 to 71.0%) | 62.1% (55.8 to 68.4%) | 65.6% (59.6 to 71.5%) | 47.8%
Udagawa et al., 1998 ^90^ | Serum GAT | 68 | 68 | 13 | 285 | 50.0% (41.6 to 58.4%) | 95.6% (93.3 to 97.9%) | 84.0% (76.0 to 91.9%) | 80.7% (76.6 to 84.9%) | 31.3%
Sedlaczek et al., 2002 ^91^ | sIL to 2R | 54 | 13 | 1 | 31 | 80.6% (71.1 to 90.1%) | 96.9% (90.8 to 100%) | 98.2% (94.7 to 100%) | 70.5% (57.0 to 83.9%) | 67.8%
Hurteau et al., 1995 ^92^ | Soluble IL-2 receptor alpha | 37 | 2 | 58 | 3 | 94.9% (87.9 to 100%) | 4.9% (0 to 10.3%) | 38.9% (29.1 to 48.8%) | 60.0% (17.1 to 100%) | 39.0%
Opala et al., 2003 ^93^ | Soluble intra-cellular adhesion molecule 1 | 42 | 9 | 7 | 9 | 82.4% (71.9 to 92.8%) | 56.3% (31.9 to 80.6%) | 85.7% (75.9 to 95.5%) | 50.0% (26.9 to 73.1%) | 76.2%
McIntosh et al., 2004 ^94^ | Soluble mesothelin-related marker (benign masses) | 15 | 37 | 4 | 216 | 28.8% (16.5 to 41.2%) | 98.2% (96.4 to 99.9%) | 78.9% (60.6 to 97.3%) | 85.4% (81.0 to 89.7%) | 19.1%
Sedlaczek et al., 2002 ^91^ | TPS | 53 | 14 | 6 | 26 | 79.1% (69.4 to 88.8%) | 81.3% (67.7 to 94.8%) | 89.8% (82.1 to 97.5%) | 65.0% (50.2 to 79.8%) | 67.8%
Medl et al., 1995 ^95^ | TATI | 75 | 40 | 67 | 200 | 65.2% (56.5 to 73.9%) | 74.9% (69.7 to 80.1%) | 52.8% (44.6 to 61.0%) | 83.3% (78.6 to 88.0%) | 30.1%
Peters-Engl et al., 1995 ^96^ | TATI | 114 | 66 | 60 | 154 | 63.3% (56.3 to 70.4%) | 72.0% (65.9 to 78.0%) | 65.5% (58.5 to 72.6%) | 70.0% (63.9 to 76.1%) | 45.7%
Schutter et al., 1999 ^97^ | Urinary gonadotropin peptide | 7 | 2 | 7 | 14 | 78.0% (50.9 to 100%) | 65.0% (44.6 to 85.4%) | 50.0% (23.8 to 76.2%) | 87.5% (71.3 to 100%) | 30.0%

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Symptomatic women - DNA variations. We did not identify any studies that allowed estimation of sensitivity and specificity of inherited or acquired mutations in detecting ovarian cancer.

Symptomatic women - gene expression. We identified one study that reported on the sensitivity of cytological tests of ascitic fluid for the presence of a series of genes believed to be activated in ovarian cancer; ^98^ although specificities were universally high, sensitivities ranged from 8 to 60 percent, with wide confidence intervals for both values. These low sensitivities were even more striking given the high prevalence of ovarian cancer in the samples (61 percent).

We identified one study that used immunohistochemistry for a range of gene products in the diagnosis of ovarian cancer in ovarian tissue; ^99^ performance for different markers ranged widely. Because there were only 20 ovarian cancer patients (out of a total of 70), confidence intervals were wide. In addition, no data were provided on the reproducibility of the assay or interpretation of results.

Another study measured cytokeratin 19 (CK19) expression in peripheral blood mononuclear cells; ^100^ false-positive rates were quite high in both discriminating cancer from benign ovarian tumors (specificity 28.6 percent) and cancer from normal controls (specificity 40.0 percent). Again, confidence intervals were very wide.

No other studies directly reported the sensitivity and specificity of gene expression patterns identified through the use of microarray technology.

Symptomatic women - proteomics. Studies of protein profiles as a potential tool for early diagnosis of ovarian cancer have attracted considerable attention recently. However, all of the identified studies examined test performance using databases; none have been tested in a clinical population.

### Discussion

In general, single gene products other than CA-125 have not been shown to be useful in the diagnosis of ovarian cancer, either in symptomatic or asymptomatic women. Small sample sizes, lack of detail on the prediagnosis history of patients, and an unrealistically high prevalence of ovarian cancer in the majority of studies make it difficult to assess how any of these tests would perform in clinical practice.

Estimating the clinical value of more complex tests (those using multiple gene and/or protein markers) is even more difficult. Studies of protein expression, in particular, are limited by lack of consensus on appropriate statistical methods, small sample sizes with substantially higher prevalences of ovarian cancer than would be found in the general population, lack of reproducibility, and uncertainty about the specificity of the biological processes resulting in the observed protein patterns. Most importantly, none have been tested in clinical populations.

## Question 3: Impact on Clinical Management of Asymptomatic Patients

Question 3 is: What is the evidence that genomic testing to detect ovarian cancer in asymptomatic women, including high-risk women, changes clinical management and leads to improved health outcomes?

### Approach

We searched for articles related to the use of genomic tests in screening for ovarian cancer in asymptomatic women, including any studies that focused on screening in women previously identified as being at greater risk on the basis of family history or other genomic tests. We excluded studies of CA-125 that were previously reviewed in a report for the USPSTF; ^30^ we did, however, review studies published subsequent to the USPSTF review.

### Other Evidence Reports

In the review of ovarian cancer screening for the USPSTF, ^30^ studies did consistently show a greater prevalence of Stage I ovarian cancer among women screened with CA-125 (based on small numbers of cancers), but there were no data on the impact of screening on mortality.

In the BRCA1 and BRCA2 review, ^31^ there were “limited” data on the efficacy of intensive screening among carriers, and no prospective studies of chemoprevention (especially oral contraceptives) or tubal ligation, although some suggestion from observational studies that both of those interventions might reduce ovarian cancer risk. In three retrospective studies and one cohort study, prophylactic oophorectomy reduced the risk of ovarian cancer by 85 to 100 percent, although the authors of the review noted that the confidence interval for risk reduction crossed 1.0 in the prospective study.

### Results

We did not identify any studies of the use of genomic tests for screening asymptomatic women in any risk group that met our inclusion criteria.

### Discussion

To date, no test has been shown to have acceptable sensitivity and specificity for screening for ovarian cancer, or to reduce the morbidity and mortality associated with ovarian cancer. Because definitive diagnosis of ovarian cancer requires surgery, a high level of specificity is needed in order to minimize the costs and potential complications of unnecessary surgery; although screening in high-risk groups could theoretically have better outcomes (because a higher pretest probability of cancer should result in better positive predictive values), this has not been demonstrated in adequately designed studies. One study of 1,610 women at increased risk because of family history found a positive predictive value for ovarian cancer of less than five percent (3 of 61 abnormal tests), ^101^ a value similar to that observed in the 28,000 average-risk women in the PLCO study (3.7 percent). ^61^ The ability to detect early cancer in these populations, even with intensive screening, may be limited; a study of 291 high-risk women who were screened every 6 months with ultrasound and CA-125 detected early stage ovarian cancer in only one of the eight women who developed ovarian or peritoneal cancer during 10 years of followup; five of the eight had had normal screening tests within 6 months of diagnosis. ^18^ Other studies in similar populations have reported similar findings. ^16,^ ^19^ The degree to which the lack of effectiveness of screening is due to insufficient test sensitivity rather than the inherent biology of ovarian cancer is discussed further in the section on modeling.

### Summary

We found no articles on the use of genomic tests (other than CA-125) for detecting ovarian cancer in asymptomatic women, regardless of risk group.

## Question 4: Impact on Clinical Management of Diagnosed Patients

Question 4 is: What is the evidence that genomic testing in women with clinical suspicion of ovarian cancer or with already-diagnosed ovarian cancer changes clinical management and leads to improved health outcomes?

### Approach

Studies included in this section reported data on the association of genomic test results with either a change in clinical management or a health outcome related to a particular management strategy. For example, genomic tests whose results were associated with response to therapy are included here. We did not, however, include studies that related genomic tests strictly to prognosis, for example, describing survival differences based on genomic test results. Similarly, if genomic test results were associated with staging data, we did not include these studies here despite the fact that staging may in turn be used to select treatment. Our notion is that we were primarily interested in how genomic testing could inform clinical management beyond usual clinical staging, which is already routinely used to guide therapy.

### Results

We found no studies that compare two groups of women, one of which underwent genomic testing and one of which did not. Ideally, such a study would be prospective with random allocation to the groups. In fact, we did not encounter any non-randomized comparative studies, either prospective or retrospective, that compare management or health outcomes in two such groups. Therefore, the following review considers only uncontrolled studies describing the association of test-positive and test-negative women with management and health outcomes. This design limits the certainty with which one might infer that applying the test in clinical practice could result in improved management decisions or health outcomes compared to not applying the test.

The description of evidence is divided first between studies of women with a clinical suspicion of ovarian cancer versus women with already diagnosed ovarian cancer. Within these groups, we will discuss the influence of genomic tests on specific management decisions or health outcomes. Summaries of all the included articles are provided in Evidence Table 3 (Appendix D *).

Women with clinical suspicion of ovarian cancer. We found no studies that describe evidence regarding change in management or health outcome resulting from use of genomic testing in women with a clinical suspicion of ovarian cancer. A large number of studies discussed under Question 2 describe the diagnostic accuracy of genomic tests in women with a clinical suspicion of ovarian cancer (based on symptoms), but none of these studies, nor any others screened in the literature search, described clinical management changes or health outcomes resulting from these tests.

Women with already diagnosed ovarian cancer. The most studied use of genomic tests was for predicting or detecting response to treatment after debulking therapy and adjuvant chemotherapy. The studies were of two types. First, several studies sought to predict which patients would have a favorable response to chemotherapy (e.g., complete or partial response vs. stable or progressive disease). A second goal of studies was to predict, among women who appeared to have no evidence of disease on clinical evaluation, who would have evidence of disease on second-look laparotomy (SLL). Finally, several studies related genomic test results at the time of primary debulking surgery with the ability to achieve optimal cytoreduction.

Predicting favorable response to chemotherapy. We found six studies describing the association between CA-125 and favorable response to chemotherapy; ^79,^ ^102^ – ^106^ these studies used a wide range of threshold values, from 10 to 500 U/mL. In addition, the following tests were described in one study each: human kallikrein 6 (hK6); ^79^ low-density lipoprotein receptor-related protein (LRP), multidrug resistance protein (MRP), and P-glycoprotein (Pgp); ^107^ multidrug resistance gene 1 (MDR-1), MRP-1, and MRP-2; ^108^ TP53; ^109^ c-erb-B2; ^110^ and human kallikrein 10 (hK10). ^111^

Table 9 and Figure 5 show the sensitivity and specificity of these tests for predicting response to chemotherapy. Estimates of sensitivity are widely scattered and range from 12 to 100 percent; specificity ranged from 0 to 84 percent. The only study to report diagnostic performance that exceeded that of the studies of change in CA-125 ^102,^ ^104^ – ^106^ was one of MDR-1; ^108^ however, it is important to note that this relatively small study (n = 27) did not report estimates from the other markers assessed in the study (MRP-1 and MRP-2), but noted only that there was no association between those tests and response to chemotherapy. ^108^ No other studies have replicated this finding.

Table 9 Sensitivity and specificity of genomic tests for predicting response to chemotherapy

Test/Study | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Probability of response to chemotherapy
CA-125
Balbi et al., 2005 ^102^ | 32 | 8 | 2 | 24 | 80.00% (65.2 to 89.5%) | 92.30% (75.9 to 97.9%) | 94.10% (80.9 to 98.4%) | 75.00% (57.9 to 86.7%) | 60.60%
Balbi et al., 2005 ^102^ | 22 | 4 | 2 | 19 | 84.60% (66.5 to 93.8%) | 90.50% (71.1 to 97.3%) | 91.70% (74.2 to 97.7%) | 82.60% (62.9 to 93.0%) | 55.30%
Rustin et al., 2001 ^104^ | 80 | 5 | 1 | 2 | 94.10% (87.0 to 97.5%) | 66.70% (20.8 to 93.9%) | 98.80% (93.3 to 99.8%) | 28.60% (8.2 to 64.1%) | 96.60%
Rustin et al., 1996 ^105^ | 73 | 12 | 4 | 42 | 85.90% (76.9 to 91.7%) | 91.30% (79.7 to 96.6%) | 94.80% (87.4 to 98.0%) | 77.80% (65.1 to 86.8%) | 64.90%
Gronlund et al., 2004 ^106^ | 27 | 1 | 14 | 30 | 96.40% (82.3 to 99.4%) | 68.20% (53.4 to 80.0%) | 65.90% (50.5 to 78.4%) | 96.80% (83.8 to 99.4%) | 38.90%
Gadducci et al., 2004 ^103^ | 26 | 16 | 10 | 19 | 61.90% (46.8 to 75.0%) | 65.50% (47.3 to 80.1%) | 72.20% (56.0 to 84.2%) | 54.30% (38.2 to 69.5%) | 59.20%
(CA-125 half life)
Gadducci et al., 2004 ^103^ | 26 | 17 | 10 | 19 | 60.50% (45.6 to 73.6%) | 65.50% (47.3 to 80.1%) | 72.20% (56.0 to 84.2%) | 52.80% (37.0 to 68.0%) | 59.70%
(CA-125% reduction)
hk6
Diamandis et al., 2003 ^79^ | 17 | 4 | 46 | 61 | 81.00% (60.0 to 92.3%) | 57.00% (47.5 to 66.0%) | 27.00% (17.6 to 39.0%) | 93.80% (85.2 to 97.6%) | 16.40%
MDR-1
Kamazawa et al., 2002 ^108^ | 21 | 0 | 1 | 5 | 100.00% (84.5 to 100.0%) | 83.30% (43.6 to 97.0%) | 95.50% (78.2 to 99.2%) | 100.00% (56.6 to 100.0%) | 77.80%
TP53
Kupryjandzyk et al., 2003 ^109^ | 98 | 57 | 37 | 37 | 63.20% (55.4 to 70.4%) | 50.00% (38.9 to 61.1%) | 72.60% (64.5 to 79.4%) | 39.40% (30.1 to 49.5%) | 67.70%
c-erb-B2
Lassus et al., 2004 ^110^ | 234 | 66 | 30 | 51 | 78.00% (73.0 to 82.3%) | 63.00% (52.1 to 72.7%) | 88.60% (84.2 to 91.9%) | 43.60% (34.9 to 52.6%) | 78.70%
hk10
Luo et al., 2003 ^111^ | 74 | 44 | 7 | 14 | 62.70% (53.7 to 70.9%) | 66.70% (45.4 to 82.8%) | 91.40% (83.2 to 95.8%) | 24.10% (15.0 to 36.5%) | 84.90%
Pgp
Izquierdo et al., 1995 ^107^ | 32 | 9 | 8 | 0 | 78.00% (63.3 to 88.0%) | 0.00% (0.0 to 32.4%) | 80.00% (65.2 to 89.5%) | 0.00% (0.0 to 29.9%) | 83.70%
MRP
Izquierdo et al., 1995 ^107^ | 13 | 28 | 3 | 5 | 31.70% (19.6 to 47.0%) | 62.50% (30.6 to 86.3%) | 81.30% (57.0 to 93.4%) | 15.20% (6.7 to 30.9%) | 83.70%
LRP
Izquierdo et al., 1995 ^107^ | 5 | 36 | 5 | 3 | 12.20% (5.3 to 25.5%) | 37.50% (13.7 to 69.4%) | 50.00% (23.7 to 76.3%) | 7.70% (2.7 to 20.3%) | 83.70%

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Figure 5. Diagnostic performance of genomic tests to predict response to chemotherapy plotted in receiver operating characteristic (ROC) space

Key to Figure 5: Crosses indicate studies of CA-125; circles indicated other serum or immunohistochemical tests.

Predicting residual disease on SLL. A second goal of studies was to predict, among women who appeared to have no evidence of disease on clinical evaluation, who would have evidence of disease on SLL. A test might be clinically useful if it could predict with a high sensitivity which patients with clinically undetectable disease might have cancer progression on SLL. Such a test might obviate the need for SLL or at least improve the accuracy of clinical staging. CA-125 is one marker used to detect early recurrence.

We found five studies describing the association between CA-125 and positive disease on SLL. ^112^ – ^116^ Two studies described cancer-associated serum antigen (CASA). ^113,^ ^114^ In addition, the following markers were described in one study each: Cathespin-D and nm23; ^117^ p53, murine double minute protein (Mdm2), and Bcl-2; ^118^ interleukin 6 (IL-6); ^81^ cytokeratin fragment 21-1 (CYFRA 21-1); ^119^ tetranectin (TN); ^113^ and TPS. ^115^

Three reports classified patients with microscopic disease as disease-negative, ^81,^ ^117,^ ^118^ while the remaining studies classified macroscopic or microscopic disease at SLL as disease-positive.

Table 10 shows the sensitivity of a positive test for identifying patients with positive SLL. The sensitivities for CA-125 range from 6.4 to 57.9 percent. Thresholds for a positive test vary from 10 U/mL to 35 U/mL, but there is no clear relationship between cut-point and sensitivity that explains the differences between studies. While most studies of CA-125 fell in the lower left quadrant of the receiver operating characteristic (ROC) space (Figure 6), representing low sensitivity but high specificity, the other genomic tests reported displayed greater variability, particularly in specificity. The higher average sensitivity was associated with lower specificity.

Table 10 Sensitivity and specificity of genomic tests for identifying patients with residual disease at second-look laparotomy

Test/Study | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Probabilty of residual disease
CA-125
Folk et al., 1995 ^112^ | 3 | 24 | 0 | 18 | 11.1% (3.9 to 28.1%) | 100.0% (82.4 to 100.0%) | 100.0% (43.9 to 100.0%) | 42.9% (29.1 to 57.8%) | 60.0%
Hogdall et al., 1996 ^113^ | 21 | 17 | 0 | 30 | 55.3% (39.7 to 69.9%) | 100.0% (88.6 to 100.0%) | 100.0% (84.5 to 100.0%) | 63.8% (49.5 to 76.0%) | 55.9%
Senapad et al., 2000 ^115^ | 11 | 8 | 11 | 3 | 57.9% (36.3 to 76.9%) | 21.4% (7.6 to 47.6%) | 50.0% (30.7 to 69.3%) | 27.3% (9.7 to 56.6%) | 57.6%
CA-125 > 10
Kierkegaard et al., 1995 ^114^ | 23 | 335 | 0 | 35 | 6.4% (4.3 to 9.5%) | 100.0% (90.1 to 100.0%) | 100.0% (85.7 to 100.0%) | 9.5% (6.9 to 12.9%) | 91.1%
CA-125 > 15
Wong et al., 2000 ^116^ | 5 | 23 | 1 | 17 | 17.9% (7.9 to 35.6%) | 94.4% (74.2 to 99.0%) | 83.3% (43.6 to 97.0%) | 42.5% (28.5 to 57.8%) | 60.9%
CA-125 > 35
CASA
Hogdall et al., 1996 ^113^ | 12 | 26 | 0 | 29 | 31.6% (19.1 to 47.5%) | 100.0% (88.3 to 100.0%) | 100.0% (75.8 to 100.0%) | 52.7% (39.8 to 65.3%) | 56.7%
Kierkegaard et al., 1995 ^114^ | 13 | 45 | 0 | 35 | 22.4% (13.6 to 34.7%) | 100.0% (90.1 to 100.0%) | 100.0% (77.2 to 100.0%) | 43.8% (33.4 to 54.7%) | 62.4%
Cathepsin D
Baekelandt et al., 1999 ^117^ | 22 | 14 | 78 | 61 | 61.1% (44.9 to 75.2%) | 43.9% (35.9 to 52.2%) | 22.0% (15.0 to 31.1%) | 81.3% (71.1 to 88.5%) | 20.6%
CYFRA 21-1
Gadducci et al., 2001 ^119^ | 20 | 4 | 5 | 6 | 83.3% (64.1 to 93.3%) | 54.5% (28.0 to 78.7%) | 80.0% (60.9 to 91.1%) | 60.0% (31.3 to 83.2%) | 68.6%
p53
Baekelandt et al., 1999 ^118^ | 20 | 16 | 64 | 75 | 55.6% (39.6 to 70.5%) | 54.0% (45.7 to 62.0%) | 23.8% (16.0 to 33.9%) | 82.4% (73.3 to 88.9%) | 20.6%
Ayhan et al., 1998 ^120^ | 9 | 6 | 5 | 10 | 60.0% (35.7 to 80.2%) | 66.7% (41.7 to 84.8%) | 64.3% (38.8 to 83.7%) | 62.5% (38.6 to 81.5%) | 50.0%
Other
Baekelandt et al., 1999 ^117^ | 24 | 12 | 100 | 39 | 66.7% (50.3 to 79.8%) | 28.1% (21.3 to 36.0%) | 19.4% (13.4 to 27.2%) | 76.5% (63.2 to 86.0%) | 20.6%
nm23
Baekelandt et al., 1999 ^118^ | 4 | 32 | 25 | 114 | 11.1% (4.4 to 25.3%) | 82.0% (74.8 to 87.5%) | 13.8% (5.5 to 30.6%) | 78.1% (70.7 to 84.0%) | 20.6%
Mdm2
Baekelandt et al., 1999 ^118^ | 19 | 17 | 49 | 90 | 52.8% (37.0 to 68.0%) | 64.7% (56.5 to 72.2%) | 27.9% (18.7 to 39.6%) | 84.1% (76.0 to 89.8%) | 20.6%
Bcl-2
Berek et al., 1991 ^81^ | 16 | 5 | 2 | 13 | 76.2% (54.9 to 89.4%) | 86.7% (62.1 to 96.3%) | 88.9% (67.2 to 96.9%) | 72.2% (49.1 to 87.5%) | 58.3%
IL-6
Hogdall et al., 1996 ^113^ | 9 | 29 | 0 | 30 | 23.7% (13.0 to 39.2%) | 100.0% (88.6 to 100.0%) | 100.0% (70.1 to 100.0%) | 50.8% (38.4 to 63.2%) | 55.9%
TN
Combination markers
Kierkegaard et al., 1995 ^114^ | 27 | 31 | 0 | 35 | 46.6% (34.3 to 59.2%) | 100.0% (90.1 to 100.0%) | 100.0% (87.5 to 100.0%) | 53.0% (41.2 to 64.6%) | 62.4%
Senapad et al., 2000 ^115^ | 11 | 8 | 13 | 1 | 57.9% (36.3 to 76.9%) | 7.1% (1.3 to 31.5%) | 45.8% (27.9 to 64.9%) | 11.1% (2.0 to 43.5%) | 57.6%

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Figure 6. Studies of the ability of serum markers to predict positive disease on second-look laparotomy following primary surgery and adjuvant chemotherapy plotted in ROC space

Key to Figure 6: Crosses indicated studies of CA-125; open circles indicate studies of other genomic tests.

Studies also differ with regard to the separation in time between the time at which the marker was measured and the time of SLL. The immunohistochemical tests are based on surgical samples, while serum markers were measured after surgery, after adjuvant chemotherapy, and immediately prior to SLL.

Predicting ability to perform optimal cytoreduction. Several studies evaluated genomic tests for their ability to predict whether optimal cytoreduction (by surgical debulking) was possible. Definitions for optimal cytoreduction were identical between studies, based on the Gynecology Oncology Group criteria, ^121^ requiring no residual tumor masses > 1 cm at debulking surgery.

Table 11 and Figure 7 show the sensitivity and specificity of tests for predicting which patients will achieve optimal cytoreduction at primary surgical debulking.

Table 11 Sensitivity and specificity of tests for predicting which patients will achieve optimal cytoreduction at primary surgical debulking

Study/Test | TP | FN | FP | TN | Sensitivity (95% CI) | Specificity (95% CI) | PPV (95% CI) | NPV (95% CI) | Probability of optimal cytoreduction
Berchuck et al., 2004 ^122^ | 20 | 5 | 7 | 12 | 80.0% (60.9 to 91.1%) | 63.2% (41.0 to 80.9%) | 74.1% (55.3 to 86.8%) | 70.6% (46.9 to 86.7%) | 56.8%
Chip
Diamandis et al., 2003 ^79^ | 53 | 28 | 9 | 40 | 65.4% (54.6 to 74.9%) | 81.6% (68.6 to 90.0%) | 85.5% (74.7 to 92.2%) | 58.8% (47.0 to 69.7%) | 62.3%
hK6
Gemer et al., 2001 ^123^ | 10 | 6 | 4 | 20 | 62.5% (38.6 to 81.5%) | 83.3% (64.1 to 93.3%) | 71.4% (45.4 to 88.3%) | 76.9% (57.9 to 89.0%) | 40.0%
CA-125
Memarzadeh et al., 2003 ^124^ | 14 | 12 | 31 | 42 | 53.8% (35.5 to 71.2%) | 57.5% (46.1 to 68.2%) | 31.1% (19.5 to 45.7%) | 77.8% (65.1 to 86.8%) | 26.3%
CA-125
Obeidat et al., 2004 ^125^ | 13 | 5 | 6 | 16 | 72.2% (49.1 to 87.5%) | 72.7% (51.8 to 86.8%) | 68.4% (46.0 to 84.6%) | 76.2% (54.9 to 89.4%) | 45.0%
CA-125
Saygili et al., 2002 ^126^ | 33 | 11 | 12 | 36 | 75.0% (60.6 to 85.4%) | 75.0% (61.2 to 85.1%) | 73.3% (59.0 to 84.0%) | 76.6% (62.8 to 86.4%) | 47.8%
CA-125
Gemer et al., 2005 ^127^ | 126 | 56 | 138 | 104 | 69.2% (62.5 to 72.9%) | 57.0% (50.8 to 63.2%) | 54.8% (48.4 to 61.2%) | 71.1% (64.8 to 77.5%) | 42.9%
CA-125

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; NPV = negative predictive value; PPV = positive predictive value; TN = true negative; TP = true positive

Figure 7. Diagnostic performance of studies of tests to predict suboptimal cytoreduction (surgical debulking with residual disease > 1 cm) plotted in ROC space

Key to Figure 7: Crosses indicate studies of CA-125; open circles indicate other tests.

### Discussion

The vast majority of the available literature on the use of genomic tests in the management of patients with ovarian cancer consists of serum measurement of single-gene products, particularly CA-125, as predictors of (a) initial response to chemotherapy; (b) complete resolution of disease (i.e., negative SLL); or (c) the ability to perform optimal cytoreduction. There is also a substantial literature that reports on the association of various genomic tests with prognosis, but the majority of these studies were excluded because they did not describe patient management.

The studies that sought to predict initial response to chemotherapy were generally performed in unselected women with ovarian cancer, not just those with optimal debulking, for example. Although, in theory, there is significant benefit, both clinically and in the research setting, of being able to predict who will respond to chemotherapy, we did not identify any studies that demonstrated this; there were no studies, for example, that compared different chemotherapeutic regimens based on test results.

Studies evaluating the association of genomic test results with second-look surgery were commonly limited to women who had appeared to have a complete response to initial debulking and chemotherapy. In these studies serum markers were often measured close to the time of SLL (e.g., at the end of chemotherapy or immediately prior to SLL); however, immunohistochemical tests were usually based on tissue obtained at the time of primary surgery. SLL is sometimes used to evaluate women who appear clinically to have had a complete response, since other techniques, such as CA-125 and imaging, are fairly insensitive for very small disease. However, most of the data suggests that there is no substantial survival benefit to SLL, even if residual tumor is removed; a Gynecologic Oncology Group non-randomized study reported a difference in median survival of only 1 month. ^128^ Thus, the SLL might be more properly though of as a test for monitoring disease or the outcome of treatment (a reference standard) rather than as a therapeutic option itself; the potential benefit of better sensitivity at detecting residual disease would be the ability to avoid the need for SLL altogether (and its concomitant cost and morbidity).

Finally, the prediction of optimal debulking is potentially helpful; for example, patients might benefit by referral to particularly expert surgeons, or to research protocols. Patients unlikely to obtain optimal debulking could be selected for neoadjuvant chemotherapy to improve the likelihood of debulking success; however, this strategy has not been tested. ^129^ As with tests for response to chemotherapy, there are, as yet, no studies prospectively demonstrating improved patient outcomes from such a strategy.

### Summary

Although there is a reasonable amount of data on the association between genomic tests, particularly CA-125, and the likelihood of different clinical outcomes, we did not identify any studies that provided evidence for changes in management leading to improved outcomes based on the results of the tests.

## Question 5: Harms of Using Genomic Tests

Question 5 is: What are the harms of using genomic tests for ovarian cancer prevention and management?

### Approach

The nature of the potential harms associated with genomic testing in ovarian cancer varies depending on the potential application of the test:

Testing for increased risk of ovarian cancer. Potential harms associated with testing for inherited or acquired genetic changes that are associated with increased risk of ovarian cancer include:

- The harms associated with the management of women who have positive results. These include complications of primary preventive therapy (for example, surgical complications from prophylactic oophorectomy) and sequelae of the therapy (loss of fertility, premature menopause). For strategies involving more frequent screening, the impact on time and any discomforts associated with the screening test need to be considered.
- The effects on quality of life and other psychological measures of a diagnosis that provides knowledge of an increased risk of disease, with little direct evidence for the benefit of management strategies.
- The potential impact on decisions about childbearing for inherited mutation.

Screening for early ovarian cancer, diagnosis of ovarian cancer. The main potential harm associated with the use of genomic tests for screening for ovarian cancer or for the diagnosis of ovarian cancer is the risk of a false-positive test result, with potential for anxiety about the diagnosis, as well as the risks of definitive diagnostic surgery. ^14^

Testing for targets for specific therapy. The main potential harm associated with testing for specific targets is a false-positive result, which would lead to inappropriately exposing a patient to the risks of the targeted treatment, provision of ineffective treatment, and delayed start of potentially more effective therapy.

We searched for studies that described these classes of adverse outcomes for any type of genomic testing, excluding studies covered in previous reviews of the potential harms of screening using CA-125 and BRCA1/2 conducted for the USPSTF, ^14,^ ^30,^ ^31^ but including articles published after the inclusion dates for these reviews.

### Other Evidence Reports

The review of ovarian cancer screening for the USPSF did not identify any specific articles describing harms of screening, but pointed out the low positive predictive value of available tests and the large number of unnecessary surgeries. ^30^ The adnexal mass evidence report was unable to draw any conclusions about the potential harms of false-positive surgeries because of limitations in the literature, primarily a failure to distinguish the preoperative indication for surgery from the postoperative findings. ^14^

The review of BRCA1/2 testing identified relatively few studies addressing the harms of testing. ^31^ Only one study reported complications of prophylactic oophorectomy in carriers (4 of 80 women). Quality-of-life studies which involved only prophylactic oophorectomy (as opposed to prophylactic mastectomy with or without oophorectomy) were inconclusive. ^31^

### Results

We did not identify any articles that specifically described the harms associated with genomic testing for ovarian cancer. In the PLCO study, 62 of 402 women with an elevated CA-125 underwent surgical biopsy; of these, 16 had any neoplasm, with 13 (3.7 percent) having an invasive cancer. ^61^ The paper did not report whether there were any complications from these surgeries.

We identified four studies of BRCA1/2 testing published since the USPSTF review (see Evidence Table 4, Appendix D *).

McInerney-Leo and colleagues published two papers from the same large study. In the first paper, ^130^ they reported data on a variety of psychological measures, including depression, self-esteem, and cancer-related distress, in 212 adult members of families with documented BRCA1/2 mutations before and after counseling and possible testing. Intrusive thoughts, depressive symptoms, and breast and ovarian cancer worries improved in subjects with negative test results, but there was no change in those with positive results, or in those who declined testing.

In the second paper, McInerney-Leo and colleagues ^131^ measured the impact of BRCA1/2 testing on family relationships using a validated index in the same study population. Interestingly, subjects who declined testing had more positive changes than those who accepted testing. In those who accepted testing, there was a non-significant trend towards decreased expressiveness among family members in those who had an abnormal test result.

Two studies reported measures separately for ovarian and breast cancer in women at risk for BRCA1 and BRCA2 mutations. In the first, Bish and colleagues ^132^ collected data on a variety of quality-of-life measures in 203 subjects undergoing counseling regarding BRCA1 and 2 mutation testing because of family histories, and found that (1) worry about ovarian cancer was significantly less than worry for breast cancer; (2) worry about ovarian cancer was highest in women with a personal history of cancer, independent of the degree of risk or results of testing and (3) there was no overall change in worry about ovarian cancer in response to testing.

Claes and colleagues ^133^ performed a similar study in 71 similar subjects. As in the Bish study, there were differences in responses by cancer type: risk perception and distress were higher for breast cancer than for ovarian cancer. After testing, distress related to ovarian cancer was higher in carriers then in non-carriers, but was not signficiantly different from baseline levels by 12 months posttesting. Women who underwent prophylactic oophorectomy had decreased levels of concern, but higher levels of somatic symptoms.

### Discussion

Only two articles specifically reported outcomes relevant to ovarian cancer. The majority of the available literature focuses on BRCA1/2 testing, but does not report results separately for ovarian and breast cancer outcomes. The differences observed in the studies we did identify suggest that testing for genetic markers of ovarian cancer susceptibility alone may have different implications compared to testing for genes that affect both breast and ovarian cancer risk.

For the most part, the potential harms associated with the use of genomic tests in screening, diagnosis, and management of ovarian cancer are no different than those of other tests, such as imaging: the risks of false-positive results leading to unnecessary and potentially dangerous treatment, as well as the psychological effects of a cancer diagnosis; and the risks of false-negative results leading to delayed diagnosis and therapy, with a potential for a poorer prognosis. The types of risks are similar - the only potential difference between genomic tests and other modalities lies in the quantitative risk of false-negative and false-positive results, which in turn depends on test sensitivity, specificity, and the pretest probability of disease. Higher quality evidence about the test characteristics of genomic tests for ovarian cancer should allow better estimation of these types of harms. The one type of test that might have implications similar to those for markers of increased risk would be a test for an inherited polymorphism that affected the likelihood of response to therapy; if such a polymorphism also affected the likelihood of responses or side effects for therapies for other conditions, the longer term implications for the patient and her family would have to be considered.

For tests of markers of increased risk, such as inherited mutations, there are some additional potential harms, namely, the impact of knowledge of increased risk when optimal options for reducing that risk, either through primary or secondary prevention, are unclear. Specifically, in the case of ovarian cancer, bilateral oophorectomy in premenopausal women affects childbearing potential and induces premature menopause; given the uncertainty about optimal methods for hormone replacement, this option may be even more confusing for some women. Because of varying degrees of penetrance, even the estimate of increased risk associated with a given mutation is subject to a fairly wide degree of uncertainty. Issues surrounding heritability in subsequent generations may also be important to some women. In this case, although the literature on BRCA testing is helpful in identifying some of these issues, there is a greater need for providing results specifically for ovarian cancer-related issues in studies of markers which affect the risk of several types of cancers. The available literature suggests that, for most women with BRCA mutations, breast cancer is a greater concern than ovarian cancer. Given the differences in both quantitative risk and the types of risks associated with testing, diagnosis, and prophylaxis, results need to be provided specifically for ovarian cancer-related outcomes in studies of BRCA testing.

### Summary

The literature on the harms of genomic tests for ovarian cancer is sparse, with the majority of the available literature on psychological impacts of testing consisting of studies of women tested for susceptibility to both breast and ovarian cancer. Future studies will need not only to identify the short-term psychological impact of different test results, but also provide data on the outcomes of strategies used to reduce the risk of ovarian cancer in patients who undergo testing for susceptibility. The theoretical harms of genomic tests in the setting of screening, diagnosis, and management of ovarian cancer are similar to those for other types of tests and should ultimately be estimated based on better evidence for test characteristics and the effectiveness of management strategies based on test results.

## Question 6: Direct-to-Consumer and Direct-to-Physician Marketing

Question 6 is: Has direct-to-consumer and direct-to-physician marketing of genomic tests on ovarian cancer increased the “appropriate” use (as defined by study investigators) of these tests?

### Approach

We searched for articles that specifically measured responses by providers and/or patients to direct advertising campaigns. We also considered alternative sources of data on the nature and volume of direct-to-consumer and direct-to-provider marketing and identified methodological issues involved with utilizing these alternative sources.

### Results

We did not identify any articles specifically targeting ovarian cancer genomic testing. We identified two articles that investigated the impact of a single advertising campaign for BRCA1/2 testing, targeted at women at high risk for breast or ovarian cancer. ^134,^ ^135^

From September 2002 through February 2003, the U.S. manufacturer of BRCA1/2 testing conducted a pilot direct-to-consumer marketing campaign in Atlanta, Georgia, and Denver, Colorado. The campaign was targeted at women aged 25 to 54 with personal or family histories of breast and/or ovarian cancer, along with their healthcare providers. Television, radio, and print advertisements were generated to raise awareness about BRCA1/2 testing and to motivate women to ask their providers about how testing might help assess risk and change management. Providers received information and patient support materials prior to the beginning of the campaign. Although this marketing campaign was not designed as a research study, two groups were able to take advantage of the campaign and design studies to assess the impact of the campaign on test utilization.

In a study conducted by the Centers for Disease Control and Prevention (CDC) and the state health departments of Colorado, Georgia, North Carolina, and Washington, ^134^ investigators conducted a survey of providers and consumers in the two pilot cities and two comparison metropolitan areas (Raleigh-Durham, NC, and Seattle, WA). From April 21 through May 20, 2004, a 51-question consumer telephone survey was conducted using random telephone numbers, with a target response of 1,600 women. Questions included family history; campaign awareness; interest in genetic testing for BRCA1/2; cancer concerns; and interactions with providers, family, and friends. A 35-question survey and monetary survey were mailed to providers (randomly selected to be proportionately representative of family practice, internal medicine, obstetrics/gynecology, and oncology) on May 1, 2003; the target response was approximately 1,600.

One thousand and six hundred and thirty-five (1,635) women completed the survey, for a response rate of 45 percent; most were non-Hispanic white women with more than high school education and a median age of 40 years. Women in the pilot cities were significantly more likely to have heard of the test, but no significant differences were observed in stated knowledge about genetic testing, concern about risk for breast and ovarian cancer, or proportion of women who had talked with someone about genetic testing. Family histories were similar among those who expressed an increased interest compared to those who did not.

One thousand and fifty-four (1,054) providers completed the survey (66 percent response rate). Providers in pilot cities were significantly more likely to report that they and their patients had been exposed to an advertisement about genetic testing and to report an increase in the number of patients asking about testing, asking for genetic counseling, and requesting testing. The number of tests ordered increased significantly in the pilot cities as well, although the number of referrals for counseling did not increase. Provider knowledge about testing did not differ between cities, but knowledge did differ between specialists, with obstetricians/gynecologists and oncologists having higher levels of knowledge.

Limitations noted by study investigators included lack of data on non-responders; the potential for bias because of the low response rate among consumers; a relatively short lag time between the advertising campaign and the survey, which might have been insufficient to allow all those interested in testing to undertake and complete the process; lack of availability of data on the number of tests actually performed and the appropriateness of those tests because of the proprietary nature of the tests; and lack of data on the appropriateness of education, counseling, and testing ordered by providers.

A separate study conducted by investigators at Kaiser Permanente Colorado compared utilization of testing before and after the advertising campaign to similar time periods using data from the Henry Ford Health System in Detroit, Michigan. ^135^ Utilization assessment was through electronic records. The investigators noted a 240 percent increase in the number of referrals for genetic testing in Colorado during the advertising campaign compared to a similar time period 1 year prior to the campaign (from 144 referrals per average membership to 499 referrals per average membership), while no change was seen in Detroit (53 and 52 referrals per average membership during the two time periods).

Interestingly, although the absolute number of women with 10 percent or greater pretest probability of a mutation increased during the advertising campaign, the proportion of all referrals with a high pretest probability decreased from 69 percent to 48 percent in Denver, while no change was seen in Detroit. An increase in referrals from non-physician providers was noted.

The authors noted the difference between self-reported patient behavior in the CDC report and their observations; possible explanations included inaccurate self-report, differences in interest in testing between the general population and women with prepaid access to healthcare, concurrent education efforts by Kaiser Permanente, and discussion among women at workplaces or other settings with common insurance coverage.

### Discussion

We identified only two relevant articles on the impact of direct-to-consumer advertising on utilization of genomic tests, both involving the same advertising campaign. One study found evidence of increased awareness of the test covered in the advertising campaign among consumers, but no self-reported increase in knowledge or intention to get tested. Conversely, providers reported the perception of an increased number of patients discussing and requesting testing and reported ordering more tests. The second study used administrative data to measure test utilization within a managed care organization before and after the campaign and found an increase in the number of tests ordered, with a decrease in the proportion of women with a high pretest probability of a mutation.

There are a number of methodological issues involved in assessing the impact of advertising on genetic test utilization:

Definition of “appropriate” use of testing. Possible definitions include:

- Use of the test only in those women with characteristics similar to those for whom the benefit of the test has been conclusively demonstrated, preferably through a randomized trial.
- Use of the test only in those women with characteristics that meet criteria agreed upon by expert consensus.
- Use of the test only in women who receive unbiased counseling on the state of knowledge regarding the benefits and harms of the test and who, based on their personal preferences, wish to have the test.
- Use of the test only in women for whom use of the test is estimated to result in an acceptable cost-effectiveness ratio.

Given the state of the literature on genomic tests in ovarian cancer, consensus opinions on appropriateness are likely to be the only criteria available for the near future.

Measuring test utilization. There are several challenges to measuring test utilization:

- As the CDC researchers noted, data on tests performed in private laboratories may not be publicly available; companies may view these data as proprietary information which, if available, would put them at a disadvantage in a competitive marketplace.
- Test utilization data could be obtained through administrative data, such as from a managed care organization. The ability to link to clinical data could help in estimating “appropriateness” - estimation of pretest probability of BRCA1/2 mutations by the Kaiser researchers is an example of this. However, this type of data is also often proprietary and not readily accessible to outside researchers. In addition, depending on the data source, there may be issues about the generalizability of results, since presumably utilization of tests and other resources would be more tightly constrained within a managed care organization. Also, as the Kaiser researchers point out, women enrolled in managed care plans may be different in many respects from the general population.

Quantifying direct-to-consumer advertising. Challenges to measuring and quantifying direct-to-consumer advertising include:

- Estimating exposure to various advertising in various types of media requires complex survey methodology.
- Measurement of the impact of non-advertising coverage in the media, such as coverage in news reports of scientific meetings, journal publications, or other forums (such as congressional hearings), needs to be considered.
- It is possible that other publicly available information could provide some insight into advertising; for example, annual reports of publicly traded companies might provide a breakdown of marketing expenses, although the extent to which specific inferences could be drawn about the nature of these marketing expenses is unclear.

Quantifying direct-to-physician advertising. Methdological challenges in measuring direct-to-physician advertising include:

- Quantifying advertising in journals would require either hand searches or access to records from a specific journal. This would be particularly difficult for non-peer-reviewed journals, which are frequently not maintained in medical libraries, but which may represent a significant portion of the literature.
- Quantifying other types of “advertising,” such as sponsorship of symposia at meetings, exhibits at meetings, sponsorship of continuing education activities at local hospitals, etc.

Study design. Even with a clear definition of “appropriate use” and methods for measuring utilization and advertising, there remain additional methodological issues. For example, although randomized trials would be ideal, it is difficult to imagine how one would be feasible. Before-and-after studies, with “exposed” and control populations, as were done with BRCA1/2 testing, appear to be the most practical, but require considerable planning, including, ideally, advance notice about the advertising campaign.

### Summary

There are considerable methodological issues involved in determining the effect of direct-to-consumer and direct-to-physician marketing on the appropriate or inappropriate use of tests. We identified two studies of a single advertising campaign which suggested increased utilization of testing in the near term after a direct-to-consumer campaign, but provided little information on the appropriateness of the testing. The decrease in pretest probability observed after the advertising campaign suggests that, for some types of genomic tests, there may be a decrease in positive predictive value in response to advertising.

## Modeling Results

The results presented below represent initial calibration of the natural history models (one assuming that all cancers progress through Stage II, and one allowing direct progression to Stage III from Stage I).

### Model Validation

Lifetime cancer incidence and mortality. Figures 8–11 and Table 12 show the results of these calibrations under our two natural history assumptions of disease progression.

Table 12 Overall and age-specific stage distribution of ovarian cancer at diagnosis

Age | Stage I | | | Stage II | | | Stage III/IV
| SEER | Model 1* | Model 2* | SEER | Model 1* | Model 2* | SEER | Model 1* | Model 2*
45–54 | 25.77% | 20.66% | 21.18% | 8.25% | 9.71% | 5.81% | 65.98% | 69.63% | 73.02%
55–64 | 17.71% | 19.57% | 20.33% | 7.29% | 9.45% | 5.79% | 75.00% | 70.98% | 73.88%
65–74 | 12.63% | 19.14% | 19.98% | 6.32% | 9.34% | 5.78% | 81.05% | 71.53% | 74.24%
75+ | 9.20% | 18.83% | 19.74% | 5.75% | 9.26% | 5.78% | 85.06% | 71.91% | 74.49%
All ages | 16.33% | 19.55% | 20.31% | 6.90% | 9.44% | 5.79% | 76.77% | 71.01% | 73.91%

* Model 1 assumes that patients must transition from Stage I ovarian cancer through Stage II before progressing to Stage III. Model 2 assumes that some proportion of patients proceed directly to Stage III ovarian cancer from Stage I.

Figure 9. Age-specific probability of dying from ovarian cancer (assuming Stage II is necessary transition)

Figure 10. Age-specific probability of developing ovarian cancer (assuming Stage I can transition directly to Stage III)

Figure 8. Age-specific probability of developing ovarian cancer (assuming Stage II is necessary transition)

Figure 11. Age-specific probability of dying from ovarian cancer (assuming Stage I can transition directly to Stage III)

Both models closely approximate the Surveillance, Epidemiology, and End Results (SEER) lifetime risk for women at age 40 of 1.44 percent; there is a slight underestimation of mortality risk, primarily for women 85 and older (which is likely due to the assumption of constant stage-specific probability of diagnosis; because of age-specific variations in access to care, prevalence of conditions mimicking ovarian cancer, etc., this assumption may be incorrect). Lifetime risk of dying from ovarian cancer within the SEER data is 1.13 percent; model predictions are 1.06 percent.

Stage distribution. Table 12 illustrates overall and age-specific stage distributions from SEER and the two models.

Although many of the parameters of the model are known (stage-specific mortality, age-specific mortality from other causes, etc.), there are several parameters which are “unknowable unknowns.” In particular, we can never know with any degree of precision two key variables: (1) the rate at which an ovarian cancer at a given stage will proceed to the next stage; and (2) the probability that, within a given time period, a woman with a given stage of ovarian cancer will have her cancer detected and thus become an incident case. These probabilities must be imputed from available data - we know what the cancer incidence and stage distribution should be, and the values for these “unknowable” parameters are adjusted until a reasonable approximation is achieved. Table 13 shows the current values for these imputed probabilities.

Table 13 Baseline estimates for annual probability of progressing between stages and stage-specific probability of progression

Parameter | Value: Model 1 | Value: Model 2
Annual probability of progression
Stage I to Stage II or III | 0.75 | 0.725
Stage II to Stage III | 0.925 | 0.75
Stage III to Stage IV | 0.35 | 0.35
Proportion of Stage I tumors progressing directly to Stage III | 0 | 0.75
Annual probability of detection
Stage I | 0.25 | 0.25
Stage II | 0.25 | 0.4
Stage III | 0.7 | 0.7
Stage IV | 1 | 1

The wider variation in stage distribution observed between age groups within the SEER data compared to model predictions may be due to any of several factors:

(1) There may be age-specific variations in the rates of progression between stages; for example, age-related changes in hormonal status or immune function may affect the likelihood of metastasis.
(2) There may be age-specific variations in the rates of detection within stages; for example, older women may have their cancer detected at later stages because of less access to physicians, different thresholds for seeking care for symptoms, or delayed diagnosis because the non-specific symptoms of ovarian cancer frequently mimic other conditions common in older women.
(3) SEER data is cross-sectional, and the model is simulating a cohort. There may be unmeasured cohort effects in exposure to risk factors for ovarian cancer, competing risks, etc., which are not captured.

Future versions of the model will explore these possibilities by allowing the probabilities of progression and detection to vary with age. Allowing either more rapid progression to Stage III/IV or lower probability of detection among older women, in particular, would result in a greater proportion of advanced stage disease and higher mortality rates, and result in a closer match to SEER data. However, the greater “precision” of such an approach must be balanced against the risks of introducing inaccuracies by “overfitting” a cohort model which does not incorporate potential cohort effects into cross-sectional data.

### Impact of Different Strategies

In order to compare the relative impact of different strategies and the conditions under which they would be effective, sensitivity analyses were conducted to determine the values for specific parameters that would result in a 20 percent reduction in ovarian cancer mortality. Table 14 summarizes these results.

Table 14 Parameter estimates resulting in 20% reduction in ovarian cancer mortality under different strategies

Strategy | Model 1 | Model 2
Primary prevention | Efficacy of primary prevention must be greater than 20%
Interval screening | Screening (with 95% specific and 90% sensitive test) should be every 33 months or less | Screening (with 95% specific and 90% sensitive test) should be every 31 months or less
Interval screening | Assuming every 2-year screening, sensitivity must be greater than 67% | Assuming every 2-year screening, sensitivity must be greater than 69%
Genetic screening and interval screening of women with the mutation | Assuming every 2-year screening for positive patients, a genetic mutation needs to confer at least a 30× risk increase | Assuming every 2-year screening for positive patients, a genetic mutation needs to confer at least a 32× risk increase
Genetic screening and interval screening | Assuming every 2-year screening for positive patients, the genetic mutation needs to be prevalent in 60% of the population | Assuming every 2-year screening for positive patients, the genetic mutation needs to be prevalent in 64% of the population
Genetic screening and primary prevention in women with the mutation (effectiveness of primary prevention = 20%) | A genetic mutation needs to confer at least a 30× risk increase | A genetic mutation needs to confer at least a 30× risk increase
Genetic screening and primary prevention in women with the mutation (effectiveness of primary prevention = 20%) | The genetic mutation needs to be prevalent in 51% of the population | The genetic mutation needs to be prevalent in 52% of the population
Targeted treatment | If the targeted treatment reduces cancer mortality by 67% then the targeted risk factor needs to be prevalent in approximately 80% of the population. An 89% reduction would require 35% prevalence of the targeted risk factor. | If the targeted treatment reduces cancer mortality by 67% then the targeted risk factor needs to be prevalent in approximately 89% of the population. An 89% reduction would require 35% prevalence of the targeted risk factor.

Addressing the original questions:

(1) How effective would a primary prevention intervention need to be to reduce ovarian cancer deaths by 20 percent?

Not surprisingly, a primary intervention in the entire population that reduces ovarian cancer incidence by 20 percent should reduce mortality by 20 percent. This level of reduction could be achieved either by an intervention with 20 percent reduction used in 100 percent of the population, or by an intervention with higher efficacy used in a smaller proportion (for example, a 20 percent overall reduction would be achieved by an intervention with 40 percent efficacy used in 50 percent of the population).

(2) What combinations of test sensitivity and frequency result in at least a 20 percent reduction in mortality?

At a sensitivity of 90 percent, screening could be done relatively infrequently (every 33 months) and still result in a predicted decrease of 20 percent in mortality. For biannual screening, sensitivity could be as low as 67 percent.

(3) What combinations of (a) prevalence of a genetic mutation in the population and (b) relative risk associated with that mutation would result in the target 20 percent reduction in ovarian cancer deaths with either primary prevention (at various levels of effectiveness) or interval screening (at varying levels of sensitivity and specificity)?

At a population level, very high relative risks and prevalences are required to have a substantial impact on overall ovarian cancer mortality; primary prevention or screening could, in theory, be highly effective for individuals with the genetic predisposition, but this would have a relatively small impact on overall population mortality.

(4) How effective would a targeted treatment for ovarian cancer need to be (and in what proportion of the population would the marker for that treatment need to exist)? Note that we assume that targeted therapy would be equally effective across all stages of disease.

If the targeted treatment reduces cancer mortality by 67 percent, then the targeted risk factor needs to be prevalent in approximately 80 percent of the population. An 89 percent reduction would require 35 percent prevalence of the targeted risk factor.

(5) How do the test characteristics for targeted treatment or genetic screening affect the results?

(6) How do the above results differ under the assumption that cancer must progress from Stage I to II (Model 1) and then III versus that assumption that ovarian cancer may progress directly from Stage I to Stage III (Model 2)?

(7) What effect does the assumption about natural history have on the relative efficacy of screening?

Figure 12 illustrates the effect of varying screening intervals at three different levels of test sensitivity, and for the two different models. Reductions of less than 20 percent occur at intervals greater than 30 months.

Figure 12. Effect of screening frequency on reduction in cancer mortality at different levels of test sensitivity

Of note:

- At any given level of sensitivity, Model 1 (which assumes that Stage II is required prior to development of Stage III) results in greater relative reduction in cancer mortality than Model 2, where cancer can progress directly from Stage I to Stage III.
- This difference is relatively small, largely because the duration of Stage II in Model 1 needed to result in stage distributions similar to observed data is short.
- This effect is somewhat ameliorated by decreasing the screening interval (allowing more opportunities to detect the Stage I cancer prior to progression to Stage III).
- Under both models, the difference in relative cancer reduction at a screening interval at 12 months between a test with a sensitivity of 80 percent and one with a sensitivity of 99 percent is approximately 7 percent. At any given level of sensitivity, this difference can also be achieved by reducing the screening interval by 3 months.
- Reductions in mortality greater than 50 percent require screening at most every 12 months; at sensitivities below 99 percent, screening needs to be at less than annual intervals.
- The finding that mortality reduction is highly sensitive to screening intervals of less than 12 months, but relatively insensitive to screening intervals between 12 and 30 months, suggests that screening at less frequent intervals is detecting a population of tumors which are relatively indolent (length bias).

Figure 13 illustrates the impact of screening frequency and test sensitivity under the assumptions of Model 2 (some cancers progress directly to Stage III from Stage I) on the lifetime negative predictive value of screening.

Figure 13. Effect of screening frequency on population negative predictive value at different levels of test sensitivity (specificity fixed at 99%)

Note that, although the relationship between negative predictive value and screening interval increases as test sensitivity decreases, the negative predictive value is still greater than 99.99 percent at a sensitivity of 80 percent with biennial screening; this is due to the relatively rarity of ovarian cancer.

Conversely, positive predictive value over the lifetime of the cohort is quite sensitive to screening frequency (Figure 14).

Figure 14. Effect of screening frequency on population positive predictive value at different levels of test specificity (sensitivity fixed at 99%)

Even at high levels of specificity, the positive predictive value remains below four percent. At the screening frequencies required for 50 percent reduction in mortality, the positive predictive value is less than three percent. Although this does not have a substantial impact on overall mortality, because of the relatively low mortality associated with laparotomy, it does have a substantial impact on the efficiency of screening (Table 15). At intervals of 12 months or less, and specificities less than 97.5 percent, the average woman is guaranteed to have at least one false positive test result over her lifetime. Given the above findings regarding sensitivity and screening frequency, and that there is an almost inevitable tradeoff between sensitivity and specificity, it seems likely that screening with the frequency required to have a substantial impact on mortality will result in a very high number of false-positive results.

Table 15 Estimated lifetime number of false positive results at different screening frequencies and test specificities

Screening interval (months) | Test specificity
| 95% | 97.50% | 99%
3 | 8.11 | 4.05 | 1.62
6 | 4.07 | 2.03 | 0.81
9 | 2.72 | 1.36 | 0.54
12 | 2.05 | 1.02 | 0.41
15 | 1.64 | 0.82 | 0.33
18 | 1.37 | 0.69 | 0.27
21 | 1.18 | 0.59 | 0.24
24 | 1.04 | 0.52 | 0.21

### Summary

- The current model closely approximates lifetime cancer incidence, mortality, and stage distribution. Differences between observed and predicted values for age-specific stage distribution and mortality will require further imputation of values for stage-specific progression and detection probabilities.
- Strategies which seek to identify high-risk groups are likely to have relatively small impact on overall ovarian cancer mortality, even if they are highly successful in reducing mortality in the risk group.
- Therapies after diagnosis which are based on genomic targets may reduce mortality substantially, but only if the targets are common and treatment highly effective.
- Reductions in ovarian cancer mortality of greater than 50 percent through screening require testing at intervals of 12 months or less, and are relatively independent of test sensitivity. Conversely, the number of false-positive results is quite high at these screening intervals unless test specificity is quite high.
- These findings suggest that the failure to identify effective strategies for ovarian cancer screening may be due at least in part to the natural history of the disease, rather than the failure of the tests evaluated.