# Methods

This section of the report describes the basic methodology used to develop the evidence report, including topic assessment and refinement, analytic framework, literature search strategies and results, literature screening, quality assessment, data abstraction methods, and quality control procedures.

## Topic Assessment and Refinement

The Centers for Disease Control and Prevention (CDC) and the Agency for Healthcare Research and Quality (AHRQ) originally identified six key questions to be addressed by the report, which is intended to assess the evidence for the diagnostic accuracy, benefits, and harms of genomic tests in screening and management of ovarian cancer. The Duke research team clarified and refined the overall research objectives and key questions by first consulting with the two study sponsors, AHRQ and CDC, and then convening a national panel of technical experts to serve as advisors to the project. These experts were selected to represent relevant specialties. Members of the technical expert panel were:

Alfred O. Berg, M.D., M.P.H.; Department of Family Medicine, University of Washington; Seattle, WA (member of the CDC Evaluation of Genomic Applications in Practice and Prevention [EGAPP] Working Group)

Katrina Armstrong, M.D., M.S.C.E.; Leonard Davis Institute of Health Economics, University of Pennsylvania School of Medicine; Philadelphia, PA (EGAPP Working Group member)

Jeffrey Botkin, M.D., M.P.H.; Department of Pediatrics and Medical Ethics, University of Utah; Salt Lake City, UT (EGAPP Working Group member)

JoEllen Schildkraut, Ph.D.; Department of Prevention Research, Duke University; Durham, NC

As a result of an initial conference call with the technical experts, AHRQ, and CDC, the Duke research team finalized the key research questions to be included in the report and the approach that would be used to address them. The final key questions are as follows:

- Question 1: What is the evidence that ovarian cancer genomic tests performed in a typical clinical laboratory actually measure what they are purported to measure?
- Question 2: What is the sensitivity and specificity of genomic tests in detecting ovarian cancer in asymptomatic and symptomatic women, including high-risk women?
- Question 3: What is the evidence that genomic testing to detect ovarian cancer in asymptomatic women, including high-risk women, changes clinical management and leads to improved health outcomes?
- Question 4: What is the evidence that genomic testing in women with clinical suspicion of ovarian cancer or with already-diagnosed ovarian cancer changes clinical management and leads to improved health outcomes?
- Question 5: What are the harms of using genomic tests for ovarian cancer prevention and management?
- Question 6: Has direct-to-consumer and direct-to-physician marketing of genomic tests on ovarian cancer increased the “appropriate” use (as defined by study investigators) of these tests?

## Analytic Framework

The methodological approach to this review was designed to inform the EGAPP Working Group's deliberations in formulating evidence-based recommendations for the use of genetic testing in the detection and management of ovarian cancer. We developed a project-specific analytic framework to address the key questions within the context of a standardized evidence report (Figure 2).

Figure 2. Analytic framework for evidence report

Note: Numbers refer to key questions

The analytic framework depicted above serves to clarify the relevant key questions as follows:

- Genomic tests can detect an inherited predisposition, genes and proteins that are associated with the presence of cancer, or genes and proteins that identify targets for therapy or predict response to therapy. Question 1 addresses whether available tests perform as intended at the level of the laboratory (“analytic validity”).
- Genomic tests in the second category, above, may detect ovarian cancer either in women without symptoms (used as a screening test) or as part of the evaluation of women with symptoms (Question 2).
- Based on the results of genomic testing, women may have different strategies; women with a predisposition to ovarian cancer may undergo primary or secondary prevention strategies, while, ideally, asymptomatic women detected through genomic tests will have reduced ovarian cancer mortality, without unacceptable levels of harm from testing and diagnosis, than women who do not undergo genetic testing (Question 3).
- Genomic testing can potentially serve as a test to help discriminate cancer from benign conditions in women with symptoms, or lead to specific therapies with better outcomes in women who have already had a diagnosis of ovarian cancer (Question 4).
- As with any test, there are potential harms associated with genomic testing. These include anxiety about the risk of ovarian cancer and difficult decisions regarding reproduction and possible prophylactic surgery in women with inherited predispositions; additional diagnostic tests, including diagnostic surgery, or use of inappropriate therapy, in women with false-positive tests; and the failure to further evaluate, or appropriately treat, women with false-negative tests (Question 5).
- Although not in the formal pathway, marketing to consumers and physicians may make women more likely to undergo testing. Particularly in asymptomatic women, this testing may lead to (a) diagnosis of a predisposition in the absence of clear evidence on appropriate management strategies, or (b) diagnosis of “abnormality,” leading to additional tests, including surgery (Question 6).

## Literature Search and Review

### Sources

The primary source of literature was MEDLINE^®^ (1966–May 2006). Searches of this database were supplemented by reviews of reference lists contained in all included articles and in relevant review articles and meta-analyses.

### Search Strategies

The basic search strategy used the National Library of Medicine's Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE.^®^ Searches were limited to articles published in English. The exact search string used is given in Appendix A.^*^The three searches yielded a total of 1,303 citations, whose records were maintained in a ProCite (Thompson ISI ResearchSoft, Berkeley, CA) database.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/genovctp.htm.

### Abstract and Full-text Screening

Paired researchers from the Duke research team independently reviewed abstracts and classified each as “include” or “exclude” according to study-specific criteria, which they also developed. Abstracts were included if at least one of the paired reviewers recommended that it be included. A total of 552 abstracts were included for the further full-text review stage. Interrater reliability for include/exclude decisions at the abstract screening stage was tested by having seven pairs of readers review 813 abstracts. Agreement was good to excellent (kappa 0.36 to 0.75).

At the full-text review stage, the paired researchers independently reviewed a set of the articles and indicated a decision to “include” or “exclude” the article for the data-abstraction stage. When a pair of reviewers arrived at different opinions about whether to include an article, they were asked to reconcile the difference. Detailed inclusion and exclusion screening criteria were developed by research question and are described immediately below.

### Screening Criteria

Abstracts were included for full-text review if they met the criteria described below, or if insufficient information was provided to judge whether they met the criteria. Articles were included for abstraction if full-text review showed that all criteria were met.

An article was included if it pertained to:

(1) Epithelial ovarian cancer or primary peritoneal carcinomatosis; and
(2) Genomics as defined by AHRQ for this project to mean any gene-based test used for predicting risk of developing disease, screening, diagnosis of disease, disease management, or prognosis only in strategies for the prevention of ovarian cancer morbidity and mortality. These included single gene products (e.g., cancer antigen 125 [CA-125]); genetic variations (e.g., breast cancer genes 1/2 [BRCA1/2] ); gene expression (e.g, human epidermal growth factor receptor 2 [HER2]/neu); and either single or multiple genes (e.g., microarrays) and protein expression (e.g., mass spectroscopy of multiple proteins in sera of patients with ovarian cancer compared with controls).

We included tests that:

(1) Detect the presence of inherited mutations or gene polymorphisms which increase the risk of development of ovarian cancer;
(2) Genes, RNA, or protein markers which are present or produced (or are present or produced in greater quantity) only in cells that have already undergone the transformation to cancer, and which can be used to detect asymptomatic or symptomatic cancers; and
(3) Genes or proteins which may help predict the response to specific types of therapy, or themselves be targets of specific therapies.

We excluded the following:

(1) Studies on BRCA1/2 screening and identification of risk covered in an earlier AHRQ evidence report; ^31^
(2) Studies on CA-125 screening and diagnosis covered in earlier AHRQ evidence reports; ^14,^ ^30^
(3) Studies involving only germ cell or stromal ovarian cancer, or non-ovarian primary;
(4) Studies where patients are not the denominator;
(5) Studies involving a cell line only;
(6) Studies where reported data do not allow construction of a 2-by-2 table.

Summaries of the results of the abstract screening and full-text review are provided in Tables 3 and 4. A list of excluded articles, with reasons for exclusion, is provided in Appendix B.^*^

Table 3 Results of abstract and full-text screening

Articles identified | 1,303
Abstracts screened | 1,303
Included | 552
Excluded | 751
Full-text articles screened | 549^†^
Included | 113
Excluded | 436

† We were unable to obtain copies of 3 articles that passed the abstract screen.

Table 4 Included full-text articles by research question

Question | Number of articles
Question 1: Analytic validity of testing | 32
Question 2: Sensitivity and specificity of tests | 50
Question 3: Impact on clinical management of asymptomatic patients | 0
Question 4: Impact on clinical management of diagnosed patients | 29
Question 5: Harms of testing | 4
Question 6: Impact of direct-to-consumer or physician marketing | 2
Total number of included articles | 113^†^

† Total does not equal sum of number of articles across questions because some articles were included for more than one question.

Table 5 depicts the specific tests and clinical application of the tests covered by the included articles.

Table 5 Tests and applications covered by articles included in this report

Category of genomic test | Clinical use of test
| Predisposition | Screening | Diagnosis | Management
Single gene products | | CA-125 | Alpha-L-fucosidase | Bcl-2 (anti-apoptosis protein)
| | | CA-125, CA-72-4, CA-15-3, CA-19-9 | CA-125
| | | CEA | CASA
| | | c-erb-2 | Cathespin-D
| | | CYFRA 21-1 | CYFRA 21-1
| | | Epithelial cell adhesion molecule | c-erb-B2
| | | FAS | hK6, hK10
| | | G-CSF | IL-6
| | | hK6, hK10 | LRP
| | | IL-6, IL-8 | Mdm2
| | | M-CSF | MDR-1
| | | OVX1 | MRP1/2
| | | p55, p75 (tumor necrosis factor receptors) | nm23 (metatstasis suppressor)
| | | Secretory leukocyte protease inhibitor | Pgp
| | | Serum cadherin | p53 = TP53 (transcription factor)
| | | Soluble IL-2 alpha | TN
| | | Soluble intracellular adhesion molecule | TPS
| | | TPS
| | | TATI
| | | Urinary gonadotropin peptide
| | | VEGF
Genetic variations | BRCA1 | | | p53 = TP53 (transcription factor)
| BRCA2
Gene expression | | | CK19 | c-erb-B2
| | | Multiple genes: ascitic fluid | Multiple genes: microarray
| | | Multiple genes: immunohisto-chemistry
Proteomics | | Ciphergen ProteinChips: SAX2, WCX2
| | Mass spectrometry using SELDI
| | (statistical methods varied widely)

## Data Abstraction and Development of Evidence Tables

The Duke research team developed data abstraction forms/evidence table templates for abstracting data for the various key questions (Appendix C *). Based on clinical expertise, a pair of researchers was assigned to the research questions to abstract data from the eligible articles. One of the pair abstracted the data, and the second researcher over-read the article and the accompanying abstraction to check for accuracy and completeness. The completed evidence tables are provided in Appendix D.^*^

## Quality Assessment Criteria

At the data abstraction stage, abstractors were asked to evaluate each included article for factors affecting internal and external validity. The quality assessment criteria used for this purpose were previously developed by the Tufts-New England Medical Center Evidence-based Practice Center for an evidence report on “Effects of Omega-3 Fatty Acids on Cardiovascular Disease.” ^32^ Abstractors were instructed to assign a “+” or “-” to each item and provide a brief rationale for their decisions. Quality criteria assessed in this way were:

For Questions 1 and 2:

- Reference standard
- Verification bias
- Test reliability/variability
- Sample size
- Statistical tests
- Blinding
- Definition of +/- on screening test

For Questions 3–5 (randomized controlled trials [RCTs]):

- Randomization method
- Blinding
- Dropout rate < 20 percent
- Adequacy of randomization concealment

For Questions 3–5 (cohort studies):

- Unbiased selection of the cohort (prospective recruitment of subjects)
- Large sample size
- Adequate description of the cohort
- Use of validated method for genomic test (i.e., analytic validity established)
- Use of validated method for ascertaining clinical outcomes (e.g., surgical pathology, use of validated quality-of-life instrument, death)
- Adequate followup period
- Completeness of followup
- Analysis (multivariate adjustments) and reporting of results

For Questions 3–5 (case-control studies):

- Valid ascertainment of cases
- Unbiased selection of cases
- Appropriateness of the control population
- Verification that the control is free of cancer
- Comparability of cases and controls with respect to potential confounders
- Appropriateness of statistical analyses

After evaluating each study against its question- and design-specific quality criteria, abstractors applied a three-category (A, B, C) summary quality grading system that has been used in previous evidence reports by the Tufts-New England Medical Center Evidence-based Practice Center, including the report cited above. ^32^ This scheme defines a generic grading system for study quality that is applicable to each type of study design (i.e., RCT, cohort study, case-control study). The categories are defined as follows:

A Least bias; results are valid. A study that mostly adheres to the commonly held concepts of high quality, including the following: a formal randomized study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.
B Susceptible to some bias, but not sufficient to invalidate the results. A study that does not meet all the criteria in category A. It has some deficiencies but none likely to cause major bias. Study may be missing information, making assessment of the limitations and potential problems difficult.
C Significant bias that may invalidate the results. A study with serious errors in design, analysis, or reporting. These studies may have large amounts of missing information or discrepancies in reporting.

## Additional Analyses

### Test Characteristics and Confidence Intervals

For test characteristics, a Microsoft Excel® spreadsheet was developed that calculated appropriate test characteristics (sensitivity, specificity, negative predictive value, positive predictive value) for individual studies if studies provided enough data to input (a) values for individual cells of a 2-by-2 table, (b) the prevalence of disease and values for sensitivity and specificity, or (c) sufficient data to solve for two equations involving sensitivity, specificity, or predictive values. Ninety-five percent confidence intervals were automatically estimated using the approximate formula for proportions:

, where p = point estimate of proportion, N = total sample size.

### Ovarian Cancer Model

Model description. We developed a Markov model to estimate the life expectancy for asymptomatic women who are considered candidates for potential prevention and screening strategies for ovarian cancer. The model tracks a hypothetical cohort of 40-year-old women over their lifetimes and compares the impact of one of six strategies for the prevention of ovarian cancer on cancer incidence, mortality, and overall life expectancy.

Simulation model. Women enter the Markov model (Figure 3), which follows the women's natural history of ovarian cancer; the probabilities of each event can be modified based on different strategies for primary prevention, screening, or targeted treatment (see below). Each month women are at risk for developing ovarian cancer. Over time, the cancer could progress through the different stages of ovarian cancer; we assumed that death from ovarian cancer was always preceded by diagnosis. Women with cancer could be detected either through a screening program or through clinical symptoms and diagnosis. Once detected, women undergo a laparotomy, and those who survive undergo treatment for their cancer. Cancer survival is based on the stage at diagnosis.

Figure 3. Schematic representation of Markov model of ovarian cancer

Historically, cancer progression has been modeled as a serial progression through clinical stages - Stage I is followed by Stage II, Stage II is followed by Stage III, and Stage IV follows Stage III. This conceptual model has worked well with cervical cancer, but it is not clear that using this overall “model” for ovarian cancer is appropriate for the following reasons:

- The main purpose of cancer staging is to identify groups of patients who have similar prognosis; this allows comparability in comparing treatment results in both prospective and retrospective studies. Although the concept that stages also represent biological progression is attractive, it is not necessarily true, and, at least in the case of the ovarian cancer staging system of the International Federation of Obstetrics and Gynecology (FIGO), ^33^ plays no role in the development and validation of a staging system.
- Cervical cancer is, in many ways, unique among human cancers: it has a single cause (persistent infection with certain types of human papilloma virus); exposure to this cause in most people occurs within a relatively narrow time frame (roughly ages 15 to 25, the times of highest sexual activity with multiple partners); and the most common type of cancer is a squamous type, which primarily spreads through direct extension. In contrast, the cause or causes of ovarian cancer are unclear, duration of exposure is unclear, and, most importantly, the pattern of spread and metastases is quite different.
- By definition, Stage I ovarian cancer is limited to the ovary, Stage II involves the ovary and other organs in the pelvis, and Stage III, the most common stage at diagnosis, involves organs in the upper abdomen, including the large and small bowel, the omentum, the diaphragm, and other peritoneal surfaces. Peritoneal fluid constantly circulates, and it is not uncommon for loops of small bowel to come in contact with the ovary. In order for the “conceptual model” requiring an intervening Stage II prior to development of Stage III to be correct, one has to assume that cancer cells on the surface of the ovary must necessarily spread to the uterus or other pelvic organs before they can spread to areas in the upper abdomen via transport in peritoneal fluid or via direct contact with small bowel. We postulate that a scenario where a certain unknown proportion of ovarian cancers progress directly from Stage I to Stage III is at least as plausible a scenario.

Given this uncertainty about the clinical progression of ovarian cancer, we therefore modeled the progression under two alternative assumptions: (1) that ovarian cancer needs to progress from Stage I to Stage II before progressing to Stage III; and (2) that a proportion of ovarian cancer progresses directly from Stage I to Stage III. We evaluated how these two competing assumptions about the natural history of ovarian cancer affect the required stage progression and mortality rates and the estimated life expectancies of the alternative prevention strategies.

We assumed that women who have survived their detected cancer for 5 years are to be considered disease-free and to have mortality equal to that of the general population. Each month, a woman may also choose to have a benign oophorectomy, reducing her risk of ovarian cancer. Throughout their lifetimes, all women are at risk for age-specific mortality unrelated to ovarian cancer. We also included age-specific rates for bilateral oophorectomy, under the assumption that women without ovaries are not at risk for developing ovarian cancer; we did not specifically model the possibility of primary peritoneal carcinomatosis in these women.

Arrows in Figure 3 depict possible transitions between states. Note that one version of the model allows transition directly from Stage I (confined to the ovaries) to Stage III (metastases to the upper abdomen).

Data sources. We obtained age-specific estimates of ovarian cancer incidence, mortality, stage distribution, and survival from the National Cancer Institute's Surveillance, Epidemiology, and End Results (SEER) online database Cancer Query System (http://seer.cancer.gov/canques).

Estimates for other-cause mortality were obtained by subtracting age-specific ovarian cancer mortality from age-specific all-cause mortality for women, using U.S. lifetables available from the National Center for Health Statistics (www.cdc.gov/nchs/deaths.htm).

Estimates for age-specific oophorectomy rates were obtained from AHRQ's Nationwide Inpatient Sample, using ICD-9 codes for bilateral oophorectomy, bilateral salpingoophorectomy, or removal of remaining ovary or remaining tube and ovary (http://hcup.ahrq.gov/HCUPnet.asp).

Software. We constructed the model and performed all analyses using DATA Pro 2006 (Williamstown, MA: TreeAge Software, Inc).

Prevention strategies. We modeled six clinical strategies of prevention for ovarian cancer (Figure 4):

(1) The baseline strategy of no screening or prevention (NoScreen) where women are identified with ovarian cancer only through development of clinical symptoms.
(2) A primary prevention strategy (PrimaryPrevention) where women undertake a hypothetical method of primary prevention which reduces their incidence of ovarian cancer.
(3) An interval screening strategy (IntervalScreen) where women are screened at recurrent intervals for ovarian cancer using a hypothetical test. Women identified through screening could benefit from early treatment.
(4) A genetic screening strategy where women are tested for a specific genetic mutation and if positive undergo primary prevention for ovarian cancer (Genetic&PrimaryPrevention). The overall population risk for ovarian cancer is unchanged; we varied incidence in those with and without the putative mutation.
(5) A genetic screening strategy where women are tested for a specific genetic mutation and if positive they undergo screening for ovarian cancer at recurrent intervals (Genetic&IntervalScreen).
(6) A strategy where women once identified with ovarian cancer are tested for a hypothetical marker which allows targeted treatment for ovarian cancer (TargetTx). Women who are positive for the marker and undergo the targeted treatment experience greater survival.

Figure 4. Schematic representation of ovarian cancer prevention and treatment

Approach. Because the majority of the literature on genomic testing does not allow definitive conclusions about the relative effectiveness of different strategies using different tests, we adapted a “generic” approach to comparison of different strategies.

We chose as a goal a 20 percent reduction in ovarian cancer death, similar to the reductions targed for other cancers in the Healthy People 2010 objectives. With this target, we used the calibrated models to explore the following clinical questions:

(1) How effective would a primary prevention intervention need to be to reduce ovarian cancer deaths by 20 percent?
(2) What combinations of test sensitivity and frequency result in at least a 20 percent reduction in mortality?
(3) What combinations of (a) prevalence of a genetic mutation in the population and (b) relative risk associated with that mutation would result in the target 20 percent reduction in ovarian cancer deaths with either primary prevention (at various levels of effectiveness) or interval screening (at varying levels of sensitivity and frequency)?
(4) How effective would a targeted treatment for ovarian cancer need to be (and in what proportion of the patient population would the marker for that treatment need to exist)? Note that we assume that targeted therapy would be equally effective across all stages of disease.
(5) How do the test characteristics for targeted treatment or genetic screening affect the results?
(6) How do the above results differ under the assumption that cancer must progress from Stage I to II and then III versus that assumption that ovarian cancer may progress directly from Stage I to Stage III?
(7) What effect does the assumption about natural history have on the relative efficacy of screening?
(8) What is the impact of attributable risk proportion on the potential efficacy of genetic risk factors?

## Peer Review Process

We employed internal and external quality-monitoring checks through every phase of the study to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include: three progressively stricter screening opportunities for each article (abstract screening, full-text article review, data abstraction review); involvement of three individuals (two clinicians and copy-editor) in each data abstraction; and agreement of at least two clinicians on all included studies.

Our principal external quality-monitoring device is the peer-review process. Nominations for peer reviewers were solicited from several sources, including the technical expert panel and interested federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers submitting comments on this draft is provided in Appendix E.^*^