# Introduction

## Ovarian Cancer

Cancer of the ovaries is the leading cause of cancer death from gynecologic malignancies, with an annual incidence of over 25,000 and an annual mortality of approximately 14,000. ^1^ Cancer incidence increases dramatically with age, being relatively rare prior to age 50 (Figure 1).

Figure 1. U.S. ovarian cancer incidence by age, 1992-2003

Sources: Surveillance, Epidemiology, and End Results (SEER) Program ^2^ and United States Cancer Statistics (USCS). ^3^

Ovarian cancer incidence varies by race and ethnicity. Both incidence and mortality are highest for white women (Table 1).

Table 1 Age-adjusted annual incidence and mortality per 100,000 women by race and ethnicity, 1992-2002*

| White | African-American | Asian/Pacific Islander | Native American | Hispanic
Incidence
SEER | 15.1 | 10.3 | 10.4 | 8.9 | 11.9
USCS | 13.5 | 9.8 | 9.5 | 5.4 | 11.0
Mortality
SEER | 9.3 | 7.6 | 4.8 | 5.1 | 6.2
USCS | 9.4 | 7.4 | 5.1 | 4.9 | 6.0

* Sources: Surveillance, Epidemiology, and End Results (SEER) Program ^2^ and United States Cancer Statistics (USCS). ^3^

Malignant tumors of the ovary can either arise in the ovary (primary ovarian cancer) or be the result of metastasis from another site, such as the breast or colon. Primary ovarian tumors, whether benign or malignant, can arise from three broad types of cells: the cells on the surface (epithelial cells); the cells that form eggs (germ cells); and the cells surrounding the eggs, including the cells that produce ovarian hormones (sex cord-stromal cells). Epithelial tumors are the most common type, accounting for 60 percent of all ovarian tumors and up to 90 percent of primary cancers. Sex cord-stromal tumors account for 10 to 15 percent of all tumors, while germ cell tumors account for 25 percent of tumors. In general, sex cord-stromal tumors and germ cell tumors are relatively more common in younger premenopausal women. Thus, although ovarian cancer is relatively rare in younger women, when it does occur it is more likely to be a non-epithelial cancer than cancers in postmenopausal women. ^4^

Within the broad classification of epithelial, sex cord-stromal, and germ cell tumors, tumors are further classified by the individual cell types from which the tumor is derived. For example, the most common epithelial tumors are serous and mucinous tumors, the most common sex-cord stromal tumors are fibromas (arising from the connective tissue surrounding eggs), and the most common germ cell tumors are teratomas. Within each histological class, tumors can be benign or malignant, based on their ability to metastasize. ^4^

Some epithelial tumors are classified as “borderline” or “low malignant potential” (LMP) tumors. These are tumors in which there is no invasion into the ovarian stroma, but histologic evidence of proliferation (increased cell division, changes in the appearance of the cell nucleus). There is controversy over whether these tumors represent preinvasive cancer, and, if untreated, would go on to become a cancer, or whether they represent a subtype of tumor which has a relatively small chance of becoming a cancer. ^4^ In estimating the diagnostic accuracy of tests for determining whether a mass is benign or malignant, whether one classifies LMP tumors as benign or malignant can have an effect on the estimates of test performance, as we will discuss later in the report.

Ovarian cancer spreads primarily by dissemination throughout the peritoneal cavity; common sites of metastasis are the small and large bowel, the omentum, the liver, and the diaphragm. Spread to retroperitoneal lymph nodes is also common.

Treatment for ovarian cancer consists of surgical removal of the ovaries, fallopian tubes, and uterus (if present), along with as much metastatic disease as possible; if there is no obvious spread beyond the ovaries, the lymph nodes are sampled to determine if there has been lymphatic metastasis. Surgery is followed by chemotherapy, with responsiveness to chemotherapy depending on the amount of tumor left after surgical removal and the cell type of tumor, among other factors. ^4^

The high case-fatality rate observed in ovarian cancer has largely been attributed to the fact that most ovarian cancers are diagnosed in advanced stages (Stages III, where the cancer has spread beyond the pelvis to organs of the upper abdominal cavity, and IV, where the cancer has spread outside of the peritoneal cavity), when survival is poor. Stage I cancer (limited to the ovaries) has a survival rate of over 90 percent. Thus, there has long been a clinical and research emphasis on identifying methods for early detection of ovarian cancer, under the rationale that increasing the proportion of cancers detected in early stages will lead to decreases in morbidity and mortality.

## Approaches to Reducing Ovarian Cancer Morbidity and Mortality

Conceptually, there are five basic strategies for reducing ovarian cancer morbidity and mortality; we briefly review the rationale for each below.

### Primary Prevention in the Entire Population

Primary prevention can be achieved either through medical or surgical treatment which preserves the ovaries but reduces the incidence of ovarian cancer, or by removal of the ovaries themselves.

Although oral contraceptives and tubal ligation have consistently been associated with reduction in ovarian cancer in epidemiological studies, ^5^ the use of these measures as prophylaxis has never been prospectively tested in an adequately designed and powered trial; given the relative rarity of ovarian cancer, as well as the rarity of some of the serious side effects of oral contraceptives, such as an increased risk of deep vein thrombosis, such a trial may ultimately not be feasible.

Although primary peritoneal carcinomatosis, a condition which histologically and clinically is almost identical to ovarian cancer, ^6^ can occur after removal of the ovaries, it appears to be rare in average-risk women. ^7^ Bilateral oophorectomy in perimenopausal women undergoing hysterectomy for other causes has traditionally been recommended for prevention of ovarian cancer; however, this practice has also not been subjected to rigorous prospective study. A recent decision analysis suggests that, based on the available evidence, the potential harms from the other effects of oophorectomy may outweigh the benefits of ovarian cancer prevention. ^8^

### Primary Prevention in Women at Increased Risk for Developing Ovarian Cancer

This strategy depends on two things: the availability of a test for ascertainment of individuals at increased risk for developing ovarian cancer, and the availability of effective primary preventive treatment.

Although no randomized trials have been conducted, several observational studies suggest that women with an inherited predisposition to developing ovarian cancer who undergo prophylactic oophorectomy are at reduced risk of developing ovarian cancer compared to the expected incidence in this population. ^9^ – ^11^ Observational data also suggests that oral contraceptive use reduces ovarian cancer incidence in high-risk groups. ^12,^ ^13^

### Secondary Prevention through Screening

Unlike cervical cancer, where screening has proven remarkably effective, no screening test has proven effective in reducing ovarian cancer mortality. Physical examination using the bimanual pelvic examination, ^14^ serum testing using the tumor marker cancer antigen 125 (CA-125), and imaging using vaginal ultrasound ^15^ have all proven ineffective; the U.S. Preventive Services Task Force (USPSTF) gives a D recommendation to current methods for screening for ovarian cancer (at least fair evidence that the practice is ineffective or that harms exceed benefits). Additional studies are currently being conducted.

### Secondary Prevention through Screening in Women at High Risk

As with primary prevention, this strategy is dependent on both effective screening methods and the ability to accurately determine who is at “high risk.” Screening, including more frequent screening, has not resulted in a reduced ovarian cancer incidence, or a substantial shift in stage distribution of detected cancers, in high-risk groups. ^16^ – ^19^

### Improved Therapy after Diagnosis of Ovarian Cancer

Identification of women who are particularly likely to respond to specific therapies, or identification of new targets for therapy, could lead to improved survival and quality of life in women with ovarian cancer. Although there is much ongoing research into possible targets for therapy, ovarian cancer therapy lags behind therapy for breast cancer, where identification of particular molecular targets appears to be effective. ^20^ This category could also include tests that help distinguish particular types of ovarian cancer from other types, and to distinguish primary ovarian cancer from cancer metastatic to the ovary from other sites, since misclassification could lead to relatively less effective therapy.

## Genomic Tests

Advances in molecular biology, including the decoding of the human genome, have led to intensive research across the spectrum of human disease. The terms “genomics” or “genetic test” have been used differently in different settings. For the purposes of this report, we include the following types of tests based on the interests of the Agency for Healthcare Research and Quality (AHRQ), the Centers for Disease Control and Prevention (CDC), and the Evaluation of Genomics Applications in Practice and Prevention (EGAPP) program.

### Tests Measuring Single Gene Products

These tests measure the concentration or presence/absence of proteins which are associated with the presence of ovarian cancer. The classic example of this type of test is CA-125, a protein for which several validated, commercially available assays are available. Levels of CA-125 are increased in patients with ovarian cancer compared to normal subjects, and the test is useful in discriminating benign from malignant masses in postmenopausal patients. ^14^ Typically, these tests are for proteins detectable in serum, although, in some cases, tests may be peformed in fluid aspirated from an ovarian mass or the peritoneal cavity, or immunohistochemistry stains may be performed on ovarian or tumor tissue.

### Tests for Variations in DNA

Tests for inherited or acquired mutations (e.g., breast cancer genes 1 and 2 [BRCA1/2]) in single genes can potentially identify patients at higher risk for developing cancer. Alternatively, mutations in some genes in the cancer itself may indicate greater or lesser likelihood of responding to a given therapy, or of developing side effects with a given therapy. In addition, changes in the overall pattern of the genome, such as loss of heterozygosity, are characteristic of many cancers, and potentially have a role in diagnosis. ^21^ Finally, epigenetic changes (reversible changes to DNA and chromatin, such as the addition or subtraction of methyl groups), are currently under active investigation in a variety of cancers, including ovarian cancer. ^22^ – ^24^

### Gene Expression

Quantitative or semi-quantitive measurement of the expression (either higher or lower than normal) of particular genes in serum or tumor tissue has the potential for help in diagnosis (either as a screening tool or in discrminating particular subtypes of cancer), or potentially to aid in targeted therapy; for example, overexpression of human epidermal growth factor receptor 2 (HER-2) in breast cancer predicts responsiveness to therapy with an antibody against the receptor, trastuzimab. ^20^ Both single genes, and patterns of expression of multiple genes using technologies such as microarray, can be helpful. The introduction of high-throughput technology has facilitated the search for patterns of expression associated with specific outcomes, allowing simultaneous comparison of multiple genes in specimens from patients with and without the outcome. Studies of gene expression may also serve as the basis for identification of single gene products which can subsequently be evaluated as markers for screening, diagnosis, or management guidance.

### Proteomics/Protein Characterization

Finally, quantification of protein patterns, typically in serum, can be performed using mass spectroscopy; one of the more common techniques is surfance-enhanced laser desorption inonization time-of-flight (SELDI-TOF). ^25^ As with multiple gene expression, protein patterns can be compared between patients with and without a given outcome of interest, or used to identify single markers.

## Interest in Genomic Tests for Ovarian Cancer

Although there is widespread interest in genomic tests for prevention of morbidity and mortality for a wide range of conditions, ovarian cancer has been an area of particular interest on the part of the scientific community and lay public, largely because of the lack of an effective screening test. In particular, efforts to rapidly commercialize a proteomics-based test, OvaCheck™, prior to validation of the test in a large population, has led to a realization of the need for critical evaluation of the validity of these tests. ^26,^ ^27^

## Use of Genomic Tests in Prevention of Ovarian Cancer Morbidity and Mortality

Despite the broad definition of “genomic tests” used here, there are very few tests currently in clinical use for ovarian cancer (Table 2), based on a recent review of both the published and “grey” literature by the Tufts-New England Medical Center Evidence-based Practice Center. ^28^

Table 2 Current usage of genomic tests in ovarian cancer ^28^

Test | Type of test | Use of test
| | Increased risk | Screening | Diagnosis | Management
Commercially available
Routine use in ovarian cancer
Cancer antigen 125 (CA-125) | Single gene product | | | X | X
Beta human chorionic gonadotropin (β-hCG; germ cell tumors) | Single gene product | | | X | X
Breast cancer gene 1/2 (BRCA1/2) | Genetic variation | X
Carcinoembryonic antigen (CEA) | Single gene product | | | X
Investigational for ovarian cancer
Cancer antigen 27-29 (CA-27-29) | Single gene product | | X | X
Lipid-associated sialic acid (LASA) | Single gene product | | X | X
Human epidermal growth factor receptor 2 (HER2)/neu | Gene expression | | | | X
Investigational
Chromosome 8q gain | Genetic variation | | | | X
DNA methylation | Genetic variation | | X | X | X
Epidermal growth factor receptor (EGFR) | Single gene product | | X | X
Genome-wide loss of heterozygosity | Genetic variation | | X
Lysophospholipids (LSA) | Single gene product | | X | | X
Matrix metalloproteinases (MMP) | Single gene product | | X
Protein expression profiles (OvaCheck, etc.) | Protein expression | | X
Urinary plasminogen activator | Single gene product | | X

Because the majority of applications for genomic tests are investigational, there are few formal guidelines for their use, other than recommendations for the use of CA-125 as an adjunct to diagnosis of ovarian cancer, ^29^ against the use of CA-125 for routine screening for ovarian cancer, ^15,^ ^30^ and for the use of BRCA1 and 2 testing in women with family histories suggestive of familial breast or ovarian cancer. ^31^

Because the use of BRCA 1 and 2 testing for identifying women at high risk and the use of CA-125 for screening and as a diagnostic test in women with an adnexal mass have been recently covered by AHRQ evidence reports, ^14,^ ^30,^ ^31^ we have summarized the findings of these reports in the appropriate sections, incorporating any additional relevant evidence published subsequent to the reports.

In this review, and particularly in the discussion of the results and suggestions for future research, we will attempt to identify: (a) issues related to evaluation of specific strategies for ovarian cancer prevention; (b) issues related to evaluation of specific classes of “genomic tests;” and (c) where applicable, specific issues related to the evaluation of a given class of genomic test for a given prevention strategy.