# Appendix E: Peer Reviewers

The Duke Evidence-based Practice Center is grateful to the following peer reviewers who read and commented on a draft version of this report:

Ralph J. Coates, PhD, Associate Director for Science, Division of Cancer Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia

Tracy G. Lively, PhD, Associate Chief, Diagnostics Evaluation Branch, Cancer Diagnosis Program, National Cancer Institute, Rockville, Maryland

Edward E. Partridge, MD, Professor, Obstetrics and Gynecology, and Interim Director, UAB Comprehensive Cancer Center, Birmingham, Alabama

Gurvaneet Randhawa, MD, MPH, Center for Outcomes and Evidence, Agency for Healthcare Research and Quality, Rockville, Maryland

Edward (Ted) Trimble, MD, MPH, Head of Gynecologic Cancer Therapeutics and Quality of Cancer Care Therapeutics, National Cancer Institute, Rockville, Maryland

Combined comments from the Evaluation of Genomics Applications in Practice and Prevention (EGAPP)/Centers for Disease Control and Prevention (CDC) Discussion Group

Nominations for peer reviewers were solicited from several sources, including the project's technical expert panel and interested federal agencies. The list of nominees was vetted and approved by the Agency for Healthcare Research and Quality (AHRQ).