# Appendix D: Evidence Tables

Table 1 Evidence Table - Question 1: What is the evidence that ovarian cancer genomic tests performed in a typical clinical laboratory actually measure what they are purported to measure?

Study | Study Design | Description of Test(s) | Patient Characteristics | Results | | | | Comments/Quality Scoring
Benetkiewicz, Wang, Schaner, et al., 2005 | Geographical location: | Genomic test(s) used: | Age: NR, but referenced | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#8570 | Uppsala, Sweden; Oslo, Norway; Palo Alto, CA | Microarray of chromosome 22 | Race/ethnicity (n [%]): | Abnormalities detected in 12 of 18 tumors. | | | | - Cancers only; - Small sample
| Study dates: | Two methods used: DNA copy number counted, mRNA expression measured | All Norwegian | 21 frequently deleted genes with low mRNA expression, 12 amplified genes with elevated mRNA. | | | | Quality assessment:
| NR | Type(s) of samples: | Diagnoses (n [%]): | | | | | Reference standard: +
| Size of population: | Blood or tissue | Ovarian cancer: 18 (100%) | | | | | Verification bias: -
| 18 | Cyst fluid | Borderline: 0 | | | | | Test reliability/variability: -
| Type of laboratory: | Ascites | Benign ovarian mass: 0 | | | | | Sample size: -
| Hospital-based clinical samples | | Other: 0 | | | | | Statistical tests: -
| Research lab | | Healthy controls: 0 | | | | | Blinding: -
| | | Inclusion criteria: | | | | | Definition of +/- on screening test:+
| | | NR | | | | | Grade: B
| | | Exclusion criteria:
| | | NR
Brinkmann, Ryan, Ayhan, et al., 2004 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#1400 | London, UK; Belfast, Northern Ireland; Berlin, Germany | DNA: loss of heterozygosity, microsatellite instability | Race/ethnicity (n [%]): | Concordance between genetic and histo-pathologic diagnosis: | | | | - No linkage with clinical outcomes; - The poor agreement between pathologist opinion and genetic testing suggests that pathologists are not very good at detecting primary tumors with metastases vs. asynchronous primary tumors.
| Study dates: | Based on findings, odds that two tumors represented either single primary with metastasis or dual primary calculated. Classified as single primary if odds > 1, dual primary if odds < 1. | NR | Endometrial/ovarian: 42% | | | | Quality assessment:
| NR | Type(s) of samples: | Diagnoses (n [%]): | Bilateral ovarian: 67% | | | | Reference standard: +
| Size of population: | Blood or tissue | Ovarian cancer: 69 (100%); - 38 synchronous endometrial/ovarian; - 15 bilateral ovarian; - 9 synchronous endometrial/bilateral ovarian | | | | | Verification bias: -
| 62 | | Inclusion criteria: | | | | | Test reliability/variability: +
| Type of laboratory: | | Diagnosis of synchronous tumors | | | | | Sample size: -
| Hospital-based clinical samples | | Exclusion criteria: | | | | | Statistical tests:+
| Research lab | | NR | | | | | Blinding: -
| | | | | | | | Definition of +/- on screening test: -
| | | | | | | | Grade: C
Conrads, Fusaro, Ross, et al., 2004 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Low resolution spectrometer, cancer vs. healthy: | | | | Comments:
#1150 | Frederick and Bethesda, MD; Chicago, IL | Mass spectroscopy of protein expression using ProteinChip arrays; 1) High vs. low resolution spectrometers compared; 2) Candidate patterns determined using Proteome Quest software; algorithm combines elements of genetic algorithms and self-organizing adaptive pattern-recognition; 3) Candidates selected in training set evaluated in blinded training set; 4) Variances between assays compared to a reference standard | Race/ethnicity (n [%]): | | | | | - Full spectrum of clinical disease not reported; - Prevalence of disease 50% or greater - much higher than in screening or even most diagnostic situations; - Confidence intervals for sensitivity/specificity estimates not presented
| Study dates: | Type(s) of samples: | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | T+ | 103 | 0 | 103 | Reference standard: +
| Size of population: | | NR for entire study; for training set, 28 healthy, 49 cancer; two testing sets 37 healthy, 63 cancer; 37 healthy, 40 cancer | T- | 0 | 67 | 67 | Verification bias: +
| 248 | | Of total 103 cancer, 22 (20%) stage I | Tot | 103 | 67 | 170 | Test reliability/variability: + (reported, but low)
| Type of laboratory | | Inclusion criteria: | | | | | Sample size: -
| Hospital-based clinical samples | | NR | | | Lower | Upper | Statistical tests: +
| Research lab | | Exclusion criteria: | | Value | 95% CI | 95% CI | Blinding: +
| | | NR | Se | 100.0% | 97.1% | 100.0% | Definition of +/- on screening test: +
| | | | Sp | 100.0% | 95.5% | 100.0% | Grade: B
| | | | PPV | 100.0% | 97.1% | 100.0%
| | | | NPV | 100.0% | 95.5% | 100.0%
| | | | 2) High resolution spectrometer, cancer vs. healthy:
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 68 | 0 | 68
| | | | T- | 0 | 43 | 43
| | | | Tot | 68 | 43 | 111
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 95.6% | 100.0%
| | | | Sp | 100.0% | 93.0% | 100.0%
| | | | PPV | 100.0% | 95.6% | 100.0%
| | | | NPV | 100.0% | 93.0% | 100.0%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | “Comparisons...revealed that the variation in the mass spectra (overall amplitude, total record count and deviation in mean amplitudes) between ovarian cancer cases and control samples was statistically indistinguishable from the variance within the process itself, as indicated by the serum reference standard.”
Filella, Ballesta, Fox, et al., 1996 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#7620 | Barcelona, Spain; London, UK; Graz, Austria; Chambery, France | COBAS CORE automated immunoassay analyzer | Range: 17–89 for controls | Coefficent of variation: level 1 (mean 17.2) 3.8 to 6.1%, level 2 (mean 47.1) 2.8 to 6.4%, level 3 (mean 164.3) 1.8 to 4%. | | | | None
| Study dates: | Type(s) of samples: | Race/ethnicity (n [%]): | 97.5 percentile for CA-125 assay: 36.7; median 8.8. | | | | Quality assessment:
| NR | Blood or tissue | NR | CA-125 levels correlated with disease stage in ovarian cancer, show response to treatment. | | | | Reference standard: +
| Size of population: | | Diagnoses (n [%]): | | | | | Verification bias: -
| 239 normal, 167 cancers | | Ovarian cancer: 167 (41.1%) | | | | | Test reliability/variability:+
| Type of laboratory: | | Borderline: 0 | | | | | Sample size: +
| Clinical lab | | Benign ovarian mass: 0 | | | | | Statistical tests:+
| | | Other: 0 | | | | | Blinding: -
| | | Healthy controls: 239 (58.9%) | | | | | Definition of +/- on screening test:+
| | | Inclusion criteria: | | | | | Grade: B
| | | NR
| | | Exclusion criteria:
| | | NR
Hasholzner, Baumgartner, Steiber, et al., 1996 | Geographical location: | Genomic test(s) used: | Age: NR | 1) CA-125, 31 U/mL threshold, specificity fixed at for healthy controls; controls and benign masses vs. cancer: | | | | Comments:
#7520 | Munich, Germany | CA 72-4, CA-125 II using COBAS-CORE EIA kit | Race/ethnicity (n [%]): | | | | | - Prevalence of cancer in sample higher than in normal population
| Study dates: | Type(s) of samples: | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | T+ | 105 | 16 | 121 | Reference standard: +
| Size of population: | | Ovarian cancer: At time of primary diagnosis: 123 (28.9%); during follow-up: 236 (55.4%) | T- | 18 | 51 | 69 | Verification bias:-
| 426 | | Borderline: 0 | Tot | 123 | 67 | 190 | Test reliability/variability: +
| Type of laboratory: | | Benign ovarian mass: 37 (8.7%) | | | | | Sample size: -
| Clinical lab | | Other: 0 | | | Lower | Upper | Statistical tests: +
| Hospital-based specimens | | Healthy controls: 30 (7.0%) | | Value | 95% CI | 95% CI | Blinding: -
| | | Inclusion criteria: | Se | 85.0% | 78.7% | 91.3% | Definition of +/- on screening test: +
| | | NR | Sp | 76.8% | 66.7% | 86.9% | Grade: B
| | | Exclusion criteria: | PPV | 86.8% | 80.7% | 92.8%
| | | NR | NPV | 73.9% | 63.6% | 84.3%
| | | | 2) CA-72.4, threshold 2.9 U/mL, specificity fixed at 95% for healthy controls; healthy controls plus benign masses vs. cancer:
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 66 | 4 | 70
| | | | T- | 57 | 63 | 120
| | | | Tot | 123 | 67 | 190
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.0% | 45.2% | 62.8%
| | | | Sp | 94.5% | 89.0% | 100.0%
| | | | PPV | 94.3% | 88.8% | 99.7%
| | | | NPV | 52.5% | 43.6% | 61.4%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Intra-assay coefficient of variation:
| | | | CA 72.4: 3.5 to 4%
| | | | CA-125 II: 3.4%
| | | | Inter-assay coefficient of variation:
| | | | CA 72.4: 5 to 7.4%
| | | | CA-125 II: 8.4%
| | | | Correlation between markers:
| | | | -0.066 (controls)
| | | | 0.576 (serous ovarian cancer)
Heinzelmann-Schwarz, Gardiner-Garden, Henshall, et al., 2004 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#8650 | Randwick, Australia | Microarray and immunohistochemistry | 23 (20%) < 50 | In univariate analysis, no marker was significantly associated with either relapse-free survival or disease-specific survival. | | | | None
| Study dates: | 3 cell adhesion molecules identified | Race/ethnicity (n [%]): | Closest was CLDN3 (HR 0.63, 95% CI 0.4 to 1.0, p = 0.068). | | | | Quality assessment:
| NR | Type(s) of samples: | NR | Scoring of expression by 2 independent readers, discrepancies resolved by consensus. | | | | Reference standard: +
| Size of population: | Blood or tissue | Diagnoses (n [%]): | | | | | Verification bias: -
| 158 | | Ovarian cancer: 158 (100%) | | | | | Test reliability/variability: -
| Type of laboratory: | | Borderline: 0 | | | | | Sample size: -
| Hospital-based clinical samples | | Benign ovarian mass: 0 | | | | | Statistical tests: +
| Research lab | | Other: 0 | | | | | Blinding: -
| | | Healthy controls: 0 | | | | | Definition of +/- on screening test: +
| | | Inclusion criteria: | | | | | Grade: B
| | | NR
| | | Exclusion criteria:
| | | NR
Hellström, Raycraft, Hayden-Ledbetter, et al., 2003 | Geographical location: | Genomic test(s) used: | Age: NR | 1) HE4 for early stage cancer vs. normal at specificity of 96% (sensitivity of CA-125 71% at this level of specificity): | | | | Comments:
#2560 | Seattle, WA | HE4: Gene identified through microarray as overexpressed in ovarian cancer; monoclonal antibody and ELISA generated | Race/ethnicity (n [%]): | | | | | None
| Study dates: | Type(s) of samples: | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | T+ | 6 | 3 | 9 | Reference standard: +
| Size of population: | | Ovarian cancer: 37 (30.6%) | T- | 1 | 62 | 63 | Verification bias: -
| 121 | | Borderline: 0 | Tot | 7 | 65 | 72 | Test reliability/variability: +
| Type of laboratory: | | Benign ovarian mass: 19 (15.7%) | | | | | Sample size: -
| Research lab | | Other: 0 | | | Lower | Upper | Statistical tests: -
| | | Healthy controls: 65 (53.7%) | | Value | 95% CI | 95% CI | Blinding: -
| | | Inclusion criteria: | Se | 85.7% | 59.8% | 100.0% | Definition of +/- on screening test: +
| | | Stored sera at NCI | Sp | 95.4% | 90.3% | 100.0% | Grade: C
| | | Exclusion criteria: | PPV | 66.7% | 35.9% | 97.5%
| | | NR | NPV | 98.4% | 95.3% | 100.0%
| | | | 2) HE4 for late stage cancer vs normal at specificity of 96% (sensitivity of CA-125 at same specificity = 80%):
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 24 | 3 | 27
| | | | T- | 6 | 62 | 68
| | | | Tot | 30 | 65 | 95
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 80.0% | 65.7% | 94.3%
| | | | Sp | 95.4% | 90.3% | 100.0%
| | | | PPV | 88.9% | 77.0% | 100.0%
| | | | NPV | 91.2% | 84.4% | 97.9%
| | | | 3) HE4 for all cancer cases vs. all benign diseases at specificity of 96% (sensitivity of CA-125 at same specificity = 40%):
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 20 | 1 | 21
| | | | T- | 17 | 18 | 35
| | | | Tot | 37 | 19 | 56
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.1% | 38.0% | 70.1%
| | | | Sp | 94.7% | 84.7% | 100.0%
| | | | PPV | 95.2% | 86.1% | 100.0%
| | | | NPV | 51.4% | 34.9% | 68.0%
| | | | 4) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Sensitivity/specificity compared to CA-125 reported for fixed levels of specificity for each marker; in general, similar performance.
Hubl, Chan, Van Ingen, et al., 1999 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#5520 | Dresden, Göttingen, and Mannheim, Germany; Baltimore, MD; Tokai, Japan; Rotterdam, The Netherlands; Barcelona and Asturias, Spain; Creteil, France | Elecsys® CA-125 II Assay | Race/ethnicity (n [%]): | Low range (10 to 20 U/mL): | | | | None
| Study dates: | Type(s) of samples: | NR | Intra-assay CV: 1.0 to 3.0% | | | | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | Interassay CV: 3.0 to 10.9% | | | | Reference standard: +
| Size of population: | | Ovarian cancer: NR | Mid-range (40 U/mL): | | | | Verification bias: -
| NR (593 controls, N for other diseases not specified) | | Borderline: NR | Intra-assay CV: 0.8 to 4.6% | | | | Test reliability/variability: +
| Type of laboratory: | | Benign ovarian mass: NR | Interassay CV: 2.4 to 8.7% | | | | Sample size: -
| Clinical lab | | Other: 0 | Correlation with other immunoassays: 0.932 to 0.989 | | | | Statistical tests:+
| Hospital-based clinical samples | | Healthy controls: 593; % not calculable | 95 percentile for healthy subjects: 35 U/mL | | | | Blinding: -
| | | Inclusion criteria: | | | | | Definition of +/- on screening test: =
| | | NR | | | | | Grade: C
| | | Exclusion criteria:
| | | NR
Janatova, Pohlreich, and Matous, 2003 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#2410 | Prague, Czech Republic | Spreadex Polymer NAB (electrophoresis gels) | Race/ethnicity (n [%]): | Mutations detected using technique in subjects with known mutations; none in controls | | | | - Small sample size; - No formal measure of agreement
| Study dates: | Type(s) of samples: | NR | | | | | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | | | | | Reference standard: +
| Size of population: | | NR: 13 (50%) with known BrCA1/2 mutations, 13 controls | | | | | Verification bias:-
| 26 | | Inclusion criteria: | | | | | Test reliability/variability:+
| Type of laboratory: | | NR | | | | | Sample size: -
| Research lab | | Exclusion criteria: | | | | | Statistical tests: -
| | | NR | | | | | Blinding: -
| | | | | | | | Definition of +/- on screening test: -
| | | | | | | | Grade: C
Kenemans, Vestraeten, van Kamp, et al., 1995 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#8200 | Amsterdam, The Netherlands | 2^nd^ generation CA-125 | Race/ethnicity (n [%]): | Regression coefficients from 0.88 to 1.17. | | | | - High prevalence of cancer
| Study dates: | Centocor CA-125 II | NR | Centocor CA-125 II: intra-assay CV 5%, inter-assay CV 7%. | | | | Quality assessment:
| NR | BYK LIamat | Diagnoses (n [%]): | No differences in ROC curves. | | | | Reference standard: +
| Size of population: | Boehriner Mannheim | Ovarian cancer: 216 (51.8%) | | | | | Verification bias: -
| 417 samples, from 285 patients | (use mouse monoclonal antibody as capture) | Borderline: 0 | | | | | Test reliability/variability: -
| Type of laboratory: | Type(s) of samples: | Benign ovarian mass: 111 (26.6%) | | | | | Sample size: +
| Clinical lab | Blood or tissue | Other:; - Endometrial CA: 24 (5.8%); - Colon CA: 22 (5.3%); - Pregnant: 44 (10.6%) | | | | | Statistical tests: +
| Hospital-based clinical samples | | Healthy controls: 0 | | | | | Blinding: -
| | | Inclusion criteria: | | | | | Definition of +/- on screening test: +
| | | NR | | | | | Grade: B
| | | Exclusion criteria:
| | | NR
Li, Tang, Wu, et al., 2004 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Filter approach (all 3 datasets pooled): | | | | Comments:
#1160 | Tampa, FL | SELDI proteomics, analyzed using | Race/ethnicity (n [%]): | | | | | - Appropriate discussion of effect of low prevalence of ovarian cancer on PPV; estimation of test performance based on real-world prevalence; - Reporting of variability in results across methods, using same datasets
| Study dates: NR | - Filtered approach with statistical testing; - Wapper approach using genetic algorithms | NR | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Type(s) of samples: | Diagnoses (n [%]): | T+ | 337 | 32 | 369 | Reference standard: +
| 3 public access data bases: | Blood or tissue | Datasets I and II: | T- | 25 | 291 | 316 | Verification bias: +
| I: 216 | | Ovarian cancer: 100 (46.3%) | Tot | 362 | 323 | 685 | Test reliability/variability: +
| II: 216 | | Benign ovarian mass: 7.4% | | | | | Sample size: +
| III: 253 | | Healthy controls: 100 (46.3%) | | | Lower | Upper | Statistical tests: +
| Type of laboratory: | | Dataset III: | | Value | 95% CI | 95% CI | Blinding: +
| Research lab | | Ovarian cancer: 162 (64.0%) | Se | 93.1% | 90.5% | 95.7% | Definition of +/- on screening test: +
| | | Healthy controls: 91 (36.0%) | Sp | 90.1% | 86.8% | 93.4% | Grade: A
| | | Inclusion criteria: | PPV | 91.3% | 88.5% | 94.2%
| | | NR | NPV | 92.1% | 89.1% | 95.1%
| | | Exclusion criteria: | Individual datasets specificity ranged from 80.1 to 96.7%; estimated PPV based on prevalence of 0.05% ranged from 0.2 to 1.48%
| | | NR | 2) Genetic algorithm approach (all 3 datasets pooled):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 356 | 7 | 363
| | | | T- | 6 | 316 | 322
| | | | Tot | 362 | 323 | 685
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 98.3% | 97.0% | 99.7%
| | | | Sp | 97.8% | 96.2% | 99.4%
| | | | PPV | 98.1% | 96.7% | 99.5%
| | | | NPV | 98.1% | 96.7% | 99.6%
| | | | Individual data sets specificity ranged from 95.4 to 100%; estimated PPV based on prevalence of 0.05% ranged from 0.92 to 100%
Liu, 2006 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Support Vector Machine (SVM) - Linear kernel: | | | | Comments:
#12810 | Dallas, TX | Type(s) of samples: | Race/ethnicity (n [%]): | | | | | None
| Study dates: NR | Blood or tissue (reanalysis of data from Clinical Proteomic Program Databank) | NR | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | | Diagnoses (n [%]): | T+ | 160 | 7 | 167 | Reference standard: +
| 253 | | Ovarian cancer: 162 (64%) | T- | 2 | 84 | 86 | Verification bias: -
| Type of laboratory: | | Healthy controls: 91 (36%) | Tot | 162 | 91 | 253 | Test reliability/variability: -
| Research lab | | Inclusion criteria: | | | | | Sample size: -
| | | NR | | | Lower | Upper | Statistical tests: +
| | | Exclusion criteria: | | Value | 95% CI | 95% CI | Blinding:
| | | NR | Se | 99.0% | 97.5% | 100.0% | Definition of +/- on screening test:
| | | | Sp | 92.0% | 86.4% | 97.6% | Grade: B
| | | | PPV | 95.8% | 92.8% | 98.8%
| | | | NPV | 97.7% | 94.5% | 100.0%
| | | | 2) SVM - Polynomial kernel:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 162 | 19 | 181
| | | | T- | 0 | 72 | 72
| | | | Tot | 162 | 91 | 253
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 98.1% | 100.0%
| | | | Sp | 79.0% | 70.6% | 87.4%
| | | | PPV | 89.5% | 85.0% | 94.0%
| | | | NPV | 100.0% | 95.8% | 100.0%
| | | | 3) SVM - Radial kernel:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 162 | 91 | 253
| | | | T- | 0 | 0 | 0
| | | | Tot | 162 | 91 | 253
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 98.1% | 100.0%
| | | | Sp | 0.0% | 0.0% | 0.0%
| | | | PPV | 64.0% | 58.1% | 69.9%
| | | | NPV | - | - | -
Meinhold-Heerlein, Bauerschlag, Hilpert, et al., 2005 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#8710 | Kiel, Frieburg, Bonn, and Berlin, Germany; San Diego, CA | Microarray | Race/ethnicity (n [%]): | Sensitivity/specificity not reported; predictive model based on gene expression correctly discriminated between low malignant potential/grade 1 invasive vs. grade 2 or 3 invasive 54/57 (95%). | | | | - Survival data not available for all patients; - Survival not analyzed by microarray results
| Study dates: | Type(s) of samples: | NR | | | | | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | | | | | Reference standard: +
| Size of population: | | Ovarian cancer: 49 (86.0%) | | | | | Verification bias: -
| 57 | | Borderline: 8 (14.0%) | | | | | Test reliability/variability: +
| Type of laboratory: | | Benign ovarian mass: 0 | | | | | Sample size: -
| Hospital-based clinical samples | | Other: 0 | | | | | Statistical tests:-
| Research lab | | Healthy controls: 0 | | | | | Blinding: -
| | | Inclusion criteria: | | | | | Definition of +/- on screening test: +
| | | NR | | | | | Grade: C
| | | Exclusion criteria:
| | | NR
Mok, Chao, Skates, et al., 2001 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#4140 | Boston, MA; Charleston, SC | Microarray used to identify prostatin (secreted protein); antibody/ELISA developed | < 55: 102 (55.7%) | Correlation with CA-125 0.217 (p = 0.2) in nonmucinous cancers, -0.004 (p = -0.97) in controls; markers together had better sensitivity (92%) at specificity of 94% than either alone (CA-125 sensitivity 64.9%; prostatin 51.4% at 94% specificity). | | | | - Small sample size; - Enriched for ovarian cancer compared to population
| Study dates: | Type(s) of samples: | ≥ 55: 89 (44.3%) | | | | | Quality assessment:
| NR | Blood or tissue | Race/ethnicity (n [%]): | | | | | Reference standard:+
| Size of population: | | NR | | | | | Verification bias:-
| 201 | | Diagnoses (n [%]): | | | | | Test reliability/variability: +
| Type of laboratory: | | Ovarian cancer: 64 (31.8%) | | | | | Sample size: -
| Hospital-based clinical samples | | Borderline: 0 | | | | | Statistical tests:-
| Research lab | | Benign ovarian mass: 42 (20.9%) | | | | | Blinding: -
| | | Other (other GYN cancers): 24 (11.9%) | | | | | Definition of +/- on screening test: +
| | | Healthy controls: 71(35.3%) | | | | | Grade: B
| | | Inclusion criteria:
| | | NR
| | | Exclusion criteria:
| | | NR
Mor, Visintin, Lai, et al., 2005 | Geographical location: | Genomic test(s) used: | Age: | 1) Scoring rule based on leptin, prolactin, OPN, and IGF-II for diagnosis of ovarian cancer (cut points empirically derived): | | | | Comments:
#240 | New Haven, CT; Washington, DC; Las Vegas, NV | Microarray (cytokine rolling circle) | Mean ages of groups in validation set 58.4–63 years | | | | | - High prevalence of cancer
| Study dates: | EIA | Race/ethnicity (n [%]): | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Classification by Support vector machine k-nearest neighbors classification tree | NR | T+ | 96 | 6 | 102 | Reference standard: +
| Size of population: | Validation run 1000 times | Diagnoses (n [%]): | T- | 4 | 100 | 104 | Verification bias: +
| Validation set: 206 | Score based classification method also used | Ovarian cancer: 100 (48.5%) | Tot | 100 | 106 | 206 | Test reliability/variability: +
| Type of laboratory: | Markers selected: | Borderline: 0 | | | | | Sample size: -
| Hospital-based clinical samples | Leptin | Benign ovarian mass: 0 | | | Lower | Upper | Statistical tests: +
| Research lab | Prolactin | Other (family history): 40 (19.4%) | | Value | 95% CI | 95% CI | Blinding: +
| Commercial lab | OPN | Healthy controls: 66 (32.0%) | Se | 96.0% | 92.2% | 99.8% | Definition of +/- on screening test: +
| | IGF-II | Inclusion criteria: | Sp | 94.3% | 89.9% | 98.7% | Grade: B
| | Type(s) of samples: | NR | PPV | 94.1% | 89.6% | 98.7%
| | Blood or tissue | Exclusion criteria: | NPV | 96.2% | 92.5% | 99.8%
| | | NR
Petricoin, Ardekani, Hitt, et al., 2002 | Geographical location: | Genomic test(s) used: | Age: | 1) Cancer vs. benign disease, peak identified: | | | | Comments:
#3870 | Bethesda, MD; Houston, TX; Lawrenceville, NJ; Chicago, IL | Protein profiling using mass spectroscopy | Development set: | | | | | - Population well-characterized; - Prevalence of ovarian cancer much higher than in general population
| Study dates: | Patterns identified through genetic algorithm, closer analysis | Median: 49 | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Type(s) of samples: | Range: 21–75 | T+ | 50 | 3 | 53 | Reference standard: +
| Size of population: | Blood or tissue | Validation set: | T- | 0 | 63 | 63 | Verification bias: +
| 117 | | Median: 48 | Tot | 50 | 66 | 116 | Test reliability/variability: +
| Type of laboratory: | | Range: 25–73 | | | | | Sample size: +
| Hospital-based clinical samples | | Race/ethnicity (n [%]): | | | Lower | Upper | Statistical tests: +
| Research lab | | NR | | Value | 95% CI | 95% CI | Blinding: +
| | | Diagnoses (n [%]): | Se | 100.0% | 94.0% | 100.0% | Definition of +/- on screening test: +
| | | Development set: | Sp | 95.5% | 90.4% | 100.0% | Grade: A
| | | Ovarian cancer: 50 (50%) | PPV | 94.3% | 88.1% | 100.0%
| | | Borderline: 0 | NPV | 100.0% | 95.2% | 100.0%
| | | Benign ovarian mass: 13 (13%) | 2) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | Other: 0 | Coefficient of variation < 10% if specimens not frozen and thawed more than twice, and, once thawed, kept at 4°C for < 24 hours.
| | | Healthy controls: 37 (37%) | Sera from one unaffected, one Stage III cancer run 100 times; 100% concordance.
| | | Validation set:
| | | Ovarian cancer: 50 (43.1%)
| | | Borderline: 0
| | | Benign ovarian mass: 25 (21.6%)
| | | Other (non-gyn inflammatory disease): 7 (6.0%)
| | | Healthy controls: 24 (20.7%)
| | | Inclusion criteria:
| | | Controls: 5 years follow-up without cancer
| | | Exclusion criteria:
| | | NR
Rai, Zhang, Rosenzweig, et al., 2002 | Geographical location: | Genomic test(s) used: | Age: | 1) Logistic regression using 60, 79 kd peaks: | | | | Comments:
#3180 | Baltimore, MD; Fremont, CA | Protein profile using ProteinChip | Cancer cases: | | | | | - Very high prevalence of cancer relative to general population; - Reproduciblity not reported
| Study dates: | Patterns selected by classification and regression tree (CART) and unified maximum separability analysis (UMSA) | Median: 53 | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Type(s) of samples: | Range: 36–84 | T+ | 25 | 2 | 27 | Reference standard: +
| Size of population: | Blood or tissue | Controls: | T- | 17 | 36 | 53 | Verification bias: +
| 81 | | Median: 57 | Tot | 42 | 38 | 80 | Test reliability/variability: -
| Type of laboratory: | | Range: 45–75 | | | | | Sample size: + (confidence intervals reported)
| Hospital-based clinical samples | | Race/ethnicity (n [%]): | | | Lower | Upper | Statistical tests: +
| Research lab | | NR | | Value | 95% CI | 95% CI | Blinding: +
| | | Diagnoses (n [%]): | Se | 59.5% | 44.7% | 74.3% | Definition of +/- on screening test: +
| | | Ovarian cancer: 43 (53%) | Sp | 94.7% | 87.6% | 100.0% | Grade: B
| | | Borderline: 0 | PPV | 92.6% | 82.7% | 100.0%
| | | Benign ovarian mass: 0 | NPV | 67.9% | 55.4% | 80.5%
| | | Other (“nongynecologic diseases”): 38 (47%) | 2) Logistic regression model using biomarkers at 60, 79 kD plus CA-125 (>35 U/mL cutoff):
| | | Healthy controls: 0
| | | Inclusion criteria: | | Ref+ | Ref- | Tot
| | | NR | T+ | 30 | 2 | 32
| | | Exclusion criteria: | T- | 2 | 34 | 36
| | | NR | Tot | 32 | 36 | 68
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.8% | 85.4% | 100.0%
| | | | Sp | 94.4% | 86.9% | 100.0%
| | | | PPV | 93.8% | 85.4% | 100.0%
| | | | NPV | 94.4% | 87.0% | 100.0%
| | | | Sensitivity of CA-125 alone 65.6% (95% CI 49.2 to 82.1%), specificity 97.2% (91.9 to 100%).
Riisbro, Stephens, Brunner, et al., 2001 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#4190 | Copenhagen and Hvidovre, Denmark; Russelsheim, Germany | RIA for soluble urokinase plasminogen activator receptor | Median (range) for: | Interassay CV: 7.6% | | | | - High prevalence of malignancy
| Study dates: | Type(s) of samples: | Healthy controls: 36 (29–84) | Intra-assay CV: 4.6% | | | | Quality assessment:
| NR | Blood or tissue | Benign gyn disease: 50 (22–73) | Levels correlated with malignancy, stage of disease, but not significantly in multivariate analysis. | | | | Reference standard: +
| Size of population: | | Ovarian cancer: 63 (22–82) | | | | | Verification bias: +
| 129 | | Race/ethnicity (n [%]): | | | | | Test reliability/variability:+
| Type of laboratory: | | NR | | | | | Sample size: -
| Hospital-based clinical samples | | Diagnoses (n [%]): | | | | | Statistical tests:+
| Research lab | | Ovarian cancer: 53 (41.1%) | | | | | Blinding: +
| | | Borderline: 0 | | | | | Definition of +/- on screening test: +
| | | Benign ovarian mass: 17 (13.2%) | | | | | Grade: B
| | | Other (benign endometrial conditions): 28 (21.0%)
| | | Healthy controls: 31 (24.0%)
| | | Inclusion criteria:
| | | NR
| | | Exclusion criteria:
| | | NR
Sapi, Okpokwasili, and Rutherford, 2002 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#3630 | New Haven, CT | Telomerase activity in peripheral cells (blood or ascites) after methods to remove peripheral leukocytes | Race/ethnicity (n [%]): | Telomerase activity in 8/8 Stage IV, 7/20 Stage III, 0/30 controls (after purification). | | | | None
| Study dates: | Type(s) of samples: | NR | CA-125 levels higher in patients with positive telomerase. | | | | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | | | | | Reference standard: +
| Size of population: | Ascites | Ovarian cancer: 28 (48.3%) | | | | | Verification bias: -
| 58 | | Borderline: 0 | | | | | Test reliability/variability:+
| Type of laboratory: | | Benign ovarian mass: 0 | | | | | Sample size: -
| Research lab | | Other: 0 | | | | | Statistical tests:+
| Hospital-based clinical samples | | Healthy controls: 30 (51.7%) | | | | | Blinding: -
| | | Inclusion criteria: | | | | | Definition of +/- on screening test:+
| | | NR | | | | | Grade: B
| | | Exclusion criteria:
| | | NR
Sorace and Zahn, 2003 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#9210 | Baltimore, MD | Analysis of serum mass spectrometry data from Clinical Proteomics Program Databank | Race/ethnicity (n [%]): | Sensitivity/specificity 100% in training set with different rules, but varied in test sets. | | | | - Prevalence of cancer in sample higher than in normal population
| Study dates: NR | Training set of 45 spectra from 91 controls, 80 spectra from 162 cases | NR | Much of discrimination lies in low mass to charge (M/Z) region, which is problematic because of potential for experimental bias, technical issues. | | | | Quality assessment:
| Size of population: | Test set consisted of those not selected for training set | Diagnoses (n [%]): | | | | | Reference standard: +
| 253 | Two-sided Wilcoxon tests used to compare intensity between cancer, controls | Ovarian cancer: 162 (64%) | | | | | Verification bias:+
| Type of laboratory: | Varying decision rules applied to data | Controls: 91 (36%) | | | | | Test reliability/variability: +
| Research lab | Type(s) of samples: | Inclusion criteria: | | | | | Sample size: -
| | Blood or tissue | NR | | | | | Statistical tests: +
| | | Exclusion criteria: | | | | | Blinding: +
| | | NR | | | | | Definition of +/- on screening test: +
| | | | | | | | Grade: B
Tamakoshi, Kikkawa, Hasegawa, et al., 1995 | Geographical location: | Genomic test(s) used: | Age: NR | 1) CA-125 II: Ovarian cancer vs. benign and normal (other cancers not included): | | | | Comments:
#8210 | Nagoya, Japan | Centocore CA-125 II Assay | Race/ethnicity (n [%]): | | | | | None
| Study dates: | Type(s) of samples: | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Blood or tissue | Diagnoses (n [%]): | T+ | 53 | 13 | 66 | Reference standard: +
| Size of population: | | Ovarian cancer: 59 (39.6%) | T- | 6 | 66 | 72 | Verification bias: -
| NR (593 controls, N for other diseases not specified) | | Borderline: 0 | Tot | 59 | 79 | 138 | Test reliability/variability:- +
| Type of laboratory: | | Benign ovarian mass: 49 (30.9%) | | | | | Sample size: -
| Clinical lab | | Other:; - Endometrial ca: 10 (6.7%); - Cervical ca: 14 (9.4%) | | | Lower | Upper | Statistical tests:+
| Hospital-based clinical samples | | Healthy controls: 20 (13.4%) | | Value | 95% CI | 95% CI | Blinding: -
| | | Inclusion criteria: | Se | 89.8% | 82.1% | 97.5% | Definition of +/- on screening test: =
| | | NR | Sp | 83.5% | 75.4% | 91.7% | Grade: B
| | | Exclusion criteria: | PPV | 80.3% | 70.7% | 89.9%
| | | NR | NPV | 91.7% | 85.3% | 98.1%
| | | | 2) CA-125 I: Ovarian cancer vs. benign and normal (other cancers not included):
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 50 | 9 | 59
| | | | T- | 9 | 70 | 79
| | | | Tot | 59 | 79 | 138
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.7% | 75.6% | 93.9%
| | | | Sp | 88.6% | 81.6% | 95.6%
| | | | PPV | 84.7% | 75.6% | 93.9%
| | | | NPV | 88.6% | 81.6% | 95.6%
| | | | Difference in tests: more positives with CA-125 II in endometrial cyst (?endometriosis), fewer in non-serous cancers.
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Correlation coefficient: 0.86.
| | | | Coefficient of variation of CA-125 II smaller, especially at lower concentrations.
Thougaard, Hogdall, Kjaer, et al., 1998 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#6610 | Frederiksberg, Copenhagen, and Aarhus, Denmark | Three different antibody (2 monoclonal, 1 polyclonal) for tetranectin | Controls (women): | Coefficient of variation by level of tetranectin: | | | | None
| Study dates: NR | Type(s) of samples: | Median: 36 | Intra-assay | | | | Quality assessment:
| Size of population: | Blood or tissue | Range: 20–59 | | Hyb 130-13 | Hby 130–14 | A371 | Reference standard: +
| 153 (67 men) | | Cancer: | Low | 5.6% | | 2.9% | Verification bias: NA
| Type of laboratory: | | Median: 57.5 | | 7.5% | | | Test reliability/variability: +
| Research lab | | Range: 35–76 | Med | 3.3% | | 2.4% | Sample size: -
| | | Race/ethnicity (n [%]): | | 5.5% | | | Statistical tests: +
| | | NR | High | 3.2% | | 1.9% | Blinding: +
| | | Diagnoses (n [%]): | | 8.3% | | | Definition of +/- on screening test: NA
| | | Ovarian cancer: 43 (28% of total study pop; 50% of women) | | | | | Grade: A
| | | Borderline: 0 | Inter-assay
| | | Benign ovarian mass: 0 | | Hyb 130-13 | Hby 130-14 | A371
| | | Other: 0 | Low | 6.2% | 11.1% | 12.1%
| | | Healthy controls: 110 (67 men, 43 women) | Med | 4.9% | 8.3% | 5.4%
| | | Inclusion criteria: | High | 7.9% | 8.2% | 4.4%
| | | NR | Difference between assays 10% or less.
| | | Exclusion criteria: | Similar performance in ovarian cancer patients—with decreasing levels with increasing FIGO stage.
| | | NR
Tuxen, Soletormos, Peterson, et al., 2001 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#4200 | Copenhagen, Hillerod, and Odense, Denmark | CA-125, CEA, TPA | Median: 55 | CA-125 II - contribution of different components to imprecision: | | | | None
| Study dates: | 16 samples obtained over course of 1 year; 4 samples within 2–3 week time period × 4 | Range: 32–71 | Mean analytic imprecision: 7.8% | | | | Quality assessment:
| NR | Median interval between series 12 weeks (range 9–15 weeks) | Other (menopausal status): | Mean intraindividual variability: | | | | Reference standard: +
| Size of population: | Each sample run in duplicate, assays by same analyst | 11 (35.5%) premenopausal | Short term: 11.8% | | | | Verification bias: +
| 31 | Commercial kits used | 20 (64.5%) postmenopausal | Long term: 16.0% | | | | Test reliability/variability:+
| Type of laboratory: | Values transformed to natural logarithm | Race/ethnicity (n [%]): | Combined: 20% | | | | Sample size: -
| Clinical lab | Type(s) of samples: | NR | Change in reference value needed to be significant after accounting for imprecision: 50% | | | | Statistical tests: +
| | Blood or tissue | Diagnoses (n [%]): | Imprecision greatest in premenopausal women (69.5% compared to 35.7% in postmenopausal women), due to larger intra-individual biological variability. | | | | Blinding: +
| | | Ovarian cancer: 0 | CEA - change in reference value needed to be significant after accounting for imprecision: 44.8% | | | | Definition of +/- on screening test:+
| | | Borderline: 0 | TPA - change in reference value needed to be significant after accounting for imprecision: 67.9% | | | | Grade: A
| | | Benign ovarian mass: 0 | Differences by menopausal status not seen with CEA and TPA.
| | | Other: 0
| | | Healthy controls: 31 (100%)
| | | Inclusion criteria:
| | | NR
| | | Exclusion criteria:
| | | NR
Tuxen, Soletormos, Rustin, et al., 2000 | Geographical location: | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#4670 | Copenhagen and Hvidovre, Denmark; Middlesex, UK | Cobas Core CA-125 II | Median: 64 | Contribution to variability in values: | | | | None
| Study dates: | Collected from 3 months post-chemotherapy to 12 months before last clinical evaluation | Range: 24–75 | Analytic imprecison: 12% | | | | Quality assessment:
| Dec 1989–Apr 1994 | Natural logarithm transformed | Race/ethnicity (n [%]): | Intra-individual variation: 32.0% (24.0% after exclusion of one outlier) | | | | Reference standard: +
| Size of population: | Type(s) of samples: | NR | Inter-individual variation: 43.6% | | | | Verification bias: +
| 26 subjects (225 samples) | Blood or tissue | Diagnoses (n [%]): | Change in reference value needed to be significant after accounting for imprecision: 79.7% (62.6% after excluding one patient with outlier values). | | | | Test reliability/variability: +
| Type of laboratory: | | Ovarian cancer: 26 (100%) | | | | | Sample size: -
| Clinical lab | | Borderline: 0 | | | | | Statistical tests: +
| | | Benign ovarian mass: 0 | | | | | Blinding: +
| | | Other: 0 | | | | | Definition of +/- on screening test: +
| | | Healthy controls: 0 | | | | | Grade: A
| | | Inclusion criteria:
| | | No evidence of progression of disease using radiological or surgical follow-up
| | | Exclusion criteria:
| | | Early death
| | | Secondary cancer
| | | Treatment with monoclonal antibody
| | | Rising CA-125 levels
| | | Less than 5 available samples
| | | Continuously falling levels
van Ingen, Chan, Hubl, et al., 1998 | Geographical location | Genomic test(s) used: | Age: | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#6490 | Rotterdam,The Netherlands; Baltimore, MD; Dresden, Göttingen, and Mannheim, Germany; Isehara, Japan; Barcelona and Madrid, Spain; Creteil Cedex, France | Automated CA-125 II assay using Elecsys 2010 (Boehringer Mannheim) | NR: all greater than 18; of normal women, 49.4% postmenopausal | Intra-assay CVs: 0.8 to 3.3% | | | | - Population reasonably well-characterized; - Considerable detail provided on analytic validity in multiple clinical labs
| Study dates: NR | Type(s) of samples: | Race/ethnicity (n [%]): | Inter-assay CVs: 2.4 to 10.9% | | | | Quality assessment:
| Size of population: | Blood or tissue | NR | Correlations with other assays: 0.932 to 0.989 | | | | Reference standard: +
| 1879 | | Diagnoses (n [%]): | No interference observed with high levels of bilirubin, hemoglobin, or triglycerides. | | | | Verification bias: -
| Type of laboratory: | | Ovarian cancer: 150 (7.9%) | | | | | Test reliability/variability: +
| Clinical lab | | Benign ovarian mass: NR; 80 (4.2%) had benign gynecologic diseases, including cervical and endometrial conditions | | | | | Sample size: +
| Commercial lab | | Other:; - Benign disease (including non-gynecologic): 342 (18.2%); - Other cancers: 505 (26.9%) | | | | | Statistical tests: +
| | | Healthy controls:; - Women: 593 (31.6%); - Men: 289 (15.4%) | | | | | Blinding: NR
| | | Inclusion criteria: | | | | | Definition of +/- on screening test: +
| | | NR | | | | | Grade: A
| | | Exclusion criteria:
| | | NR
Wen, Bernstein, Lescallett, et al., 2000 | Geographical location: | Genomic test(s) used: | Age: NR, but referenced | 1) Microarray, mutation or no mutation: | | | | Comments:
#9830 | Los Angeles, CA | Microarray and gel-based DNA sequencing for p53 mutations | Race/ethnicity (n [%]): | | | | | - Direct comparison between microarray versus sequencing; discussion of mechanisms for differences presented
| Study dates: NR | Type(s) of samples: | NR, but ?referenced | | Ref+ | Ref- | Tot | Quality assessment:
| Size of population: | Blood or tissue | Diagnoses (n [%]): | T+ | 71 | 0 | 71 | Reference standard: +
| 108 | | Ovarian cancer: 108 (100%) | T- | 6 | 31 | 37 | Verification bias: -
| Type of laboratory: | | Borderline: 0 | Tot | 77 | 31 | 108 | Test reliability/variability: -
| Hospital-based clinical samples | | Benign ovarian mass: 0 | | | | | Sample size: -
| Research lab | | Other: 0 | | | Lower | Upper | Statistical tests: +
| | | Healthy controls: 0 | | Value | 95% CI | 95% CI | Blinding: +
| | | Inclusion criteria: | Se | 92.2% | 86.2% | 98.2% | Definition of +/- on screening test: +
| | | NR, but referenced | Sp | 100.0% | 90.3% | 100.0% | Grade: B
| | | Exclusion criteria: | PPV | 100.0% | 95.8% | 100.0%
| | | NR | NPV | 83.8% | 71.9% | 95.7%
| | | | 2) Conventional sequence analysis, mutation or no mutation:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 63 | 0 | 63
| | | | T- | 14 | 31 | 45
| | | | Tot | 77 | 31 | 108
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.8% | 73.2% | 90.4%
| | | | Sp | 100.0% | 90.3% | 100.0%
| | | | PPV | 100.0% | 95.2% | 100.0%
| | | | NPV | 68.9% | 55.4% | 82.4%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Mutations detected by both methods in 57 cancers, no mutations in 31, concordance 81%.
Wu, Abbott, Fishman, et al., 2003 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:; - High prevalence of ovarian cancer; - Small sample, multiple simulations
#2360 | New Haven, CT; Chicago, IL | Mass spectroscopy for protein profiles | Race/ethnicity (n [%]): | Error rate using random forest algorithm is lower, more stable compared to CART or linear discriminant analysis. | | | | Quality assessment:
| Study dates: | Several different methods for selecting variables compared:; 1) Random forest algorithm (bootstrap aggregation with random feature selection); 2) Classification trees (CART); 3) Linear discriminant analysis and quadratic discriminant analysis | NR | Other methods not stable using large number of variables. | | | | Reference standard:+
| NR | Type(s) of samples: | Diagnoses (n [%]): | | | | | Verification bias: +
| Size of population: | Blood or tissue | Ovarian cancer: 47 (51.6%) | | | | | Test reliability/variability: +
| 91 (2 specimens not used in final analysis) | | Borderline: 0 | | | | | Sample size: -
| Type of laboratory: | | Benign ovarian mass: 0 | | | | | Statistical tests: +
| Hospital-based clinical samples | | Other: 0 | | | | | Blinding: +
| Research lab | | Healthy controls: 44 (47.4%) | | | | | Definition of +/- on screening test: +
| | | Inclusion criteria: | | | | | Grade: B
| | | NR
| | | Exclusion criteria:
| | | NR
Yu, Ongarello, Fiedler, et al., 2005 | Geographical location | Genomic test(s) used: | Age: NR | 1) Cancer vs. control, based on classification results of described procedure: | | | | Comments:
#190 | Peking, China; Graz, Austria; Lawrence, Kansas | Mass spectrometry of proteins | Race/ethnicity (n [%]): | | | | | - Small sample, multiple simulations; - Prevalence of ovarian cancer very high
| Study dates: | 4 step statistical procedure:; 1) Binning, using CART; 2) Kolmogorov-Smirnov (KS)-test based feature selection (comparing distribution of values); 3) Restriction of coefficient of variation; 4) Wavelet transformation of data | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Type(s) of samples: | Diagnoses (n [%]): | T+ | 119 | 9 | 128 | Reference standard:+
| Size of population: | Blood or tissue | Ovarian cancer: 121 (56%) | T- | 2 | 86 | 88 | Verification bias: +
| 216 | | Borderline: 0 | Tot | 121 | 95 | 216 | Test reliability/variability: -
| Type of laboratory: | | Benign ovarian mass: 0 | | | | | Sample size: -
| Hospital-based clinical samples | | Other: 0 | | | Lower | Upper | Statistical tests: +
| Research lab | | Healthy controls: 95 (44%) | | Value | 95% CI | 95% CI | Blinding: +
| | | Inclusion criteria: | Se | 98.3% | 96.1% | 100.0% | Definition of +/- on screening test: +
| | | NR | Sp | 90.5% | 84.6% | 96.4% | Grade: B
| | | Exclusion criteria: | PPV | 93.0% | 88.5% | 97.4%
| | | NR | NPV | 97.7% | 94.6% | 100.0%
Yu, Zheng, Tang, et al., 2005 | Geographical location: | Genomic test(s) used: | Age: | 1) Results for test set (60 iterations, but only 6 cases): | | | | Comments:
#310 | Hangzhou, China | SELDI protein profiling | Cancer: | | | | | - Histologic type not described; - High prevalence of cancer in data set; - Only 6 subjects in each test set
| Study dates: | SVM classification used to identify candidates | Median: 57 | | Ref+ | Ref- | Tot | Quality assessment:
| NR | 90% of samples blinded training set, 10% test set; procedure repeated 10 times | Range: 14–68 | T+ | 29 | 1 | 30 | Reference standard: +
| Size of population: | Type(s) of samples: | Control: | T- | 1 | 29 | 30 | Verification bias: +
| 61 | Blood or tissue | “Age and sex matched” | Tot | 30 | 30 | 60 | Test reliability/variability: -
| Type of laboratory: | | Race/ethnicity (n [%]): | | | | | Sample size: -
| Hospital-based clinical samples | | NR | | | Lower | Upper | Statistical tests: +
| Research lab | | Diagnoses (n [%]): | | Value | 95% CI | 95% CI | Blinding: +
| | | Ovarian cancer: 31 (50.8%) | Se | 96.7% | 90.2% | 100.0% | Definition of +/- on screening test: -
| | | Borderline: 0 | Sp | 96.7% | 90.2% | 100.0% | Grade: C
| | | Benign ovarian mass: 0 | PPV | 96.7% | 90.2% | 100.0%
| | | Other: 0 | NPV | 96.7% | 90.2% | 100.0%
| | | Healthy controls: 29 (49.2%)
| | | Inclusion criteria:
| | | NR
| | | Exclusion criteria:
| | | NR
Zarrinkar, Mainquist, Zamora, et al., 2001 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.): | | | | Comments:
#9750 | San Diego and Santa Clara, CA | High-throughput microarray using parallel analysis | Race/ethnicity (n [%]): | Correlation between wafer vs. individual chips 0.980 (CAOV-3). Similar correlation (0.982) for a mixture of breast and prostate cell lines. | | | | - Few normals; - Tissue, not serum
| Study dates: | Results compared to single sample processing | NR | False positives 31 of approximately 6800 in ovarian cell line validation. | | | | Quality assessment:
| NR | Type(s) of samples: | Diagnoses (n [%]): | | | | | Reference standard: +
| Size of population: | Tissue | Ovarian cancer: 27 (87.1%) | | | | | Verification bias: -
| 31 patients | Cell lines | Borderline: 0 | | | | | Test reliability/variability: +
| Ovarian cancer, normal prostate, and fibroblast cell lines | | Benign ovarian mass: 0 | | | | | Sample size: -
| Type of laboratory: | | Other: 0 | | | | | Statistical tests: +
| Commercial lab | | Healthy controls: 4 (12.9%) | | | | | Blinding: -
| Hospital-based clinical samples | | Inclusion criteria: | | | | | Definition of +/- on screening test: +
| Research lab | | NR | | | | | Grade: B
| | | Exclusion criteria:
| | | NR
Zhang, Bast, Yu, et al., 2004 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Results of validation set, CA-125 alone, specificity fixed at 97% for healthy controls (disease - includes benign pelvic mass): | | | | Comments:
#790 | Baltimore, MD; Houston, Tex; Fremont, CA; Durham, NC; Randwick, Australia; Groningen, the Netherlands; London, UK | ProteinChip Biomarker System | Race/ethnicity (n [%]): | | | | | - High prevalence of ovarian cancer; - Population well-characterized
| Study dates: | Unified maximum separability analysis used to select peaks | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Identified proteins purified | Diagnoses (n [%]): | T+ | 106 | 42 | 148 | Reference standard: +
| Size of population: | Testing and validation sets used | Ovarian cancer: 167 (33.2%) | T- | 32 | 187 | 219 | Verification bias: -
| Development set: 503 | Type(s) of samples: | Borderline: 28 (2.8%) | Tot | 138 | 229 | 367 | Test reliability/variability: +
| Type of laboratory: | Blood or tissue | Benign ovarian mass: 166 (33.0%) | | | | | Sample size: +
| Hospital-based clinical samples | | Other: 0 | | | Lower | Upper | Statistical tests: +
| Research lab | | Healthy controls: 142 (28.2%) | | Value | 95% CI | 95% CI | Blinding: +
| | | Inclusion criteria: | Se | 76.8% | 69.8% | 83.9% | Definition of +/- on screening test: +
| | | NR | Sp | 81.7% | 76.6% | 86.7% | Grade: A
| | | Exclusion criteria: | PPV | 71.6% | 64.4% | 78.9%
| | | NR | NPV | 85.4% | 80.7% | 90.1%
| | | | 2) Results of validation set, logistic model with 3 biomarkers identified in study, specificity fixed at 97% for healthy controls (disease - includes benign pelvic mass):
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 107 | 82 | 189
| | | | T- | 31 | 147 | 178
| | | | Tot | 138 | 229 | 367
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.5% | 70.6% | 84.5%
| | | | Sp | 64.2% | 58.0% | 70.4%
| | | | PPV | 56.6% | 49.5% | 63.7%
| | | | NPV | 82.6% | 77.0% | 88.2%
| | | | 3) Results of validation set, logistic model with 3 biomarkers identified in study plus CA-125, specificity fixed at 97% for healthy controls (disease - includes benign pelvic mass):
| | | | | Ref+ | Ref- | Tot
| | | | T+ | 108 | 93 | 201
| | | | T- | 30 | 136 | 166
| | | | Tot | 138 | 229 | 367
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 78.3% | 71.4% | 85.1%
| | | | Sp | 59.4% | 53.0% | 65.7%
| | | | PPV | 53.7% | 46.8% | 60.6%
| | | | NPV | 81.9% | 76.1% | 87.8%
Zhu, Wang, Ma, et al., 2003 | Geographical location: | Genomic test(s) used: | Age: NR | 1) Validation set: | | | | Comments:
#2100 | Stony Brook and Upton, NY | Mass spectrometry (SELDI) from FDA/NCI database | Race/ethnicity (n [%]): | | | | | - High prevalence of cancer
| Study dates: | Random field selection of markers | NR | | Ref+ | Ref- | Tot | Quality assessment:
| NR | Type(s) of samples: | Diagnoses (n [%]): | T+ | 162 | 0 | 162 | Reference standard: +
| Size of population: | Blood or tissue | Test set: | T- | 0 | 91 | 91 | Verification bias: -
| Test set: 216 | | Ovarian cancer: 100 (46.3%) | Tot | 162 | 91 | 253 | Test reliability/variability: -
| Validation: 253 | | Borderline: 0 | | | | | Sample size: -
| Type of laboratory: | | Benign ovarian mass: 0 | | | Lower | Upper | Statistical tests: +
| Research lab | | Other: 0 | | Value | 95% CI | 95% CI | Blinding: +
| | | Healthy controls: 116 (53.7%) | Se | 100.0% | 98.1% | 100.0% | Definition of +/- on screening test: +
| | | Validation set: | Sp | 100.0% | 96.7% | 100.0% | Grade: B
| | | Ovarian cancer: 162 (64.0%) | PPV | 100.0% | 98.1% | 100.0%
| | | Borderline: 0 | NPV | 100.0% | 96.7% | 100.0%
| | | Benign ovarian mass: 0 | Using different training set to identify markers and 50 iterations, 50 perfect classifications, although best subset of markers differed between iterations.
| | | Other: 0
| | | Healthy controls: 91 (36.0%)
| | | Inclusion criteria:
| | | NR
| | | Exclusion criteria:
| | | NR

Table 2 Evidence Table - Question 2: What is the sensitivity and specificity of genomic tests in detecting ovarian cancer in asymptomatic and symptomatic women, including high-risk women?

Study | Study Design | Patients | Clinical Presentation | Results | | | | Comments/Quality Scoring
Abdel-Aleem, Ahmed, Sabra, et al., 1996 | Geographical location: | Age: | Screening only (n [%]): | 1) alpha-L-fucosidase = 275 U/mL for diagnosis of ovarian cancer (all women with tumors): | | | | Comments:
#7330 | Assiut, Egypt | Mean (SD): 46.9 ± 1.6 | NR | | | | | - Study uses healthy control comparison group
| Study dates: | Menopausal status (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Jun 1994–Dec 1995 | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 43 | 0 | 43 | Reference standard: +
| Size of population: | Race/ethnicity (n [%]): | Additional data used for diagnosis: | T- | 5 | 28 | 33 | Verification bias: -
| 151 total, including 101 patients (48 with ovarian carcinoma; 26 with epithelial ovarian cancer) and 50 healthy controls | NR | None | Tot | 48 | 28 | 76 | Test reliability/variability: -
| Type of population: | Risk factors (n [%]): | | | | | | Sample size: -
| Adnexal mass | Family history: 3 (6%) | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Genotype: NR | | | Value | 95% CI | 95% CI | Blinding: -
| Alpha-L-fucosidase | Diagnoses (n [%]): | | Se | 89.6% | 80.9% | 98.2% | Definition of +/- on screening test: +
| Reference standard: | Ovarian cancer: 48 (32%) | | Sp | 100.0% | 89.3% | 100.0% | Grade: B
| Surgical pathology | Benign ovarian mass: 28 (18.5%) | | PPV | 100.0% | 93.0% | 100.0%
| Reference standard applied to all test negatives?: | Healthy controls: 50 (33%) | | NPV | 84.8% | 72.6% | 97.1%
| Yes | Inclusion criteria:
| Test reliability established?: | - Women with genital tract tumors; - Controls: women admitted for genital prolapse or dysfunctional uterine bleeding | | 2) alpha-L-fucosidase = 275 U/mL for diagnosis of ovarian cancer (Dis- are healthy controls):
| 2 references to assay methods | Exclusion criteria:
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| Se, Sp, PPV, NPV | | | T+ | 43 | 1 | 44
| Blinding: No | | | T- | 5 | 49 | 54
| Definition of positive and negative on screening test: | | | Tot | 48 | 50 | 98
| ≤ 275 U/mL
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 89.6% | 80.9% | 98.2%
| | | | Sp | 98.0% | 94.1% | 100.0%
| | | | PPV | 97.7% | 93.3% | 100.0%
| | | | NPV | 90.7% | 83.0% | 98.5%
Baron, Boardman, Lafky, et al., 2005 | Geographical location: | Age: | Screening only (n [%]): | 1) sEGFR < 1000 fmol/mL for diagnosis of ovarian cancer vs. patients with benign ovarian neoplasms: | | | | Comments:
#450 | Multiple sites in U.S. | Ovarian cancer: | NR | | | | | None
| Study dates: | Median: 61 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| 1985-94 | Range: 24–87 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 141 | 86 | 227 | Reference standard: +
| Size of population: | Benign ovarian neoplasm: | Additional data used for diagnosis: | T- | 84 | 160 | 244 | Verification bias: +/-
| - Serum samples from 225 women with incident epithelial ovarian cancer; - 246 benign ovarian neoplasm; - 253 benign gynecologic condition | Median: 51 | NR | Tot | 225 | 246 | 471 | Test reliability/variability: +/-
| Type of population: | Range: 18–88 | | | | | | Sample size: +
| Screening | Benign gynecological conditions: | | | | Lower | Upper | Statistical tests: +
| Adnexal mass | Median: 42 | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | Range: 18–84 | | Se | 62.7% | 56.3% | 69.0% | Definition of +/- on screening test: +
| sEGFR/sErbB1 | Menopausal status | | Sp | 65.0% | 59.1% | 71.0% | Grade: B
| Reference standard: | (n [%]): | | PPV | 62.1% | 55.8% | 68.4%
| Surgical pathology | Ovarian cancer: | | NPV | 65.6% | 59.6% | 71.5%
| Reference standard applied to all test negatives?: | Pre (< 45): 35
| No | Post (> 55): 183 | | 2) sEGFR < 1000 fmol/mL OR CA-125 ≥ 50 U/mL for diagnosis of ovarian cancer vs. patients with benign ovarian neoplasms:
| Test reliability established?: | Indeterminate: 7
| Yes | Benign ovarian neoplasm: | | | Dis+ | Dis- | Tot
| Statistical tests used: | Pre (< 45): 108 | | T+ | 190 | 90 | 280
| Se, Sp | Post (> 55): 123 | | T- | 34 | 156 | 190
| Blinding: | Indeterminate: 15 | | Tot | 224 | 246 | 470
| No | Benign gynecological condition:
| Definition of positive and negative on screening test: | Pre (< 45): 187 | | | | Lower | Upper
| sEGFR < 1000 fmol/mL | Post (> 55): 53 | | | Value | 95% CI | 95% CI
| | Indeterminate: 13 | | Se | 84.8% | 80.1% | 89.5%
| | Race/ethnicity (n [%]): | | Sp | 63.4% | 57.4% | 69.4%
| | NR | | PPV | 67.9% | 62.4% | 73.3%
| | Risk factors (n [%]): | | NPV | 82.1% | 76.7% | 87.6%
| | NR
| | Diagnoses (n [%]): | | 3) sEGFR < 1000 fmol/mL AND CA-125 ≥ 50 U/mL for diagnosis of ovarian cancer vs. patients with benign ovarian neoplasms:
| | Ovarian cancer: 225
| | Benign ovarian mass: 246 | | | Dis+ | Dis- | Tot
| | Benign gynecologic condition: 253 | | T+ | 113 | 0 | 113
| | Inclusion criteria: | | T- | 109 | 246 | 355
| | - Incident EOC and serum sample in repository; - Controls having surgery at Mayo for benign ovarian neoplasm or other benign gynecologic condition | | Tot | 222 | 246 | 468
| | Exclusion criteria:
| | NR | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.9% | 44.3% | 57.5%
| | | | Sp | 100.0% | 98.8% | 100.0%
| | | | PPV | 100.0% | 97.3% | 100.0%
| | | | NPV | 69.3% | 64.5% | 74.1%
| | | | 4) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | “Interassay biological detection limit (4.5 SD above the zero calibrator) for the ALISA done in this study was 7.5 fmol/mL sEGFR.”
| | | | Not abstracted
| | | | 2×2 tables also reported for:
| | | | CA-125 ≥ 33 U/L
| | | | CA-125 ≥ 50 U/mL
| | | | CA-125 ≥ 135 U/mL
Baron, Cora, Lafky, et al., 2003 | Geographical location: | Age: NR | Screening only (n [%]): | 1) p110 sEGFR < 624 fmol/mL for diagnosis of EOC (all stages, all women): | | | | Comments:
#2960 | Multiple sites in U.S. (tissue banks) | Menopausal status (n [%]): | NR | | | | | - Healthy controls were younger, more often premenopausal than EOC cases; - Cut-off value changed for each analysis
| Study dates: | EOC cases: | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| 1985-2001; date ranges varied by site | Pre (< 45): 35 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 125 | 8 | 133 | Reference standard: +
| Size of population: | Post (> 55): 183 | Additional data used for diagnosis: | T- | 100 | 136 | 236 | Verification bias: -
| 144 healthy women | Healthy controls: | NR | Tot | 225 | 144 | 369 | Test reliability/variability: -
| 225 epithelial ovarian cancer (EOC) cases | Pre (< 45): 81 | | | | | | Sample size: +
| Type of population: | Post (> 55): 59 | | | | Lower | Upper | Statistical tests: +
| Known cancer cases and healthy controls | Race/ethnicity (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | NR | | Se | 55.6% | 49.1% | 62.0% | Definition of +/- on screening test: -
| sEGFR/sErbB1 | Risk factors (n [%]): | | Sp | 94.4% | 90.7% | 98.2% | Grade: B
| Reference standard: | NR | | PPV | 94.0% | 89.9% | 98.0%
| Surgical pathology | Diagnoses (n [%]): | | NPV | 57.6% | 51.3% | 63.9%
| Reference standard applied to all test negatives?: | Ovarian cancer: 225
| No | Healthy controls: 144 | | 2) p110 sEGFR < 1185 fmol/mL for diagnosis of EOC (all stages, premenopausal women):
| Test reliability established?: | Inclusion criteria:
| No | Serum in tissue bank collected from women within 30 days of primary cytoreductive surgery for EOC | | | Dis+ | Dis- | Tot
| Statistical tests used: | Exclusion criteria: | | T+ | 26 | 5 | 31
| Se, Sp, ROC, regression modelling | Previous cytoreductive surgery, radiation, or chemotherapy | | T- | 9 | 76 | 85
| Blinding: No | | | Tot | 35 | 81 | 116
| Definition of positive and negative on screening test:
| Cut-off is 95% lower limit in healthy women for each group (not fixed) | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 74.3% | 59.8% | 88.8%
| | | | Sp | 93.8% | 88.6% | 99.1%
| | | | PPV | 83.9% | 70.9% | 96.8%
| | | | NPV | 89.4% | 82.9% | 96.0%
| | | | Additional tables reported for D+ = Stage I/II or Stage III/IV and for postmenopausal women, women ages 20–40, ages 41–60 and ages 61–87 years.
Berek, Chung, Kaldi, et al., 1991 | Geographical location: | Age: NR | Screening only (n [%]): | 1) Elevated IL-6 for diagnosis of macroscopic EOC (microscopic EOC and control patients = Dis-): | | | | Comments:
#12230 | Los Angeles, CA | Menopausal status (n [%]): | 0 | | | | | None
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 16 | 4 | 20 | Reference standard: +
| 36 women with EOC | NR | Additional data used for diagnosis: | T- | 5 | 23 | 28 | Verification bias: +/-
| 12 controls | Risk factors (n [%]): | NR | Tot | 21 | 27 | 48 | Test reliability/variability: +/-
| Type of population: | NR | | | | | | Sample size: -
| Adnexal mass | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: -
| Histologically proven cancer | Ovarian cancer: 36 | | | Value | 95% CI | 95% CI | Blinding: +
| Genomic test(s) used: | Healthy controls: 12 | | Se | 76.2% | 58.0% | 94.4% | Definition of +/- on screening test: -
| IL-6 | Inclusion criteria: | | Sp | 85.2% | 71.8% | 98.6% | Grade: C
| CA-125 | Histologically documented epithelial ovarian cancer | | PPV | 80.0% | 62.5% | 97.5%
| Reference standard: | Exclusion criteria: | | NPV | 82.1% | 68.0% | 96.3%
| Surgical pathology | NR
| Reference standard applied to all test negatives?: | | | 2) Elevated IL-6 for diagnosis of EOC (microscopic or macroscopic EOC = Dis+ and control patients = Dis-):
| Yes
| Test reliability established?: | | | | Dis+ | Dis- | Tot
| Yes (references) | | | T+ | 18 | 2 | 20
| Statistical tests used: | | | T- | 18 | 10 | 28
| Se | | | Tot | 36 | 12 | 48
| Blinding: Yes
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| “On the basis of IL-6 value of 0.12 ± 0.03 in healthy adult women.” Threshold used is unclear. | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 33.7% | 66.3%
| | | | Sp | 83.3% | 62.2% | 100.0%
| | | | PPV | 90.0% | 76.9% | 100.0%
| | | | NPV | 35.7% | 18.0% | 53.5%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Interassay variation 20%.
| | | | Correlation of serum IL-6 levels and CA-125 levels in pts with EOC = 0.84.
Bon, Verheijen, Zueten-horst, et al., 1996 | Geographical location: | Age: | Screening only (n [%]): | 1) CA > 14 U/mL for diagnosis of ovarian cancer (vs. benign ovarian tumors): | | | | Comments:
#7470 | Amsterdam, The Netherlands | Median: 45–49 | 962 (86.8%); used only to define cut-off value | | | | | - Prevalence of cancer high in diagnostic population
| Study dates: NR | Menopausal status (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Controls n = 962 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 29 | 0 | 29 | Reference standard: +/-
| 76 malignant ovarian tumor | Pre (< 45): 279 | Additional data used for diagnosis: | T- | 47 | 70 | 117 | Verification bias: -
| 70 benign ovarian tumor | Peri (45–55): 503 | NR | Tot | 76 | 70 | 146 | Test reliability/variability: -
| 962 healthy controls | Post (> 55): 180 | | | | | | Sample size: +
| Type of population: | Race/ethnicity (n [%]): | | | | Lower | Upper | Statistical tests: +
| Screening | NR | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | Risk factors (n [%]): | | Se | 38.2% | 27.2% | 49.1% | Definition of +/- on screening test: +/-
| Mucin-like Carcinoma-associated antigen | NR | | Sp | 100.0% | 95.7% | 100.0% | Grade: B
| Reference standard: | Diagnoses (n [%]): | | PPV | 100.0% | 89.7% | 100.0%
| Surgical pathology | Ovarian cancer: 76 | | NPV | 59.8% | 50.9% | 68.7%
| Reference standard applied to all test negatives?: | Benign ovarian mass: 70
| No | Healthy controls: 962 | | 2) CA-125 > 35 U/mL for diagnosis of ovarian cancer (vs. benign ovarian tumors):
| Test reliability established?: | Inclusion criteria:
| NR | - Controls - asymptomatic volunteers participating in a screening study for early detection of ovarian cancer; - Known benign ovarian tumor or ovarian carcinoma | | | Dis+ | Dis- | Tot
| Statistical tests used: | Exclusion criteria: | | T+ | 61 | 54 | 115
| ROC. Se, Sp | Abnormal pelvic exam | | T- | 15 | 16 | 31
| Blinding: NR | | | Tot | 76 | 70 | 146
| Definition of positive and negative on screening test:
| 14 U/mL, based on | | | | | Lower | Upper
| 95% in healthy controls of 19.2 U/mL | | | | Value | 95% CI | 95% CI
| | | | Se | 80.3% | 71.4% | 89.2%
| | | | Sp | 23.2% | 13.3% | 33.1%
| | | | PPV | 53.0% | 43.9% | 62.2%
| | | | NPV | 51.6% | 34.0% | 69.2%
Chang, Lee, Goodman, et al., 2002 | Geographical location: | Age: NR | Screening only (n [%]): | 1) Allelic imbalance for diagnosis of ovarian cancer: | | | | Comments:
#3230 | Baltimore, MD | Menopausal status (n [%]): | NR | | | | | - This study included patients with a wide range of neoplasm, but ovarian was the largest group and it reported data on ovarian subgroup separately.
| Study dates: NR (tumor bank) | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 50 | 0 | 50 | Reference standard: +
| 54 ovarian tumor | NR | Additional data used for diagnosis: | T- | 4 | 31 | 35 | Verification bias: -
| Type of population: | Risk factors (n [%]): | NR | Tot | 54 | 31 | 85 | Test reliability/variability: -
| Adnexal mass | NR | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: -
| Allelic Imbalance (AI) | Ovarian cancer: 41 | | | Value | 95% CI | 95% CI | Blinding: -
| Plasma DNA levels | Borderline: 6 | | Se | 92.6% | 85.6% | 99.6% | Definition of +/- on screening test: -
| CA-125 | Other: 3 | | Sp | 100.0% | 90.3% | 100.0% | Grade: C
| Reference standard: | - 3 endometrioid | | PPV | 100.0% | 94.0% | 100.0%
| Surgical pathology | - 2 clear cell | | NPV | 88.6% | 78.0% | 99.1%
| Reference standard applied to all test negatives?: | - 1 granulosa cell
| No | - 1 immature teratoma | | 2) Plasma DNA concentration for diagnosis of ovarian cancer (cut off set to achieve 100% specificity):
| Test reliability established?: | Healthy controls: 44
| No | 164 patients with non-neoplastic diseases | | | Dis+ | Dis- | Tot
| Statistical tests used: | Inclusion criteria: | | T+ | 29 | 0 | 29
| ROC curves, logistic regression models | Sample in tumor bank | | T- | 25 | 31 | 56
| Blinding: No | Exclusion criteria: | | Tot | 54 | 31 | 85
| Definition of positive and negative on screening test: | None specified
| No | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.0% | 40.7% | 67.3%
| | | | Sp | 100.0% | 90.3% | 100.0%
| | | | PPV | 100.0% | 89.7% | 100.0%
| | | | NPV | 55.4% | 42.3% | 68.4%
| | | | 3) CA-125 > 35 U/mL for diagnosis of ovarian cancer:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 30 | 2 | 32
| | | | T- | 15 | 16 | 31
| | | | Tot | 45 | 18 | 63
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 67.0% | 53.3% | 80.7%
| | | | Sp | 89.0% | 74.5% | 100.0%
| | | | PPV | 93.8% | 85.4% | 100.0%
| | | | NPV | 51.6% | 34.0% | 69.2%
Cherchi, Capobianco, Ambrosini, et al., 2002 | Geographical location: | Age: NR | Screening only (n [%]): | 1) CA-125 (serum) > 35 IU/mL for diagnosis of ovarian cancer (vs. benign ovarian tumor or functional ovarian cyst): | | | | Comments:
#3780 | Sassari, Italy | Menopausal status (n [%]): NR | NR | | | | | None
| Study dates: NR | Race/ethnicity (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 16 | 4 | 20 | Reference standard: +
| 44 women benign | Risk factors (n [%]): | Additional data used for diagnosis: | T- | 4 | 40 | 44 | Verification bias: +
| 20 women malignant | NR | NR | Tot | 20 | 44 | 64 | Test reliability/variability: -
| Type of population: | Diagnoses (n [%]): | | | | | | Sample size: -
| Adnexal mass | NR | | | | Lower | Upper | Statistical tests: -
| Genomic test(s) used: | Inclusion criteria: | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Cystic ovarian tumors | | Se | 80.0% | 62.5% | 97.5% | Definition of +/- on screening test: +
| CA-19.9 | Exclusion criteria: | | Sp | 90.9% | 82.4% | 99.4%
| CEA | NR | | PPV | 80.0% | 62.5% | 97.5% | Grade: C
| TPA | | | NPV | 90.9% | 82.4% | 99.4%
| CA-15.3
| Reference standard: | | | 2) CA 15.3 (serum) > 30 IU/mL for diagnosis of ovarian cancer (vs. benign ovarian tumor or functional ovarian cyst):
| Surgical pathology
| Reference standard applied to all test negatives?: | | | | Dis+ | Dis- | Tot
| Yes | | | T+ | 10 | 6 | 16
| Test reliability established?: | | | T- | 10 | 38 | 48
| Referenced | | | Tot | 20 | 44 | 64
| Statistical tests used:
| Se | | | | | Lower | Upper
| Blinding: No | | | | Value | 95% CI | 95% CI
| Definition of positive and negative on screening test: | | | Se | 50.0% | 28.1% | 71.9%
| Yes, provided (see Results) | | | Sp | 86.4% | 76.2% | 96.5%
| | | | PPV | 62.5% | 38.8% | 86.2%
| | | | NPV | 79.2% | 67.7% | 90.7%
| | | | 3) TPA (serum) > 70 IU/mL for diagnosis of ovarian cancer (vs. benign ovarian tumor or functional ovarian cyst):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 10 | 8 | 18
| | | | T- | 10 | 36 | 46
| | | | Tot | 20 | 44 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 28.1% | 71.9%
| | | | Sp | 81.8% | 70.4% | 93.2%
| | | | PPV | 55.6% | 32.6% | 78.5%
| | | | NPV | 78.3% | 66.3% | 90.2%
| | | | 4) CA 19.9 (serum) > 35 IU/mL for diagnosis of ovarian cancer (vs. benign ovarian tumor or functional ovarian cyst):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 2 | 15
| | | | T- | 7 | 42 | 49
| | | | Tot | 20 | 44 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 65.0% | 44.1% | 85.9%
| | | | Sp | 95.5% | 89.3% | 100.0%
| | | | PPV | 86.7% | 69.5% | 100.0%
| | | | NPV | 85.7% | 75.9% | 95.5%
| | | | 5) CEA (serum) > 5 ng/mL for diagnosis of ovarian cancer (vs. benign ovarian tumor or functional ovarian cyst):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 0 | 8
| | | | T- | 12 | 44 | 56
| | | | Tot | 20 | 44 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 40.0% | 18.5% | 61.5%
| | | | Sp | 100.0% | 93.2% | 100.0%
| | | | PPV | 100.0% | 62.5% | 100.0%
| | | | NPV | 78.6% | 67.8% | 89.3%
| | | | Data also reported for same markers in intracyst fluid.
Cooper, Ritchie, Brog-hammer, et al., 2002 | Geographical location: | Age: | Screening only (n [%]): | 1) VEGF > 246 pg/mL for diagnosis of invasive cancer (vs. LMP tumors or benign disease): | | | | Comments:
#3360 | Iowa City, IA | Ovarian cancer: | NR | | | | | None
| Study dates: | Mean (SD): 64 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| 1995-2000 | Range: 20–78 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 75 | 16 | 91 | Reference standard: +
| Size of population: | Menopausal status (n [%]): | Additional data used for diagnosis: | T- | 26 | 34 | 60 | Verification bias: +
| 151 | NR | NR | Tot | 101 | 50 | 151 | Test reliability/variability: -
| Type of population: | Race/ethnicity (n [%]): | | | | | | Sample size: +
| Adnexal mass | NR | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Risk factors (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Serum VEGF | NR | | Se | 74.0% | 65.4% | 82.6% | Definition of +/- on screening test: -
| Reference standard: | Diagnoses (n [%]): | | Sp | 68.0% | 55.1% | 80.9% | Grade: B
| Surgical pathology | Ovarian cancer: 81 | | PPV | 82.4% | 74.6% | 90.2%
| Reference standard applied to all test negatives?: | Borderline: 16 | | NPV | 56.7% | 44.1% | 69.2%
| Yes | Benign ovarian mass: 34
| Test reliability established?: | Other: | | Additional data reported for CA-125 but 2×2 tables could not be determined:
| Commercial test Quantikine HVEGF, R&D Systems, no references provided | - 13 peritoneal cancer; - 7 fallopian tube cancer | | Se 93%
| Statistical tests used: | Inclusion criteria: | | Sp 71%
| ROC | Treated on gynecologic oncology service with preoperative serum samples available | | PPV 93%
| Blinding: No | Exclusion criteria: | | NPV 68%
| Definition of positive and negative on screening test: | None specified
| No
Czekier-dowski, 2002 | Geographical location: | Age: | Screening only (n [%]): | 1) VEGF > 350 pg/mL for diagnosis of ovarian cancer: | | | | Comments:
#3020 | Lublin, Poland | Mean (SD): 38 | 100 % | | | | | - Menopausal status different between cancers and benign masses
| Study dates: | Median: 39 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| 1994-99 | Range: 13–76 | - Symptomatic (n [%]): 0; - Asymptomatic, detected by exam (n [%]): 0; - Asymptomatic, detected by imaging (n [%]): 100% | T+ | 13 | 42 | 55 | Reference standard: +
| Size of population: | Menopausal status (n [%]): | Additional data used for diagnosis: | T- | 9 | 52 | 61 | Verification bias: -
| 451 women with persistent adnexal mass from among 4876 women screened with TVUS | Post (> 55): 88 (19.5%) (47% of cancers) | NR | Tot | 22 | 94 | 116 | Test reliability/variability: -
| Type of population: | Race/ethnicity (n [%]): | | | | | | Sample size: +
| Screening | NR | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Risk factors (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| VEGF (also measured CA-19.9; CA-72.4; CA-125) | NR | | Se | 59.1% | 38.5% | 79.6% | Definition of +/- on screening test: -
| Reference standard: | Diagnoses (n [%]): | | Sp | 55.3% | 45.3% | 65.4% | Grade: B
| Surgical pathology | Ovarian cancer: 47 | | PPV | 23.6% | 12.4% | 34.9%
| Reference standard applied to all test negatives?: | Benign ovarian mass: 404 | | NPV | 85.2% | 76.3% | 94.1%
| No | Inclusion criteria:
| Test reliability established?: | Adnexal mass on screening TVUS | | 2×2 provided for 6 other cut-offs including 100, 150, 200, 300, 450 and 600 pg/mL.
| No | Exclusion criteria: | | AUC = 0.5895 (95% CI, 0.4505 to 0.7285).
| Statistical tests used: | NR | | 2) Logistic regression including Doppler US and tumor markers:
| ROC, LR
| Blinding: No | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | | | T+ | 16 | 8 | 24
| No, 350 pg/mL was optimal cut-off | | | T- | 6 | 86 | 92
| | | | Tot | 22 | 94 | 116
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 72.0% | 53.2% | 90.8%
| | | | Sp | 91.9% | 86.4% | 97.4%
| | | | PPV | 66.7% | 47.8% | 85.5%
| | | | NPV | 93.5% | 88.4% | 98.5%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.)
| | | | VGEF: Sensitivity of the assay was 9 pg/mL. Inter-assay variability was less than 10%.
Darai, Bringuier, Walker-Combrouze, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) sE-cadherin >10,000 ng/mL for diagnosis of ovarian cancer (vs. benign cystadenomas and luteal cysts): | | | | Comments:
#6520 | Paris, France | Range: 18–75 | NR | | | | | None
| Study dates: | Menopausal status (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Sep 95 – Apr 96 | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 11 | 0 | 11 | Reference standard: +
| Size of population: | | Additional data used for diagnosis: | T- | 5 | 52 | 57 | Verification bias: -
| 77 women | Race/ethnicity (n [%]): | NR | Tot | 16 | 52 | 68 | Test reliability/variability: +
| Type of population: | NR | | | | | | Sample size: -
| Adnexal mass | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Blinding: -
| sICAM-1 | Diagnoses (n [%]): | | Se | 68.8% | 46.0% | 91.5% | Definition of +/- on screening test: -
| sCD44std | Ovarian cancer: 11 | | Sp | 100.0% | 94.2% | 100.0% | Grade: C
| sE-cadherin | Borderline: 5 | | PPV | 100.0% | 72.7% | 100.0%
| Reference standard: | Benign ovarian mass: | | NPV | 91.2% | 83.9% | 98.6%
| Surgical pathology | Other: 61
| Reference standard applied to all test negatives?: | - 23 luteal cyst; - 9 dermoid cysts; - 29 cystadenoma | | No 2×2 data for sICAM-1 or sCD44std
| Yes | Inclusion criteria: | | 2) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| Test reliability established?: | Presenting with cystic ovarian mass | | Interassay coefficient of variation for samples of cyst fluid assayed in duplicate by two operators was 8% to 14.5% (these figures compared well with those provided by the manufacturers for serum samples).
| Yes | Exclusion criteria:
| Statistical tests used: | NR
| Se, Sp
| Blinding: No
| Definition of positive and negative on screening test:
| No
Diamandis, Scorilas, Fracchioli, et al., 2003 | Geographical location: | Age: | Screening only (n [%]): | 1) hK6 > 4.2 μg/L for diagnosis of ovarian cancer (vs. benigns and controls): | | | | Comments:
#2850 | Turin, Italy; Groningen, The Netherlands; Leuven, Belgium; Helsinki, Finland | Ovarian cancer: | NR | | | | | None
| Study dates: NR | Mean: 56 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Median: 57 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 76 | 24 | 100 | Reference standard: +
| 384 | Range: 28–78 | Additional data used for diagnosis: | T- | 70 | 214 | 284 | Verification bias: +
| Type of population: | Benign disease: | NR | Tot | 146 | 238 | 384 | Test reliability/variability: +
| Adnexal mass | Mean: 46 | | | | | | Sample size: +
| Genomic test(s) used: | Median: 45 | | | | Lower | Upper | Statistical tests: +
| Human kallikrein 6 (hK6) | Range: 21–76 | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Healthy controls: | | Se | 52.0% | 43.9% | 60.1% | Definition of +/- on screening test: -
| Reference standard: | Mean: 52 | | Sp | 90.0% | 86.2% | 93.8% | Grade: B
| Surgical pathology | Median: 49 | | PPV | 76.0% | 67.6% | 84.4%
| Reference standard applied to all test negatives?: | Range: 26–72 | | NPV | 75.4% | 70.3% | 80.4%
| No, only benign ovarian disease group (not apparently healthy controls) | Menopausal status (n [%]):
| Test reliability established?: | NR | | 2) hK6 > 4.4 μg/L for diagnosis of ovarian cancer (vs. benigns and controls):
| Yes | Race/ethnicity (n [%]):
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| Se, Sp | Risk factors (n [%]): | | T+ | 69 | 12 | 81
| Blinding: No | NR | | T- | 77 | 226 | 303
| Definition of positive and negative on screening test: | Diagnoses (n [%]): | | Tot | 146 | 238 | 384
| hK6 > 4.2 μg/L (90% Sp) | Ovarian cancer: 146
| hK6 > 4.4 μg/L (95% Sp) | Benign ovarian mass: 141 | | | | Lower | Upper
| | Healthy controls: 97 | | | Value | 95% CI | 95% CI
| | Inclusion criteria: | | Se | 47.0% | 38.9% | 55.1%
| | Known ovarian mass, undergoing surgery | | Sp | 95.0% | 92.2% | 97.8%
| | Exclusion criteria: | | PPV | 85.2% | 77.4% | 92.9%
| | None specified | | NPV | 74.6% | 69.7% | 79.5%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | hK6 detection limit is 0.1 ug/L; dynamic range up to 50 ug/L; precision less than 10% within the measurement range.
Fayed, Ahmad, Kassim, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) CA-125 ≥ 85 U/mL for diagnosis of ovarian cancer (vs. benign disease and healthy controls): | | | | Comments:
#6350 | Cairo, Egypt | Ovarian cancer: | NR | | | | | None
| Study dates: | Range: 19–65 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Mar 94 – Apr 96 | Benign pelvic disease: | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 23 | 3 | 26 | Reference standard: +/-
| Size of population: | Range: 20–60 | Additional data used for diagnosis: | T- | 7 | 57 | 64 | Verification bias: -
| 30 women ovarian cancer | Healthy controls: | NR | Tot | 30 | 60 | 90 | Test reliability/variability: -
| 30 benign pelvic disease | Range: 22–63 | | | | | | Sample size: -
| 30 healthy controls | Menopausal status (n [%]): | | | | Lower | Upper | Statistical tests: +
| Type of population: | NR | | | Value | 95% CI | 95% CI | Blinding: -
| Adnexal mass | Race/ethnicity (n [%]): | | Se | 76.7% | 61.6% | 91.8% | Definition of +/- on screening test: -
| Genomic test(s) used: | NR | | Sp | 95.0% | 89.5% | 100.0% | Grade: C
| CA-125 | Risk factors (n [%]): | | PPV | 88.5% | 76.2% | 100.0%
| CA-72-4 | NR | | NPV | 89.1% | 81.4% | 96.7%
| Reference standard: Surgical pathology | Diagnoses (n [%]):
| Reference standard applied to all test negatives?: | Ovarian cancer: 30 | | 2) CA 72-4 ≥ 8.5 U/mL for diagnosis of ovarian cancer (vs. benign disease and healthy controls):
| Yes, benign pelvic diseases | Benign ovarian mass: 30
| No, healthy controls | Healthy controls: 30 | | | Dis+ | Dis- | Tot
| Test reliability established?: | Inclusion criteria: | | T+ | 21 | 3 | 24
| No | NR | | T- | 9 | 57 | 66
| Statistical tests used: | Exclusion criteria: | | Tot | 30 | 60 | 90
| Se, Sp | NR
| Blinding: No | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| No | | | Se | 70.0% | 53.6% | 86.4%
| | | | Sp | 95.0% | 89.5% | 100.0%
| | | | PPV | 87.5% | 74.3% | 100.0%
| | | | NPV | 86.4% | 78.1% | 94.6%
| | | | 3) CA-125 ≥ 85 U/mL OR CA 72-4 ≥ 8.5 U/mL for diagnosis of ovarian cancer (vs. benign disease and healthy controls):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 29 | 3 | 32
| | | | T- | 2 | 57 | 59
| | | | Tot | 30 | 60 | 91
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.0% | 87.2% | 100.0%
| | | | Sp | 95.0% | 89.5% | 100.0%
| | | | PPV | 90.6% | 80.5% | 100.0%
| | | | NPV | 96.6% | 92.0% | 100.0%
Gadducci, Baicchi, Marrai, et al., 1996 | Geographical location: | Age: | Screening only (n [%]): | 1) CA-125 (> 65 U/mL): | | | | Comments:
#7770 | Pisa, Italy | Cancer: | NR | | | | | None
| Study dates: NR | Median: 62 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 28–81 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 43 | 4 | 47 | Reference standard: +
| 121 | Benign: | Does not indicate how mass was diagnosed - just that they were going to laparotomy | T- | 13 | 61 | 74 | Verification bias: -
| Type of population: | Median: 42 | Additional data used for diagnosis: | Tot | 56 | 65 | 121 | Test reliability/variability: +
| Adnexal mass | Range: 17–73 | NR | | | | | Sample size: +
| Genomic test(s) used: | Menopausal status (n [%]): | | | | Lower | Upper | Statistical tests: +
| D-dimer | Pre (< 45): 57 (47%) | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Post (> 55): 64 (53%) | | Se | 76.8% | 65.7% | 87.9% | Definition of +/- on screening test: +
| Reference standard: | Race/ethnicity (n [%]): | | Sp | 93.8% | 87.9% | 99.7% | Grade: A
| Surgical pathology | NR | | PPV | 91.5% | 83.5% | 99.5%
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | | NPV | 82.4% | 73.8% | 91.1%
| NR | Clinical diagnosis of ovarian mass
| Test reliability established?: | Diagnoses (n [%]): | | 2) D-Dimer (> 416 ng/mL):
| NR | Ovarian cancer: 56 (46%)
| Statistical tests used: | Benign ovarian mass: 65 (54%) | | | Dis+ | Dis- | Tot
| Mann-Whitney U test, Spearman rank correlation, logistic regression, p < 0.05 | Inclusion criteria: Consecutive patients with clinical diagnosis of ovarian mass | | T+ | 51 | 11 | 62
| Blinding: NR | Exclusion criteria: | | T- | 5 | 54 | 59
| Definition of positive and negative on screening test: | Patients with cardiovascular disease, diabetes, acute or chronic inflammatory disease, previous malignancy, or previous episodes of thrombophlebitis or thromboembolia | | Tot | 56 | 65 | 121
| D-dimer = 416 ng/mL
| CA-125 = 65 U/mL | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.1% | 83.6% | 98.6%
| | | | Sp | 83.1% | 74.0% | 92.2%
| | | | PPV | 82.3% | 72.7% | 91.8%
| | | | NPV | 91.5% | 84.4% | 98.6%
| | | | 3) Premenopause (CA-125):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 4 | 12
| | | | T- | 4 | 41 | 45
| | | | Tot | 12 | 45 | 57
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 66.7% | 40.0% | 93.4%
| | | | Sp | 91.1% | 82.8% | 99.4%
| | | | PPV | 66.7% | 40.0% | 93.3%
| | | | NPV | 91.1% | 82.8% | 99.4%
| | | | 4) Premenopause D-Dimer:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 12 | 4 | 16
| | | | T- | 0 | 41 | 41
| | | | Tot | 12 | 45 | 57
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 75.0% | 100.0%
| | | | Sp | 91.1% | 82.8% | 99.4%
| | | | PPV | 75.0% | 53.8% | 96.2%
| | | | NPV | 100.0% | 92.7% | 100.0%
| | | | 5) Postmenopause CA-125:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 35 | 0 | 35
| | | | T- | 9 | 20 | 29
| | | | Tot | 44 | 20 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.5% | 67.6% | 91.4%
| | | | Sp | 100.0% | 85.0% | 100.0%
| | | | PPV | 100.0% | 91.4% | 100.0%
| | | | NPV | 69.0% | 52.1% | 85.8%
| | | | 6) Postmenopause D-Dimer:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 39 | 7 | 46
| | | | T- | 5 | 13 | 18
| | | | Tot | 44 | 20 | 64
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.6% | 79.2% | 98.0%
| | | | Sp | 65.0% | 44.1% | 85.9%
| | | | PPV | 84.8% | 74.4% | 95.2%
| | | | NPV | 72.2% | 51.5% | 92.9%
Gorelik, Landsittel, Marrangoni, et al., 2005 | Geographical location: | Age: | Screening only (n [%]): | 1) CA-125: | | | | Comments:
#350 | Cleveland, OH | Control: | NR | | | | | - Cannot determine if cut points were used to determine sensitivity and specificity as listed in Table 3.
| Study dates: NR | Median: 46 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 36–76 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 42 | 21 | 63 | Reference standard: -
| 126 | Early cancer: | Additional data used for diagnosis: | T- | 2 | 61 | 63 | Verification bias: -
| Type of population: | Median: 46 | NR | Tot | 44 | 82 | 126 | Test reliability/variability: +
| Screening | Range: 34–88 | | | | | | Sample size: +
| Genomic test(s) used: | Benign: | | | | Lower | Upper | Statistical tests: +
| Cytokines | Median: 44.5 | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Range: 28–87 | | Se | 95.5% | 89.4% | 100.0% | Definition of +/- on screening test: -
| Reference standard: | Menopausal status (n [%]): | | Sp | 74.4% | 65.0% | 83.8% | Grade: B
| NR | NR | | PPV | 66.7% | 55.0% | 78.3%
| Reference standard applied to all test negatives?: | Race/ethnicity (n [%]): NR | | NPV | 96.8% | 92.5% | 100.0%
| NR | Risk factors (n [%]):
| Test reliability established?: | NR | | 2) IL-6:
| Yes | Diagnoses (n [%]):
| Statistical tests used: | Ovarian cancer: 44 (35%) | | | Dis+ | Dis- | Tot
| Wilcoxon rank sum | Benign ovarian mass: 37 (29%) | | T+ | 37 | 11 | 48
| Spearman | Healthy controls: 45 (36%) | | T- | 7 | 71 | 78
| CART | Inclusion criteria: | | Tot | 44 | 82 | 126
| Blinding: NR | NR
| Definition of positive and negative on screening test: | Exclusion criteria: | | | | Lower | Upper
| CA-125 < 28 | NR | | | Value | 95% CI | 95% CI
| Il-6 < 0.4 | | | Se | 84.1% | 73.3% | 94.9%
| IL-8 < 5.2 | | | Sp | 86.0% | 78.5% | 93.5%
| EGF < 149.3 | | | PPV | 77.1% | 65.2% | 89.0%
| VEGF < 126.5 | | | NPV | 91.0% | 84.7% | 97.4%
| | | | 3) EGF:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 37 | 19 | 56
| | | | T- | 7 | 63 | 70
| | | | Tot | 44 | 82 | 126
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.1% | 73.3% | 94.9%
| | | | Sp | 76.7% | 67.5% | 85.9%
| | | | PPV | 66.1% | 53.7% | 78.5%
| | | | NPV | 90.0% | 83.0% | 97.0%
| | | | 4) IL-8:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 39 | 25 | 64
| | | | T- | 5 | 57 | 62
| | | | Tot | 44 | 82 | 126
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.6% | 79.2% | 98.0%
| | | | Sp | 69.8% | 59.9% | 79.7%
| | | | PPV | 60.9% | 49.0% | 72.9%
| | | | NPV | 91.9% | 85.2% | 98.7%
| | | | 5) MCP:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 37 | 23 | 60
| | | | T- | 7 | 59 | 66
| | | | Tot | 44 | 82 | 126
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.1% | 73.3% | 94.9%
| | | | Sp | 72.1% | 62.4% | 81.8%
| | | | PPV | 61.7% | 49.4% | 74.0%
| | | | NPV | 89.4% | 82.0% | 96.8%
| | | | 6) VEGF:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 35 | 27 | 62
| | | | T- | 9 | 55 | 64
| | | | Tot | 44 | 82 | 126
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 79.5% | 67.6% | 91.4%
| | | | Sp | 67.4% | 57.3% | 77.5%
| | | | PPV | 56.5% | 44.1% | 68.8%
| | | | NPV | 85.9% | 77.4% | 94.5%
| | | | 7) G-CSF:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 32 | 21 | 53
| | | | T- | 12 | 61 | 73
| | | | Tot | 44 | 82 | 126
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 72.7% | 59.5% | 85.9%
| | | | Sp | 74.4% | 65.0% | 83.8%
| | | | PPV | 60.4% | 47.2% | 73.5%
| | | | NPV | 83.6% | 75.1% | 92.1%
Hasholzner, Baum-gartner, Stieber, et al., 1996 | Geographical location: | Age: NR | Screening only (n [%]): | 1) CA-125 for healthy vs. cancer: | | | | Comments:
#7520 | Munich, Germany | Menopausal status (n [%]): | NR | | | | | None
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 64 | 0 | 64 | Reference standard: -
| 426 | NR | Additional data used for diagnosis: | T- | 59 | 30 | 89 | Verification bias: +
| Type of population: | Risk factors (n [%]): | NR | Tot | 123 | 30 | 153 | Test reliability/variability: +
| Screening | NR | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| CA-125 | Ovarian cancer: 359 (84%) | | | Value | 95% CI | 95% CI | Blinding: -
| CA-72-4 | Benign ovarian mass: 37 (8.6%) | | Se | 52.0% | 43.2% | 60.8% | Definition of +/- on screening test: +
| Reference standard: Surgical pathology | Healthy controls: 30 (7%) | | Sp | 100.0% | 90.0% | 100.0% | Grade: B
| Clinical outcome | Inclusion criteria: | | PPV | 100.0% | 95.3% | 100.0%
| Reference standard applied to all test negatives?: | NR | | NPV | 33.7% | 23.9% | 43.5%
| NR | Exclusion criteria:
| Test reliability established?: | NR | | 2) CA-125 for benign vs. cancer:
| NR
| Statistical tests used: NR | | | | Dis+ | Dis- | Tot
| Blinding: NR | | | T+ | 64 | 1 | 65
| Definition of positive and negative on screening test: | | | T- | 59 | 36 | 95
| CA-125: 160 U/mL | | | Tot | 123 | 37 | 160
| CA-72-4: 3 U/mL
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 52.0% | 43.2% | 60.8%
| | | | Sp | 97.0% | 91.5% | 100.0%
| | | | PPV | 98.5% | 95.5% | 100.0%
| | | | NPV | 37.9% | 28.1% | 47.7%
| | | | 3) CA 72-4 for healthy vs. cancer:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 66 | 1 | 67
| | | | T- | 57 | 29 | 86
| | | | Tot | 123 | 30 | 153
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.0% | 45.2% | 62.8%
| | | | Sp | 97.0% | 90.9% | 100.0%
| | | | PPV | 98.5% | 95.6% | 100.0%
| | | | NPV | 33.7% | 23.7% | 43.7%
| | | | 4) CA 72-4 for benign vs. cancer:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 66 | 1 | 67
| | | | T- | 57 | 36 | 93
| | | | Tot | 123 | 37 | 160
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 54.0% | 45.2% | 62.8%
| | | | Sp | 97.0% | 91.5% | 100.0%
| | | | PPV | 98.5% | 95.6% | 100.0%
| | | | NPV | 38.7% | 28.8% | 48.6%
Hefler, Mayerhofer, Nardi, et al., 2000 | Geographical location: | Age: | Screening only (n [%]): | 1) Fas: | | | | Comments:
#5050 | Vienna, Austria | Cancer: | NR | | | | | None
| Study dates: | Median: 57 | Diagnosis of mass:NR | | Dis+ | Dis- | Tot | Quality assessment:
| Dec 1992–Mar 1999 | Range: 29–87 | - Symptomatic (n [%]):; - Asymptomatic, detected by exam (n [%]):; - Asymptomatic, detected by imaging (n [%]): | T+ | 28 | 3 | 31 | Reference standard: -
| Size of population: | Benign: | Additional data used for diagnosis: | T- | 24 | 62 | 86 | Verification bias: +
| 117 | Median: 50 | Follow-up of women with cancer | Tot | 52 | 65 | 117 | Test reliability/variability: +
| Type of population: | Range: 24–79 | | | | | | Sample size: +
| Screening | Healthy: | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Median: 39 | | | Value | 95% CI | 95% CI | Blinding: -
| Serum soluble Fas levels | Range: 23–58 | | Se | 53.0% | 39.4% | 66.6% | Definition of +/- on screening test: +
| Reference standard: | Menopausal status (n [%]): | | Sp | 95.0% | 89.7% | 100.0% | Grade: B
| Surgical pathology | NR | | PPV | 90.3% | 79.9% | 100.0%
| Clinical outcome | Race/ethnicity (n [%]): NR | | NPV | 72.1% | 62.6% | 81.6%
| Reference standard applied to all test negatives?: | Risk factors (n [%]):
| NR | NR | | 2) CA-125:
| Test reliability established?: | Diagnoses (n [%]):
| Yes | Ovarian cancer: 52 (44%) | | | Dis+ | Dis- | Tot
| Statistical tests used: | Benign ovarian mass: 30 (26%) | | T+ | 37 | 3 | 40
| Fas levels | Healthy controls: 35 (30%) | | T- | 15 | 62 | 77
| CA-125 | Inclusion criteria: | | Tot | 52 | 65 | 117
| Blinding: NR | Consecutive women with stage I, II, or III ovarian cancer
| Definition of positive and negative on screening test: | Exclusion criteria: | | | | Lower | Upper
| Fas: 3.69 ng/mL | Borderline ovarian cancer | | | Value | 95% CI | 95% CI
| CA-125: 409 U/mL | | | Se | 71.0% | 58.7% | 83.3%
| | | | Sp | 95.0% | 89.7% | 100.0%
| | | | PPV | 92.5% | 84.3% | 100.0%
| | | | NPV | 80.5% | 71.7% | 89.4%
| | | | 3) CA-125 and Fas combined:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 42 | 3 | 45
| | | | T- | 10 | 62 | 72
| | | | Tot | 52 | 65 | 117
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.0% | 70.3% | 91.7%
| | | | Sp | 95.0% | 89.7% | 100.0%
| | | | PPV | 93.3% | 86.0% | 100.0%
| | | | NPV | 86.1% | 78.1% | 94.1%
Hibbs, Skubitz, Pambuc-cian, et al., 2004 | Geographical location: | Age: | Screening only (n [%]): | 1) B8 integrin (normal vs. ovarian carcinoma): | | | | Comments:
#9030 | Minneapolis, MN | Healthy: | NR | | | | | None
| Study dates: NR | Mean: 51 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 32–79 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 16 | 7 | 23 | Reference standard: +
| 87 | Serous papillary ovarian cancer: | Additional data used for diagnosis: | T- | 4 | 43 | 47 | Verification bias: +
| Type of population: | Mean: 57.6 | NR | Tot | 20 | 50 | 70 | Test reliability/variability: +
| Screening | Range: 29–79 | | | | | | Sample size: -
| Genomic test(s) used: | Serous papillary ovarian cancer to the omentum: | | | | Lower | Upper | Statistical tests: +
| Gene expression | Mean: 59.7 | | | Value | 95% CI | 95% CI | Blinding: +
| B8 integrin | Range: 29–79 | | Se | 80.0% | 62.5% | 97.5% | Definition of +/- on screening test: +
| BMP-7 | Menopausal status (n [%]): | | Sp | 86.7% | 77.3% | 96.1% | Grade: A
| Claudin-4 | NR | | PPV | 69.6% | 50.8% | 88.4%
| Col ix a2 | Race/ethnicity (n [%]): | | NPV | 91.5% | 83.5% | 99.5%
| | NR
| CRABp-1 | Risk factors (n [%]):
| FOX J1 | NR | | 2) B8 integrin (normal vs. metastatic ovarian carcinoma):
| S100A1 | Diagnoses (n [%]):
| Reference standard: | Ovarian cancer: 37 (43%) | | | Dis+ | Dis- | Tot
| Surgical pathology | Healthy controls: 50 (57%) | | T+ | 14 | 7 | 21
| Clinical outcome | Inclusion criteria: | | T- | 3 | 43 | 46
| Reference standard applied to all test negatives?: | None had been treated with chemotherapy before resection | | Tot | 17 | 50 | 67
| Yes | Exclusion criteria:
| Test reliability established?: | NR | | | | Lower | Upper
| Yes | | | | Value | 95% CI | 95% CI
| Statistical tests used: Youden's misclassification; pair-wise tissue comparisons; | | | Se | 80.0% | 61.0% | 99.0%
| Wilcoxon-Mann-Whitney; linear logistic regression | | | Sp | 86.7% | 77.3% | 96.1%
| Blinding: Yes | | | PPV | 66.7% | 46.5% | 86.8%
| Definition of positive and negative on screening test: | | | NPV | 93.5% | 86.3% | 100.0%
| +++ maximum positive
| ++ moderate | | | 3) BMP-7 (normal vs. ovarian carcinoma):
| + weak
| +/- faint or questionable | | | | Dis+ | Dis- | Tot
| - lack of staining | | | T+ | 12 | 17 | 29
| | | | T- | 8 | 33 | 41
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 38.5% | 81.5%
| | | | Sp | 66.7% | 53.6% | 79.8%
| | | | PPV | 41.4% | 23.5% | 59.3%
| | | | NPV | 80.5% | 68.4% | 92.6%
| | | | 4) BMP-7 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 10 | 17 | 27
| | | | T- | 7 | 33 | 40
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 36.7% | 83.3%
| | | | Sp | 66.7% | 53.6% | 79.8%
| | | | PPV | 37.0% | 18.8% | 55.3%
| | | | NPV | 82.5% | 70.7% | 94.3%
| | | | 5) Claudin-4 (normal vs. ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 20 | 3 | 23
| | | | T- | 0 | 47 | 47
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 99.3% | 85.0% | 100.0%
| | | | Sp | 93.3% | 86.4% | 100.0%
| | | | PPV | 87.0% | 73.2% | 100.0%
| | | | NPV | 100.0% | 93.6% | 100.0%
| | | | 6) Claudin-4 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 3 | 20
| | | | T- | 0 | 47 | 47
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 82.4% | 100.0%
| | | | Sp | 93.3% | 86.4% | 100.0%
| | | | PPV | 85.0% | 69.4% | 100.0%
| | | | NPV | 100.0% | 93.6% | 100.0%
| | | | 7) COL Ix a2 (normal vs. ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 4 | 0 | 4
| | | | T- | 16 | 50 | 66
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 20.0% | 2.5% | 37.5%
| | | | Sp | 100.0% | 94.0% | 100.0%
| | | | PPV | 100.0% | 25.0% | 100.0%
| | | | NPV | 75.8% | 65.4% | 86.1%
| | | | 8) COL Ix a2 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 3 | 0 | 3
| | | | T- | 14 | 50 | 64
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 20.0% | 1.0% | 39.0%
| | | | Sp | 100.0% | 94.0% | 100.0%
| | | | PPV | 100.0% | 0.0% | 100.0%
| | | | NPV | 78.1% | 68.0% | 88.3%
| | | | 9) CRABP-1 (normal vs. ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 23 | 34
| | | | T- | 9 | 27 | 36
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 53.3% | 31.4% | 75.2%
| | | | Sp | 53.3% | 39.5% | 67.1%
| | | | PPV | 32.4% | 16.6% | 48.1%
| | | | NPV | 75.0% | 60.9% | 89.1%
| | | | 10) CRABP-1 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 2 | 0 | 2
| | | | T- | 15 | 50 | 65
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 13.3% | 0.0% | 29.4%
| | | | Sp | 100.0% | 94.0% | 100.0%
| | | | PPV | 100.0% | 0% | 100.0%
| | | | NPV | 76.9% | 66.7% | 87.2%
| | | | 11) FOX J1 (normal vs. ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 19 | 33 | 52
| | | | T- | 1 | 17 | 18
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.3% | 82.3% | 100.0%
| | | | Sp | 33.3% | 20.2% | 46.4%
| | | | PPV | 36.5% | 23.5% | 49.6%
| | | | NPV | 94.4% | 83.9% | 100.0%
| | | | 12) FOX J1 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 33 | 50
| | | | T- | 0 | 17 | 17
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 82.4% | 100.0%
| | | | Sp | 33.3% | 20.2% | 46.4%
| | | | PPV | 34.0% | 20.9% | 47.1%
| | | | NPV | 100.0% | 82.4% | 100.0%
| | | | 13) S100A1 (normal vs. ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 20 | 20 | 40
| | | | T- | 0 | 30 | 30
| | | | Tot | 20 | 50 | 70
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 85.0% | 100.0%
| | | | Sp | 60.0% | 46.4% | 73.6%
| | | | PPV | 50.0% | 34.5% | 65.5%
| | | | NPV | 100.0% | 90.0% | 100.0%
| | | | 14) S100A1 (normal vs. metastatic ovarian carcinoma):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 16 | 20 | 36
| | | | T- | 1 | 30 | 31
| | | | Tot | 17 | 50 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.3% | 81.4% | 100.0%
| | | | Sp | 60.0% | 46.4% | 73.6%
| | | | PPV | 44.4% | 28.2% | 60.7%
| | | | NPV | 96.8% | 90.6% | 100.0%
Hofmann and Ruschen-burg, 2002 | Geographical location: | Age: | Screening only (n [%]): | 1) BAGE: | | | | Comments:
#3610 | Göttingen Germany | Median: 68 | NR | | | | | None
| Study dates: NR | Range: 36–82 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 16 | 1 | 17 | Reference standard: +
| 44 | NR | Additional data used for diagnosis: | T- | 11 | 16 | 27 | Verification bias: -
| Type of population: | Race/ethnicity (n [%]): | NR | Tot | 27 | 17 | 44 | Test reliability/variability: +
| Screening | NR | | | | | | Sample size: -
| Genomic test(s) used: | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| BAGE | NR | | | Value | 95% CI | 95% CI | Blinding: -
| MAGE-1 | Diagnoses (n [%]): | | Se | 60.0% | 41.5% | 78.5% | Definition of +/- on screening test: +
| MAGE-3 | Ovarian cancer: 27 (61%) | | Sp | 94.0% | 82.7% | 100.0% | Grade: B
| GAGE-1/2 | Healthy controls: 17 (39%) | | PPV | 94.1% | 82.9% | 100.0%
| Reference standard: | Inclusion criteria: Samples sent to department of cytology for routine diagnosis; clinically suspected ovarian carcinoma | | NPV | 59.3% | 40.7% | 77.8%
| Surgical pathology | Exclusion criteria:
| Clinical outcome | NR | | 2) MAGE-1:
| Reference standard applied to all test negatives?:
| Yes | | | | Dis+ | Dis- | Tot
| Test reliability established?: | | | T+ | 2 | 0 | 2
| Yes | | | T- | 25 | 17 | 42
| Statistical tests used: Sensitivity, specificity | | | Tot | 27 | 17 | 44
| Blinding: NR
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Presence or absence of gene | | | | Value | 95% CI | 95% CI
| | | | Se | 8.0% | 0.0% | 18.2%
| | | | Sp | 100.0% | 82.4% | 100.0%
| | | | PPV | 100.0% | 0% | 100.0%
| | | | NPV | 40.5% | 25.6% | 55.3%
| | | | 3) MAGE-3:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 0 | 9
| | | | T- | 18 | 17 | 35
| | | | Tot | 27 | 17 | 44
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 32.0% | 14.4% | 49.6%
| | | | Sp | 100.0% | 82.4% | 100.0%
| | | | PPV | 100.0% | 66.7% | 100.0%
| | | | NPV | 48.6% | 32.0% | 65.1%
| | | | 4) GAGE-1/2:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 0 | 9
| | | | T- | 18 | 17 | 35
| | | | Tot | 27 | 17 | 44
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 32.0% | 14.4% | 49.6%
| | | | Sp | 100.0% | 82.4% | 100.0%
| | | | PPV | 100.0% | 66.7% | 100.0%
| | | | NPV | 48.6% | 32.0% | 65.1%
Hurteau, Woolas, Jacobs, et al., 1995 | Geographical location: | Age: NR | Screening only (n [%]): | 1) sIL-2Rα: | | | | Comments:
#7890 | London, England | Menopausal status (n [%]): | NR | | | | | None
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 37 | 58 | 95 | Reference standard: +
| 192 | NR | Additional data used for diagnosis: | T- | 2 | 3 | 5 | Verification bias: -
| Type of population: | Risk factors (n [%]): | NR | Tot | 39 | 61 | 100 | Test reliability/variability: +
| Screening | NR: | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| sIL-2Rα | Ovarian cancer: 39 (20%) | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Benign ovarian mass: 61 (32%) | | Se | 94.9% | 87.9% | 100.0% | Definition of +/- on screening test: +
| Reference standard: | Healthy controls: 92 (48%) | | Sp | 4.9% | 0.0% | 10.3% | Grade: B
| Surgical pathology | Inclusion criteria: | | PPV | 38.9% | 29.1% | 48.8%
| Clinical outcome | Gynecologic masses and healthy controls | | NPV | 60.0% | 17.1% | 100.0%
| Reference standard applied to all test negatives?: | Exclusion criteria:
| Yes | NR | | 2) sIL-2Rα +CA-125:
| Test reliability established?:
| Yes | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 34 | 44 | 78
| Student's t test, p<0.05 | | | T- | 5 | 17 | 22
| Blinding: NR | | | Tot | 39 | 61 | 100
| Definition of positive and negative on screening test:
| sIL-2Rα = 650 U/mL | | | | | Lower | Upper
| CA-125 = 35 U/mL | | | | Value | 95% CI | 95% CI
| | | | Se | 87.2% | 76.7% | 97.7%
| | | | Sp | 27.9% | 16.6% | 39.1%
| | | | PPV | 43.6% | 32.6% | 54.6%
| | | | NPV | 77.3% | 59.8% | 94.8%
| | | | Values were reversed in table. Unable to duplicate sensitivity value.
Inaba, Negishi, Fukasawa, et al., 1995 | Geographical location: | Age: | Screening only (n [%]): | 1) CYFRA 21-1: | | | | Comments:
#7960 | Tokyo, Japan | Healthy: | NR | | | | | None
| Study dates: NR | Range: 18–53 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Benign: | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 48 | 3 | 51 | Reference standard: +
| 215 | Range: 19–55 | Additional data used for diagnosis: | T- | 27 | 137 | 164 | Verification bias: +
| Type of population: | Cancer: | NR | Tot | 75 | 140 | 215 | Test reliability/variability: +
| Screening | Range: 23–69 | | | | | | Sample size: +
| Genomic test(s) used: | Menopausal status (n [%]): | | | | Lower | Upper | Statistical tests: +
| Cytokeratin fragment 21 (CYFRA 21-1) | NR | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Race/ethnicity (n [%]): | | Se | 64.0% | 53.1% | 74.9% | Definition of +/- on screening test: +
| SCC | NR | | Sp | 97.9% | 95.5% | 100.0% | Grade: A
| Reference standard: | Risk factors (n [%]): | | PPV | 94.1% | 87.7% | 100.0%
| Surgical pathology | NR | | NPV | 83.5% | 77.9% | 89.2%
| Clinical outcome | Diagnoses (n [%]):
| Reference standard applied to all test negatives?: | Ovarian cancer: 75 (35%) | | 2) CA-125:
| NR | Benign ovarian mass: 38 (18%)
| Test reliability established?: | Healthy controls: 102 (47%) | | | Dis+ | Dis- | Tot
| Yes | Inclusion criteria: | | T+ | 44 | 20 | 64
| Statistical tests used: | NR | | T- | 31 | 120 | 151
| X⁁2 test with Yates correction, t test, p<0.05 | Exclusion criteria: | | Tot | 75 | 140 | 215
| Blinding: NR | NR
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| CYFRA 21-1 = 1.9 ng/mL | | | | Value | 95% CI | 95% CI
| CA-125 = 35 U/mL | | | Se | 58.7% | 47.5% | 69.8%
| SCC = 1.5 ng/mL | | | Sp | 85.7% | 79.9% | 91.5%
| | | | PPV | 68.8% | 57.4% | 80.1%
| | | | NPV | 79.5% | 73.0% | 85.9%
Kim, Herlyn, Wong, et al., 2003 | Geographical location: | Age: | Screening only (n [%]): | 1) EP-CAM cutoff 0.140: | | | | Comments:
#9230 | Boston, MA | Mean (SD): 58 | NR | | | | | None
| Study dates: | Range: 45–76 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| 1992-2000 | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 22 | 2 | 24 | Reference standard: +
| Size of population: | NR | Additional data used for diagnosis: | T- | 30 | 50 | 80 | Verification bias: +
| 104 | Race/ethnicity (n [%]): | NR | Tot | 52 | 52 | 104 | Test reliability/variability: +
| Type of population: | NR | | | | | | Sample size: -
| Screening | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Blinding: -
| Ep-CAM | Diagnoses (n [%]): | | Se | 42.3% | 28.9% | 55.7% | Definition of +/- on screening test: +
| Reference standard: | Ovarian cancer: 52 (50%) | | Sp | 96.2% | 90.9% | 100.0% | Grade: B
| Surgical pathology | Benign ovarian mass: 26 (25%) | | PPV | 91.7% | 80.6% | 100.0%
| Reference standard applied to all test negatives?: | Healthy controls: 26 (25%) | | NPV | 62.5% | 51.9% | 73.1%
| Yes | Inclusion criteria:
| Test reliability established?: | NR | | 2) EP-CAM cutoff 0.115:
| Yes | Exclusion criteria:
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| Mean, SD, 95% CI; Mann-Whitney U test | | | T+ | 38 | 11 | 49
| Blinding: Yes - to clinical data | | | T- | 14 | 41 | 55
| Definition of positive and negative on screening test: | | | Tot | 52 | 52 | 104
| 0.140 cutoff
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 73.1% | 61.0% | 85.1%
| | | | Sp | 78.8% | 67.7% | 89.9%
| | | | PPV | 77.6% | 65.9% | 89.2%
| | | | NPV | 74.5% | 63.0% | 86.1%
| | | | 3) CA-125 cutoff 35 U/mL:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 45 | 6 | 51
| | | | T- | 7 | 46 | 53
| | | | Tot | 52 | 52 | 104
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.5% | 77.2% | 95.8%
| | | | Sp | 88.5% | 79.8% | 97.2%
| | | | PPV | 88.2% | 79.4% | 97.1%
| | | | NPV | 86.8% | 77.7% | 95.9%
| | | | 4) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | A patient with positive EP-CAM has 11.4-fold risk of normal women in the diagnosis of ovarian cancer (odds ratio = 11.4, CI = 3.6 to 36.1, relative risk = 3.8) in comparison with CA-125 (OR = 49.3, CI = 11.6 to 208.6, RR = 7.5).
Kozak, Amneus, Pusey, et al., 2003 | Geographical location: | Age: NR | Screening only (n [%]): | 1) Screening panel #1 (when Se equals Sp): | | | | Comments:
#2220 | Los Angeles, CA | Menopausal status (n [%]): | NR | | | | | None
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 94 | 10 | 104 | Reference standard: +
| 184 | NR | Additional data used for diagnosis: | T- | 15 | 65 | 80 | Verification bias: +
| Type of population: | Risk factors (n [%]): | NR | Tot | 109 | 75 | 184 | Test reliability/variability: +
| Screening | NR | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| Biomarker panels | Ovarian cancer: 109 (59%) | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Benign ovarian mass: 19 (10%) | | Se | 86.2% | 79.7% | 92.7% | Definition of +/- on screening test: +
| Surgical pathology | Healthy controls: 56 (30%) | | Sp | 87.0% | 79.4% | 94.6% | Grade: B
| Reference standard applied to all test negatives?: | Inclusion criteria: | | PPV | 90.4% | 84.7% | 96.1%
| Yes | NR | | NPV | 81.3% | 72.7% | 89.8%
| Test reliability established?: | Exclusion criteria:
| Yes | NR | | 2) Screening panel #1 (highest accuracy):
| Statistical tests used:
| Proteinchip data analysis software | | | | Dis+ | Dis- | Tot
| Blinding: NR | | | T+ | 104 | 13 | 117
| Definition of positive and negative on screening test: | | | T- | 5 | 62 | 67
| NR | | | Tot | 109 | 75 | 184
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 95.7% | 91.9% | 99.5%
| | | | Sp | 82.6% | 74.0% | 91.2%
| | | | PPV | 88.9% | 83.2% | 94.6%
| | | | NPV | 92.5% | 86.2% | 98.8%
| | | | 3) Validation panel #1 (when Se equals Sp):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 93 | 11 | 104
| | | | T- | 16 | 64 | 80
| | | | Tot | 109 | 75 | 184
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 85.2% | 78.5% | 91.9%
| | | | Sp | 84.7% | 76.6% | 92.8%
| | | | PPV | 89.4% | 83.5% | 95.3%
| | | | NPV | 80.0% | 71.2% | 88.8%
| | | | 4) Validation panel #1 (highest accuracy):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 89 | 4 | 93
| | | | T- | 20 | 71 | 91
| | | | Tot | 109 | 75 | 184
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.5% | 74.2% | 88.8%
| | | | Sp | 94.9% | 89.9% | 99.9%
| | | | PPV | 95.7% | 91.6% | 99.8%
| | | | NPV | 78.0% | 69.5% | 86.5%
| | | | 5) Validation panel #2 (when Se equals Sp):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 89 | 14 | 103
| | | | T- | 20 | 61 | 81
| | | | Tot | 109 | 75 | 184
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.5% | 74.2% | 88.8%
| | | | Sp | 81.4% | 72.6% | 90.2%
| | | | PPV | 86.4% | 79.8% | 93.0%
| | | | NPV | 75.3% | 65.9% | 84.7%
| | | | 6) Validation panel #2 (highest accuracy):
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 79 | 4 | 83
| | | | T- | 30 | 71 | 101
| | | | Tot | 109 | 75 | 184
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 72.8% | 64.4% | 81.2%
| | | | Sp | 94.9% | 89.9% | 99.9%
| | | | PPV | 95.2% | 90.6% | 99.8%
| | | | NPV | 70.3% | 61.4% | 79.2%
Lee, Park, Jung, et al., 2005 | Geographical location: | Age: | Screening only (n [%]): | Using > 50% positivity: | | | | Comments:
#270 | Seoul, South Korea | Median: 51 | NR | 1) P53: | | | | None
| Study dates: | Range: 16–86 | Diagnosis of mass: | | | | | Quality assessment:
| 1994-2002 | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| Size of population: | NR | Additional data used for diagnosis: | T+ | 30 | 0 | 30 | Verification bias: -
| 201 | Race/ethnicity (n [%]): | NR | T- | 74 | 97 | 171 | Test reliability/variability: -
| Type of population: | NR | | Tot | 104 | 97 | 201 | Sample size: +
| Screening | Risk factors (n [%]): | | | | | | Statistical tests: +
| Genomic test(s) used: | NR | | | | Lower | Upper | Blinding: +
| P53 | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: -
| P21 | Ovarian cancer: 104 | | Se | 28.8% | 20.1% | 37.6% | Grade: B
| Bax | Borderline: 37 | | Sp | 100.0% | 96.9% | 100.0%
| Bcl-2 | Benign ovarian mass: 60 | | PPV | 100.0% | 90.0% | 100.0%
| GADD45 | Inclusion criteria: | | NPV | 56.7% | 49.3% | 64.2%
| Cyclin E | NR
| CDK2 | Exclusion criteria: | | 2) P21:
| PCNA | NR
| MDM2 | | | | Dis+ | Dis- | Tot
| Reference standard: | | | T+ | 7 | 5 | 12
| Surgical pathology | | | T- | 97 | 92 | 189
| Reference standard applied to all test negatives?: | | | Tot | 104 | 97 | 201
| NR
| Test reliability established?: | | | | | Lower | Upper
| NR | | | | Value | 95% CI | 95% CI
| Statistical tests used: Cochran-Mantel-Haenszel chi-square test and Cochran-Armitage trend test | | | Se | 6.7% | 1.9% | 11.5%
| Blinding: Yes | | | Sp | 94.8% | 90.4% | 99.2%
| Definition of positive and negative on screening test: | | | PPV | 58.3% | 30.4% | 86.2%
| 0–5% positivity | | | NPV | 48.7% | 41.6% | 55.8%
| 6–49% positivity
| ≥ 50% positivity | | | 3) Bax:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 34 | 10 | 44
| | | | T- | 70 | 87 | 157
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 32.7% | 23.7% | 41.7%
| | | | Sp | 89.7% | 83.6% | 95.7%
| | | | PPV | 77.3% | 64.9% | 89.7%
| | | | NPV | 55.4% | 47.6% | 63.2%
| | | | 4) Bcl-2:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 13 | 15 | 28
| | | | T- | 91 | 82 | 173
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 12.5% | 6.1% | 18.9%
| | | | Sp | 84.5% | 77.3% | 91.7%
| | | | PPV | 46.4% | 28.0% | 64.9%
| | | | NPV | 47.4% | 40.0% | 54.8%
| | | | 5) GADD45:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 21 | 30
| | | | T- | 95 | 76 | 171
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 8.7% | 3.3% | 14.1%
| | | | Sp | 78.4% | 70.2% | 86.5%
| | | | PPV | 30.0% | 13.6% | 46.4%
| | | | NPV | 44.4% | 37.0% | 51.9%
| | | | 6) Cyclin E:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 12 | 0 | 12
| | | | T- | 92 | 97 | 189
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 11.5% | 5.4% | 17.7%
| | | | Sp | 100.0% | 96.9% | 100.0%
| | | | PPV | 100.0% | 75.0% | 100.0%
| | | | NPV | 51.3% | 44.2% | 58.4%
| | | | 7) CDK2:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 0 | 9
| | | | T- | 95 | 97 | 192
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 8.7% | 3.3% | 14.1%
| | | | Sp | 100.0% | 96.9% | 100.0%
| | | | PPV | 100.0% | 66.7% | 100.0%
| | | | NPV | 50.5% | 43.4% | 57.6%
| | | | 8) MDM2:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 34 | 45
| | | | T- | 93 | 63 | 156
| | | | Tot | 104 | 97 | 201
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 10.6% | 4.7% | 16.5%
| | | | Sp | 64.9% | 55.5% | 74.4%
| | | | PPV | 24.4% | 11.9% | 37.0%
| | | | NPV | 40.4% | 32.7% | 48.1%
Luo, Bunting, Scorilas, et al., 2001 | Geographical location: | Age: NR | Screening only (n [%]): | 1) hk10 > 1.5 μg/L: | | | | Comments:
#4490 | Toronto, Ontario, Canada | Menopausal status (n [%]): | NR | | | | | None
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 45 | 0 | 45 | Reference standard: -
| 122 | NR | Additional data used for diagnosis: | T- | 35 | 42 | 77 | Verification bias: +
| Type of population: | Risk factors (n [%]): | NR | Tot | 80 | 42 | 122 | Test reliability/variability: +
| Screening | NR | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| Hk10 | Ovarian cancer: 80 (66%) | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Healthy controls: 42 (34%) | | Se | 56.3% | 45.4% | 67.1% | Definition of +/- on screening test: +
| Surgical pathology | Inclusion criteria: | | Sp | 100.0% | 92.9% | 100.0% | Grade: B
| Reference standard applied to all test negatives?: | CA-125 > 372 Ku/l for patients with cancer | | PPV | 100.0% | 93.3% | 100.0%
| NR | Exclusion criteria: | | NPV | 54.5% | 43.4% | 65.7%
| Test reliability established?: | NR
| Yes | | | 2) hk10 > 0.8 μg/L:
| Statistical tests used: Pearson correlation coefficient, Mann-Whitney test, ROC, AUC
| Blinding: NR | | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | | | T+ | 62 | 0 | 62
| Hk10 > 1.5 μg/L | | | T- | 18 | 42 | 60
| Hk10 > 0.8 μg/L | | | Tot | 80 | 42 | 122
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 77.5% | 68.3% | 86.7%
| | | | Sp | 100.0% | 92.9% | 100.0%
| | | | PPV | 100.0% | 95.2% | 100.0%
| | | | NPV | 70.0% | 58.4% | 81.6%
| | | | 3) ROC curve analysis (AUC 0.92,0.88–0.96):
| | | | Weak correlation between serum hk10 and CA-125 in ovarian cancer patients (r = 0.23, p = 0.04).
Mabrouk and Ali-Labib, 2003 | Geographical location: | Age: | Screening only (n [%]): | 1) c-erbB-2: | | | | Comments:
#2200 | Cairo, Egypt | Ovarian cancer: | Not applicable | | | | | - Ad hoc population; - Estimates will be higher than in real screening population
| Study dates: NR | Mean (SD): 46 (11.97) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Benign ovarian mass: Mean (SD): 45.7 (12.95) | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 4 | 4 | 8 | Reference standard: +
| 60 | Healthy controls: | Additional data used for diagnosis: | T- | 16 | 16 | 32 | Verification bias: -
| Type of population: | Mean (SD): 46 (15.21) | Histopathology for diagnosis | Tot | 20 | 20 | 40 | Test reliability/variability: -
| Ad hoc | Menopausal status (n [%]): | | | | | | Sample size: -
| Genomic test(s) used: | NR | | | | Lower | Upper | Statistical tests: +
| uPAR | Race/ethnicity (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| c-erbB-2 | Egyptian 100% | | Se | 20.0% | 2.5% | 37.5% | Definition of +/- on screening test: +
| CA-125 | Risk factors (n [%]): | | Sp | 80.0% | 62.5% | 97.5% | Grade: C
| CA-15.3 | NR | | PPV | 50.0% | 15.4% | 84.6%
| Reference standard: Surgical pathology | Diagnoses (n [%]): | | NPV | 50.0% | 32.7% | 67.3%
| Reference standard applied to all test negatives?: | Ovarian cancer: 20 (33.3%)
| No | Benign ovarian mass: 20 (33.3%) | | 2) uPAR:
| Test reliability established?: | Healthy controls: 20 (33.3%)
| Yes | Inclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 20 | 9 | 29
| Pearson correlation | Exclusion criteria: | | T- | 0 | 11 | 11
| Fisher's exact test | NR | | Tot | 20 | 20 | 40
| Blinding: NR
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Negatives defined as: | | | | Value | 95% CI | 95% CI
| uPAR: 0.1 ng/mL | | | Se | 100.0% | 85.0% | 100.0%
| c-erbB-2: +/1 | | | Sp | 55.0% | 33.2% | 76.8%
| CA-15.3: < 25 U/mL | | | PPV | 69.0% | 52.1% | 85.8%
| CA-125: < 35 U/mL | | | NPV | 100.0% | 72.7% | 100.0%
Makhlouf, Fathalla, Zakhary, et al., 2004 | Geographical location: | Age: | Screening only (n [%]): | 1) Sulfatides for predicting malignancy at cutoff of 57 μg/mg: | | | | Comments:
#1980 | Assiut, Egypt | Malignant: | Not applicable | | | | | None
| Study dates: | Mean: 50 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Mar 1998 – Apr 2000 | Range: 44.5–55 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 42 | 2 | 44 | Reference standard: +
| Size of population: | Benign: | Additional data used for diagnosis: | T- | 4 | 28 | 32 | Verification bias: +
| Ad hoc population | Mean: 27.5 | NR | Tot | 46 | 30 | 76 | Test reliability/variability: -
| 46 malignant | Range: 20–44 | | | | | | Sample size: -
| 16 benign | Control: | | | | Lower | Upper | Statistical tests: +
| 30 normal/controls | Mean: 45 | | | Value | 95% CI | 95% CI | Blinding: -
| Type of population: | Range: 40–49 | | Se | 91.3% | 83.2% | 99.4% | Definition of +/- on screening test: +
| Ad hoc | Menopausal status (n [%]): | | Sp | 93.3% | 84.4% | 100.0% | Grade: B
| Genomic test(s) used: | 41/92 (44%) | | PPV | 95.5% | 89.3% | 100.0%
| Sulfatides | Race/ethnicity (n [%]): | | NPV | 87.5% | 76.0% | 99.0%
| Reference standard: Surgical pathology | Egyptian 100%
| Reference standard applied to all test negatives?: | Risk factors (n [%]): | | 2) Sulfatides for predicting malignancy at cutoff of 91.3 μg/mg:
| Yes | NR
| Test reliability established?: | Diagnoses (n [%]): | | | Dis+ | Dis- | Tot
| NR | Ovarian cancer: 46 | | T+ | 45 | 0 | 45
| Statistical tests used: | Benign ovarian mass: 16 | | T- | 1 | 30 | 31
| Mann Whitney U | Healthy controls: 30 | | Tot | 46 | 30 | 76
| Kruskall Wallis | Inclusion criteria:
| Chi square | NR | | | | Lower | Upper
| Firshers | Exclusion criteria: | | | Value | 95% CI | 95% CI
| Blinding: NR | NR | | Se | 97.0% | 92.1% | 100.0%
| Definition of positive and negative on screening test: | | | Sp | 100.0% | 90.0% | 100.0%
| 57 μg/mg | | | PPV | 100.0% | 93.3% | 100.0%
| | | | NPV | 96.8% | 90.6% | 100.0%
McIntosh, Drescher, Karlan, et al., 2004 | Geographical location: | Age: NR | Screening only (n [%]): | 1) CA-125 - healthy controls: | | | | Comments:
#1410 | Seattle WA; Los Angeles, CA | Menopausal status (n [%]): | Not applicable | | | | | - Ad hoc population - sensitivity and specificity are artificial
| Study dates: NR | 225/315 (71%) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 41 | 4 | 45 | Reference standard: +
| 52 ovarian cancer | 3 Native American | Additional data used for diagnosis: | T- | 11 | 216 | 227 | Verification bias: +
| 43 benign | 8 Asian | NR | Tot | 52 | 220 | 272 | Test reliability/variability: -
| 220 healthy | 1 Black | | | | | | Sample size: +
| Type of population: | 4 Hispanic | | | | Lower | Upper | Statistical tests: +
| Ad hoc | 268 White | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | Risk factors (n [%]): | | Se | 78.8% | 67.7% | 89.9% | Definition of +/- on screening test: +
| CA-125 | NR | | Sp | 98.2% | 96.4% | 99.9% | Grade: B
| Soluble mesothelin-related marker | Diagnoses (n [%]): | | PPV | 91.1% | 82.8% | 99.4%
| Reference standard: | Ovarian cancer: 52 | | NPV | 95.2% | 92.4% | 97.9%
| Surgical pathology | Benign ovarian mass: 43
| Reference standard applied to all test negatives?: | Healthy controls: 220 | | 2) CA-125 - benign controls:
| Yes | Inclusion criteria:
| Test reliability established?: | NR | | | Dis+ | Dis- | Tot
| No | Exclusion criteria: | | T+ | 20 | 4 | 24
| Statistical tests used: | NR | | T- | 32 | 216 | 248
| Logistic Regression | | | Tot | 52 | 220 | 272
| ROC analysis
| Mann Witney U | | | | | Lower | Upper
| Wilcoxin | | | | Value | 95% CI | 95% CI
| Blinding: NR | | | Se | 38.5% | 25.2% | 51.7%
| Definition of positive and negative on screening test: | | | Sp | 98.2% | 96.4% | 99.9%
| Based on a fixed specificity of 98% | | | PPV | 83.3% | 68.4% | 98.2%
| | | | NPV | 87.1% | 82.9% | 91.3%
| | | | 3) SMR - healthy controls:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 31 | 4 | 35
| | | | T- | 21 | 216 | 237
| | | | Tot | 52 | 220 | 272
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 59.6% | 46.3% | 73.0%
| | | | Sp | 98.2% | 96.4% | 99.9%
| | | | PPV | 88.6% | 78.0% | 99.1%
| | | | NPV | 91.1% | 87.5% | 94.8%
| | | | 4) SMR - benign controls:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 15 | 4 | 19
| | | | T- | 37 | 216 | 253
| | | | Tot | 52 | 220 | 272
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 28.8% | 16.5% | 41.2%
| | | | Sp | 98.2% | 96.4% | 99.9%
| | | | PPV | 78.9% | 60.6% | 97.3%
| | | | NPV | 85.4% | 81.0% | 89.7%
| | | | 5) Combined SMR + CA-125 - healthy controls:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 45 | 4 | 49
| | | | T- | 7 | 216 | 223
| | | | Tot | 52 | 220 | 272
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 86.5% | 77.3% | 95.8%
| | | | Sp | 98.2% | 96.4% | 99.9%
| | | | PPV | 91.8% | 84.2% | 99.5%
| | | | NPV | 96.9% | 94.6% | 99.1%
| | | | 6) Combined SMR + CA-125 - benign controls:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 17 | 4 | 21
| | | | T- | 22 | 216 | 238
| | | | Tot | 39 | 220 | 259
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 43.6% | 28.0% | 59.2%
| | | | Sp | 98.2% | 96.4% | 99.9%
| | | | PPV | 81.0% | 64.2% | 97.7%
| | | | NPV | 90.8% | 87.1% | 94.4%
Medl, Ogris, Peters-Engl, et al., 1995 | Geographical location: | Age: | Screening only (n [%]): | 1) TATI > 21 ng/mL: | | | | Comments:
#8220 | Austria | Mean: 62.4 | NR | | | | | - Consecutive patients enrolled but not all had either disease or benign tumors; may not be true screening population
| Study dates: | Range: 23–87 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| May 1988 – Jun 1993 | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 75 | 67 | 142 | Reference standard: +
| Size of population: | NR | Additional data used for diagnosis: | T- | 40 | 200 | 240 | Verification bias: -
| 419 | Race/ethnicity (n [%]): | NR | Tot | 115 | 267 | 382 | Test reliability/variability: +
| Type of population: | Austrian 100% | | | | | | Sample size: +
| Screening | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Blinding: +
| CA-125 | Diagnoses (n [%]): | | Se | 65.2% | 56.5% | 73.9% | Definition of +/- on screening test: +
| Tumor-associated trypsin inhibitor (TATI) | Ovarian cancer: 152 | | Sp | 74.9% | 69.7% | 80.1% | Grade: B
| Reference standard: | Benign ovarian mass: 267 | | PPV | 52.8% | 44.6% | 61.0%
| Surgical pathology | Inclusion criteria: | | NPV | 83.3% | 78.6% | 88.0%
| Reference standard applied to all test negatives?: | NR
| NR | Exclusion criteria: | | 2) CA-125 > 35 U/mL:
| Test reliability established?: | NR
| Yes | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 90 | 59 | 149
| Se, Sp, PPV, NPV, ROC curves; Kruskal-Wallis test used for statistical analysis | | | T- | 25 | 208 | 233
| Blinding: Yes | | | Tot | 115 | 267 | 382
| Definition of positive and negative on screening test:
| TATI > 21 ng/mL | | | | | Lower | Upper
| CA-125 > 35 U/mL | | | | Value | 95% CI | 95% CI
| | | | Se | 78.3% | 70.7% | 85.8%
| | | | Sp | 77.9% | 72.9% | 82.9%
| | | | PPV | 60.4% | 52.5% | 68.3%
| | | | NPV | 89.3% | 85.3% | 93.2%
| | | | 3) CA-125 > 65 U/mL:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 79 | 23 | 102
| | | | T- | 36 | 244 | 280
| | | | Tot | 115 | 267 | 382
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 68.7% | 60.2% | 77.2%
| | | | Sp | 91.4% | 88.0% | 94.8%
| | | | PPV | 77.5% | 69.3% | 85.6%
| | | | NPV | 87.1% | 83.2% | 91.1%
| | | | 4) TATI > 21 ng/mL or CA-125 > 35 U/mL:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 105 | 105 | 210
| | | | T- | 10 | 162 | 172
| | | | Tot | 115 | 267 | 382
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.3% | 86.2% | 96.5%
| | | | Sp | 60.7% | 54.8% | 66.5%
| | | | PPV | 50.0% | 43.2% | 56.8%
| | | | NPV | 94.2% | 90.7% | 97.7%
| | | | 5) TATI > 21 ng/mL or CA-125 > 65 U/mL:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 98 | 85 | 183
| | | | T- | 17 | 182 | 199
| | | | Tot | 115 | 267 | 382
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 85.2% | 78.7% | 91.7%
| | | | Sp | 68.2% | 62.6% | 73.8%
| | | | PPV | 53.6% | 46.3% | 60.8%
| | | | NPV | 91.5% | 87.6% | 95.3%
Obermair, Tempfer, Hefler, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) VEGF - healthy/cancer: | | | | Comments:
#6690 | Austria | Median: 47 | NR | | | | | None
| Study dates: NR | Range: 21–79 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 24 | 19 | 43 | Reference standard: -
| 256 | NR | Additional data used for diagnosis: | T- | 20 | 62 | 82 | Verification bias: -
| Type of population: | Race/ethnicity (n [%]): | NR | Tot | 44 | 81 | 125 | Test reliability/variability: +
| Ad hoc | NR | | | | | | Sample size: +
| Genomic test(s) used: | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| Vascular endothelial growth factor | NR | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125 | Diagnoses (n [%]): | | Se | 54.5% | 39.8% | 69.3% | Definition of +/- on screening test: +
| Reference standard: | Ovarian cancer: 44 | | Sp | 76.5% | 67.3% | 85.8% | Grade: B
| Surgical pathology | Benign ovarian mass: 81 | | PPV | 55.8% | 41.0% | 70.7%
| Reference standard applied to all test negatives?: | Healthy controls: 131 | | NPV | 75.6% | 66.3% | 84.9%
| Unable to determine | Inclusion criteria:
| Test reliability established?: | NR | | 2) CA-125:
| Yes | Exclusion criteria:
| Statistical tests used: | NR | | | Dis+ | Dis- | Tot
| Logistic Regression | | | T+ | 37 | 6 | 43
| ROC curves | | | T- | 7 | 75 | 82
| Blinding: NR | | | Tot | 44 | 81 | 125
| Definition of positive and negative on screening test:
| VEGF - 363.7 pg/ml | | | | | Lower | Upper
| CA-125 - 74.9 U/ml | | | | Value | 95% CI | 95% CI
| | | | Se | 84.1% | 73.3% | 94.9%
| | | | Sp | 92.6% | 86.9% | 98.3%
| | | | PPV | 86.0% | 75.7% | 96.4%
| | | | NPV | 91.5% | 85.4% | 97.5%
Oehler and Caffier, 1999 | Geographical location: | Ovarian CA patients | Screening only (n [%]): | 1) VEGF - ovarian cancer and normal controls: | | | | Comments:
#5560 | Wurzburg, Germany; Houston, TX | Age: | NR | | | | | - Ad hoc population
| Study dates: NR | Mean: 60 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 32–83 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 30 | 6 | 36 | Reference standard: +
| 41 cancers | Menopausal status (n [%]): | Additional data used for diagnosis: | T- | 11 | 14 | 25 | Verification bias: -
| 20 benign tumors | NR | NR | Tot | 41 | 20 | 61 | Test reliability/variability: +
| 20 normal controls | Race/ethnicity (n [%]): | | | | | | Sample size: -
| Type of population: | NR | | | | Lower | Upper | Statistical tests: +
| Ad hoc | Risk factors (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | NR | | Se | 73.2% | 59.6% | 86.7% | Definition of +/- on screening test: +
| VEGF | Diagnoses (n [%]): | | Sp | 70.0% | 49.9% | 90.1% | Grade: B
| Reference standard: | Ovarian cancer: 41 | | PPV | 83.3% | 71.2% | 95.5%
| Surgical pathology | Benign ovarian mass: 20 | | NPV | 56.0% | 36.5% | 75.5%
| Reference standard applied to all test negatives?: | Healthy controls: 20
| No | Inclusion criteria: | | 2) VEGF - ovarian cancer and benign tumors:
| Test reliability established?: | NR
| Yes | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Statistical tests used: | NR | | T+ | 29 | 7 | 36
| Kruskal-Wallis | | | T- | 12 | 13 | 25
| Mann-Whitney U | | | Tot | 41 | 20 | 61
| ROC curve
| Blinding: NR | | | | | Lower | Upper
| Definition of positive and negative on screening test: | | | | Value | 95% CI | 95% CI
| 300 pg/mL | | | Se | 70.7% | 56.8% | 84.7%
| | | | Sp | 65.0% | 44.1% | 85.9%
| | | | PPV | 80.6% | 67.6% | 93.5%
| | | | NPV | 52.0% | 32.4% | 71.6%
Onsrud, Shabana, and Austgulen, 1996 | Geographical location: | Age: | Screening only (n [%]): | Note: All tables are for ovarian cancer versus benign tumors. | | | | Comments:
#7710 | Trondhiem, Norway | Ovarian cancer: | NR | 1) p55: | | | | None
| Study dates: NR | Median: 58 | Diagnosis of mass: | | | | | Quality assessment:
| Size of population: | Range: 21–80 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| 45 - cancer | Benign tumors: | Additional data used for diagnosis: | T+ | 26 | 3 | 29 | Verification bias: -
| 27 - benign pelvic masses | Median: 45 | NR | T- | 19 | 24 | 43 | Test reliability/variability: -
| 26 - controls | Range: 19–67 | | Tot | 45 | 27 | 72 | Sample size: -
| Type of population: | Normal controls: | | | | | | Statistical tests: +
| Ad hoc | Median: 39 | | | | Lower | Upper | Blinding: -
| Genomic test(s) used: | Range: 27–76 | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| p55 | Menopausal status (n [%]): | | Se | 57.8% | 43.3% | 72.2% | Grade: B
| p75 | NR | | Sp | 88.9% | 77.0% | 100.0%
| CA-125 | Race/ethnicity (n [%]): | | PPV | 89.7% | 78.6% | 100.0%
| Reference standard: | NR | | NPV | 55.8% | 41.0% | 70.7%
| Surgical pathology | Risk factors (n [%]):
| Reference standard applied to all test negatives?: | NR | | 2) p75:
| Yes | Diagnoses (n [%]):
| Test reliability established?: | Ovarian cancer: 45 | | | Dis+ | Dis- | Tot
| No | Benign ovarian mass: 27 | | T+ | 7 | 1 | 8
| Statistical tests used: | Healthy controls: 26 | | T- | 38 | 26 | 64
| Wilcoxin rank sum | Inclusion criteria: | | Tot | 45 | 27 | 72
| Blinding: NR | Patients undergoing laparotomy surgery
| Definition of positive and negative on screening test: | Exclusion criteria: | | | | Lower | Upper
| Mean + 2 SD of the control women for all three tests: | NR | | | Value | 95% CI | 95% CI
| p55 = 2.0 ng/mL | | | Se | 15.6% | 5.0% | 26.1%
| p75 = 4.3 ng/mL | | | Sp | 96.3% | 89.2% | 100.0%
| CA-125 = 20 U/mL | | | PPV | 87.5% | 64.6% | 100.0%
| | | | NPV | 40.6% | 28.6% | 52.7%
| | | | 3) CA-125:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 37 | 4 | 41
| | | | T- | 8 | 23 | 31
| | | | Tot | 45 | 27 | 72
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 82.2% | 71.1% | 93.4%
| | | | Sp | 85.2% | 71.8% | 98.6%
| | | | PPV | 90.2% | 81.2% | 99.3%
| | | | NPV | 74.2% | 58.8% | 89.6%
| | | | Note: NPV calculated here does not match the 72% reported in the paper.
| | | | 4) p55 + CA-125:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 38 | 6 | 44
| | | | T- | 7 | 21 | 28
| | | | Tot | 45 | 27 | 72
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.4% | 73.9% | 95.0%
| | | | Sp | 77.8% | 62.1% | 93.5%
| | | | PPV | 86.4% | 76.2% | 96.5%
| | | | NPV | 74.2% | 58.8% | 89.6%
Opala, Drews, Rzymski, et al., 2003 | Geographical location: | Age: | Screening only (n [%]): | Note: All tables are for ovarian cancer vs. healthy controls. | | | | Comments:
#2650 | Poznan, Poland | Cancer: | NR | 1) sICAM-1: | | | | - Majority of analyses applied to women with malignancies; - Unable to determine specificity for CA-125; - Same patient population as Opala et al., 2005 (#480)
| Study dates: | Mean (SD): 51.5 (11.5) | Diagnosis of mass: | | | | | Quality assessment:
| Jun 2000 – Nov 2002 | Range: 23–80 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| Size of population: | Borderline: | Additional data used for diagnosis: | T+ | 42 | 7 | 49 | Verification bias: -
| 101 with suspicious tumors | Mean (SD): 46.0 (15.8) | NR | T- | 9 | 9 | 18 | Test reliability/variability: -
| 16 healthy women | Range: 25–62 | | Tot | 51 | 16 | 67 | Sample size: -
| Type of population: | Benign: | | | | | | Statistical tests: +
| Ad hoc | Mean (SD): 39.4 (14.3) | | | | Lower | Upper | Blinding: -
| Genomic test(s) used: | Range: 13–71 | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| Soluble intracellular adhesion molecule-1 | Normal: | | Se | 82.4% | 71.9% | 92.8% | Grade: C
| Reference standard: | Mean (SD): 27.8 (12.6) | | Sp | 56.3% | 31.9% | 80.6%
| Surgical pathology | Range: 20–63 | | PPV | 85.7% | 75.9% | 95.5%
| Reference standard applied to all test negatives?: | Menopausal status (n [%]): | | NPV | 50.0% | 26.9% | 73.1%
| NR | NR
| Test reliability established?: | Race/ethnicity (n [%]): | | Note: Numbers do not match those reported in the article.
| Yes | NR | | 2) CA-125:
| Statistical tests used: | Risk factors (n [%]):
| Mann Witney U | NR | | | Dis+ | Dis- | Tot
| Spearman | Diagnoses (n [%]): | | T+ | 48 | 4 | 52
| Pearson | Ovarian cancer: 51 | | T- | 3 | 12 | 15
| Blinding: NR | Borderline: 5 | | Tot | 51 | 16 | 67
| Definition of positive and negative on screening test: | Benign ovarian mass: 45
| CA-125 = 35 U/mL | Healthy controls: 16 | | | | Lower | Upper
| sICAM-1 = 250 ng/mL | Inclusion criteria: | | | Value | 95% CI | 95% CI
| | Women treated surgically b/c of suspicious pelvic tumors | | Se | 93.8% | 87.2% | 100.0%
| | Exclusion criteria: | | Sp | 74.5% | 53.1% | 95.9%
| | NR | | PPV | 92.3% | 85.1% | 99.6%
| | | | NPV | 80.0% | 59.8% | 100.0%
| | | | Note: Numbers do not match those reported in the article.
| | | | (3) sICAM-I + CA-125:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 48 | 2 | 50
| | | | T- | 3 | 14 | 17
| | | | Tot | 51 | 16 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 93.8% | 87.2% | 100.0%
| | | | Sp | 86.3% | 69.5% | 100.0%
| | | | PPV | 96.0% | 90.6% | 100.0%
| | | | NPV | 82.4% | 64.2% | 100.0%
| | | | Note: Numbers do not match those reported in the article.
Opala, Rzymski, Wildzak, et al., 2005 | Geographical location: | Age: | Screening only (n [%]): | 1) p55: | | | | Comments:
#480 | Poznan, Poland | Cancer: | NR | | | | | - Cutpoint established using cancer versus controls; - Ad hoc population; - Same patient population as Opala et al., 2003 (#2650)
| Study dates: | Mean (SD): 51.5 (11.5) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Jun 2000 – Nov 2002 | Range: 23–80 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 28 | 1 | 29 | Reference standard: +
| Size of population: | Borderline: | Additional data used for diagnosis: | T- | 23 | 15 | 38 | Verification bias: -
| 101 with suspicious tumors | Mean (SD): 46.0 (15.8) | NR | Tot | 51 | 16 | 67 | Test reliability/variability: +
| 16 healthy women | Range: 25–62 | | | | | | Sample size: -
| Type of population: | Benign: | | | | Lower | Upper | Statistical tests: +
| Ad hoc | Mean (SD): 39.4 (14.3) | | | Value | 95% CI | 95% CI | Blinding: -
| Genomic test(s) used: | Range: 13–71 | | Se | 54.9% | 41.2% | 68.6% | Definition of +/- on screening test: +
| p55 | Normal: | | Sp | 93.8% | 81.9% | 100.0% | Grade: C
| p75 | Mean (SD): 27.8 (12.6) | | PPV | 96.6% | 89.9% | 100.0%
| CA-125 | Range: 20–63 | | NPV | 39.5% | 23.9% | 55.0%
| Reference standard applied to all test negatives?: | Menopausal status (n [%]):
| No | NR | | 2) p75:
| Test reliability established?: | Race/ethnicity (n [%]):
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | Risk factors (n [%]): | | T+ | 22 | 3 | 25
| Mann Withney U | NR | | T- | 29 | 13 | 42
| ROC curves | Diagnoses (n [%]): | | Tot | 51 | 16 | 67
| Correlation coefficients | Ovarian cancer: 51
| Blinding: NR | Borderline: 5 | | | | Lower | Upper
| Definition of positive and negative on screening test: | Benign ovarian mass: 45 | | | Value | 95% CI | 95% CI
| p55: 1663 pg/mL | Healthy controls: 16 | | Se | 43.1% | 29.5% | 56.7%
| p75: 2837 pg/mL | Inclusion criteria: | | Sp | 81.3% | 62.1% | 100.0%
| CA-125: 35 U/mL | Women treated surgically b/c of suspicious pelvic tumors | | PPV | 88.0% | 75.3% | 100.0%
| | Exclusion criteria: | | NPV | 31.0% | 17.0% | 44.9%
| | NR
| | | | 3) CA-125:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 38 | 1 | 39
| | | | T- | 13 | 15 | 28
| | | | Tot | 51 | 16 | 67
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 74.5% | 62.5% | 86.5%
| | | | Sp | 93.8% | 81.9% | 100.0%
| | | | PPV | 97.4% | 92.5% | 100.0%
| | | | NPV | 53.6% | 35.1% | 72.0%
Peters-Engl, Medl, Ogris, et al., 1995 | Geographical location: | Age: | Screening only (n [%]): | 1) TATI: | | | | Comments:
#7840 | Vienna, Austria | Mean: 62.4 | NR | | | | | None
| Study dates: NR | Range: 23–87 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Menopausal status (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 114 | 60 | 174 | Reference standard: +
| 180 ovarian cancer | NR | Additional data used for diagnosis: | T- | 66 | 154 | 220 | Verification bias: +
| 214 with benign pelvic disease | Race/ethnicity (n [%]): | NR | Tot | 180 | 214 | 394 | Test reliability/variability: +
| Type of population: | Austrian 100% | | | | | | Sample size: +
| Ad hoc | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Blinding: +
| TATI | Diagnoses (n [%]): | | Se | 63.3% | 56.3% | 70.4% | Definition of +/- on screening test: +
| CA-125 | Ovarian cancer: 180 | | Sp | 72.0% | 65.9% | 78.0% | Grade: A
| Reference standard: | Benign ovarian mass: 214 | | PPV | 65.5% | 58.5% | 72.6%
| Surgical pathology | Healthy controls: 149 - used for determination of cutpoint only | | NPV | 70.0% | 63.9% | 76.1%
| Reference standard applied to all test negatives?: | Inclusion criteria:
| Yes | NR | | 2) CA-125:
| Test reliability established?: | Exclusion criteria:
| Yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 144 | 39 | 183
| “Non parametric test” | | | T- | 36 | 175 | 211
| Blinding: Yes | | | Tot | 180 | 214 | 394
| Definition of positive and negative on screening test:
| TATI: 21 ng/ml | | | | | Lower | Upper
| CA-125: 35 U/ml | | | | Value | 95% CI | 95% CI
| | | | Se | 80.0% | 74.2% | 85.8%
| | | | Sp | 81.8% | 76.6% | 86.9%
| | | | PPV | 78.7% | 72.8% | 84.6%
| | | | NPV | 82.9% | 77.9% | 88.0%
| | | | 3) CA-125 + TATI:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 164 | 75 | 239
| | | | T- | 16 | 139 | 155
| | | | Tot | 180 | 214 | 394
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 91.1% | 87.0% | 95.3%
| | | | Sp | 65.0% | 58.6% | 71.3%
| | | | PPV | 68.6% | 62.7% | 74.5%
| | | | NPV | 89.7% | 84.9% | 94.5%
Schutter, Mijatovic, Kok, et al., 1999 | Geographical location: | Age: NR | Screening only (n [%]): | 1) Ability of UGP >1 fmol/L to discriminate ovarian carcinoma from all benign gynecologic conditions (both benign masses and controls): | | | | Comments:
#5950 | Amsterdam, The Netherlands | Menopausal status (n [%]): | NR | | | | | - Only 9 cancers.; - For purposes of deciding whether this marker is better as a screening test or a diagnostic test it would be preferable to see the performance for discriminating cancers from other masses or cancers versus healthy controls, instead of mixing them together. Would also be preferable to differentiate ovarian benign masses from uterine benign masses.
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 7 | 7 | 14 | Reference standard: +
| 31 | Risk factors (n [%]): | Additional data used for diagnosis: | T- | 2 | 14 | 16 | Verification bias: +
| Type of population: | NR | NR | Tot | 9 | 21 | 30 | Test reliability/variability: -
| Malignant and non-malignant disease | Diagnoses (n [%]): | | | | | | Sample size: -
| Genomic test(s) used: | Ovarian cancer: 9 | | | | Lower | Upper | Statistical tests: +
| UGP (urinary gonadotropin peptide) | Benign ovarian or uterine mass: 10 | | | Value | 95% CI | 95% CI | Blinding: -
| UGP/Cr | Other benign controls: 12 | | Se | 78.0% | 50.9% | 100.0% | Definition of +/- on screening test: +
| CA-125 | - Sterilization: 3; - Refertilization (?): 2; - Prolapse: 2; - DUB: 2; - Endometriosis: 2; - Sterility: 1 | | Sp | 65.0% | 44.6% | 85.4% | Grade: B
| Reference standard: | Inclusion criteria: | | PPV | 50.0% | 23.8% | 76.2%
| Surgical pathology | Scheduled for surgery due to a gynecologic condition | | NPV | 87.5% | 71.3% | 100.0%
| Reference standard applied to all test negatives?: | Exclusion criteria:
| Yes | NR | | 2) Ability of UGP/creat > 1.33 fmol/mg to discriminate ovarian arcinoma from all benign gynecologic conditions (both benign masses and controls). Note: same numbers as first table:
| Test reliability established?:
| No (except CA-125) | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 7 | 7 | 14
| Se, Se, ROC | | | T- | 2 | 14 | 16
| Blinding: NR | | | Tot | 9 | 21 | 30
| Definition of positive and negative on screening test:
| UGP > 1 fmol/L is positive | | | | | Lower | Upper
| UGP/creat > 1.33 fmol/mg positive | | | | Value | 95% CI | 95% CI
| CA-125 > 100 U/mL positive | | | Se | 78.0% | 50.9% | 100.0%
| | | | Sp | 65.0% | 44.6% | 85.4%
| | | | PPV | 50.0% | 23.8% | 76.2%
| | | | NPV | 87.5% | 71.3% | 100.0%
Schutter, Sohn, Kristen, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) CA-72-4, ovarian cancer versus benign masses, cutoff 2 U/mL: | | | | Comments:
#6850 | Amsterdam, The Netherlands | Mean: 63 | NR | | | | | - No healthy controls - all patients had either malignant or non-malignant pathology
| Study dates: NR | Median: 61 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 45–88 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 36 | 42 | 78 | Reference standard: +
| 155 | Menopausal status (n [%]): | Additional data used for diagnosis: | T- | 7 | 50 | 57 | Verification bias: +
| Type of population: | Post (> 55): 155 (100%) | NR | Tot | 43 | 92 | 135 | Test reliability/variability: +
| Adnexal mass | Race/ethnicity (n [%]): NR | | | | | | Sample size: +
| Genomic test(s) used: | Risk factors (n [%]): | | | | Lower | Upper | Statistical tests: +
| CA 72-4 | NR | | | Value | 95% CI | 95% CI | Blinding: NR
| CA-125 | Diagnoses (n [%]): | | Se | 84.0% | 73.0% | 95.0% | Definition of +/- on screening test: +
| Reference standard: | Ovarian cancer: 43 (27%) | | Sp | 54.0% | 43.8% | 64.2% | Grade: A
| Surgical pathology | Borderline: 4 (3%) | | PPV | 46.2% | 35.1% | 57.2%
| Reference standard applied to all test negatives?: | Benign ovarian mass: 92 (59%) | | NPV | 87.7% | 79.2% | 96.2%
| Yes | Other (non-ovarian malignancies): 16 (10%)
| Test reliability established?: | Inclusion criteria: | | 2) CA-72-4, ovarian cancer versus benign masses, cutoff 3 U/mL:
| Yes | Plan to undergo surgery for a pelvic mass, postmenopausal
| Statistical tests used: Se, Sp, PPV, NPV, ROC, logistic regression (incorporating ultrasound score) | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Blinding: NR | Exclusion criteria not defined in this paper, reader is referred to Reference #1. | | T+ | 28 | 6 | 34
| Definition of positive and negative on screening test: | | | T- | 15 | 86 | 101
| CA-125 < 35 u/mL normal | | | Tot | 43 | 92 | 135
| CA-72-4 < 3 normal
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 65.0% | 50.7% | 79.3%
| | | | Sp | 93.0% | 87.8% | 98.2%
| | | | PPV | 82.4% | 69.5% | 95.2%
| | | | NPV | 85.1% | 78.2% | 92.1%
| | | | For CA-72-4 with cutoff 3.2 U/mL, Se = 65, Sp = 95, PPV = 85, NPV = 85.
Sedlaczek, Frydecka, Gabrys, et al., 2002 | Geographical location: | Age: NR | Screening only (n [%]): | 1) TPS serum - ovarian cancer vs. benign ovarian mass: | | | | Comments:
#3310 | Wroclaw, Poland | Menopausal status (n [%]): | NR | | | | | - TPS levels are elevated in cyst fluid of all patients with benign disease (Sp = 0); - No data on levels in ascites of patients with benign disease (cant calculate specificity)
| Study dates: NR | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 53 | 6 | 59 | Reference standard: +
| 99 | NR | Additional data used for diagnosis: | T- | 14 | 26 | 40 | Verification bias: +
| Type of population: | Risk factors (n [%]): | NR | Tot | 67 | 32 | 99 | Test reliability/variability: Unclear
| Adnexal mass | NR | | | | | | Sample size: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| TPS, sIL-2R, CA-125 | Ovarian cancer: 67 (67%) | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard | Benign ovarian mass: 32 (32%) | | Se | 79.1% | 69.4% | 88.8% | Definition of +/- on screening test: +
| Surgical pathology | Inclusion criteria: Planned surgery for ovarian mass | | Sp | 81.3% | 67.7% | 94.8% | Grade: B
| Reference standard applied to all test negatives?: | Exclusion criteria: | | PPV | 89.8% | 82.1% | 97.5%
| Yes | NR | | NPV | 65.0% | 50.2% | 79.8%
| Test reliability established?:
| Yes | | | 2) sIL-2R serum - ovarian cancer vs. benign ovarian mass:
| Statistical tests used:
| Mann-Whitney U, Wilcoxon | | | | Dis+ | Dis- | Tot
| Blinding: NR | | | T+ | 54 | 1 | 55
| Definition of positive and negative on screening test: | | | T- | 13 | 31 | 44
| CA-125 < 35 U/mL normal | | | Tot | 67 | 32 | 99
| TPS < 80 U/mL normal
| sIL-2R < 2140 pg/nl normal | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 80.6% | 71.1% | 90.1%
| | | | Sp | 96.9% | 90.8% | 100.0%
| | | | PPV | 98.2% | 94.7% | 100.0%
| | | | NPV | 70.5% | 57.0% | 83.9%
| | | | 3) TPS cyst fluid - ovarian cancer vs. benign ovarian mass:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 26 | 32 | 58
| | | | T- | 0 | 0 | 0
| | | | Tot | 26 | 32 | 58
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 88.5% | 100.0%
| | | | Sp | 0.0% | 0.0% | 0.0%
| | | | PPV | 44.8% | 32.0% | 57.6%
| | | | NPV | #DIV/0! | #DIV/0! | #DIV/0!
| | | | 4) sIL-2R cyst fluid - ovarian cancer vs. benign ovarian mass:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 21 | 4 | 25
| | | | T- | 5 | 28 | 33
| | | | Tot | 26 | 32 | 58
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 80.8% | 65.6% | 95.9%
| | | | Sp | 87.5% | 76.0% | 99.0%
| | | | PPV | 84.0% | 69.6% | 98.4%
| | | | NPV | 84.8% | 72.6% | 97.1%
| | | | 5) TPS ascites - ovarian cancer vs. benign ovarian mass:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 45 | 0 | 45
| | | | T- | 0 | 0 | 0
| | | | Tot | 45 | 0 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 93.3% | 100.0%
| | | | Sp | #DIV/0! | #DIV/0! | #DIV/0!
| | | | PPV | 100.0% | 93.3% | 100.0%
| | | | NPV | #DIV/0! | #DIV/0! | #DIV/0!
| | | | 6) sIL-2R ascites - ovarian cancer vs. benign ovarian mass:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 44 | 0 | 44
| | | | T- | 1 | 0 | 1
| | | | Tot | 45 | 0 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 97.8% | 93.5% | 100.0%
| | | | Sp | #DIV/0! | #DIV/0! | #DIV/0!
| | | | PPV | 100.0% | 93.2% | 100.0%
| | | | NPV | 0.0% | 0.0% | 0.0%
Skates, Horick, Yu, et al., 2004 | Geographical location: | Age: NR | Screening only (n [%]): | Models including all 4 markers. | | | | Comments:
#1380 | Boston, MA; Houston, TX; Durham, NC; Baltimore, MD; Groningen, The Netherlands; London, UK | Menopausal status (n [%]): | NR | 1) Logistic regression, cancer vs. control. Note: 95% CIs may not reflect 95% CI estimates based on statistical model; CIs not reported: | | | | - Very high prevalence of cancer in both test and validation sets; - 95% CIs for estimates of sensitivity/specificity with each statistical method not presented uniformly
| Study dates: NR | NR | Diagnosis of mass: | | | | | Quality assessment:
| Size of population: | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| 189 (training set); 158 (validation set) | NR | Additional data used for diagnosis: | T+ | 41 | 2 | 43 | Verification bias: +
| Type of population | Risk factors (n [%]): | NR | T- | 19 | 96 | 115 | Test reliability/variability: +
| Known cases of cancer, healthy controls | NR | | Tot | 60 | 98 | 158 | Sample size: -
| Genomic test(s) used: | Diagnoses (n [%]): | | | | | | Statistical tests: +
| CA-125 II | Ovarian cancer: 60 (38.0%) | | | | Lower | Upper | Blinding: +
| CA-15-3 | Healthy controls: 98 (62.0%) | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| CA-72-4 | Inclusion criteria: | | Se | 68.0% | 56.2% | 79.8% | Grade: B
| Macrophage colony-stimulating factor (M-CSF) | NR | | Sp | 98.0% | 95.2% | 100.0%
| Reference standard | Exclusion criteria: | | PPV | 95.3% | 89.1% | 100.0%
| Surgical pathology for cancer; not specified for controls | NR | | NPV | 83.5% | 76.7% | 90.3%
| Reference standard applied to all test negatives?:
| Unclear | | | 2) CART, cancer vs. control. Note: 95% CIs may not reflect 95% CI estimates based on statistical model; CIs not reported:
| Test reliability established?:
| Referenced | | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 21 | 2 | 23
| Logistic regression using results from multiple markers; CART trees; mixture discriminant analysis | | | T- | 39 | 96 | 135
| Blinding: NR | | | Tot | 60 | 98 | 158
| Definition of positive and negative on screening test:
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 35.0% | 22.9% | 47.1%
| | | | Sp | 98.0% | 95.2% | 100.0%
| | | | PPV | 91.3% | 79.8% | 100.0%
| | | | NPV | 71.1% | 63.5% | 78.8%
| | | | 3) MDA, cancer vs. control. Note: 95% CIs may not reflect 95% CI estimates based on statistical model; CIs not reported:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 41 | 2 | 43
| | | | T- | 19 | 96 | 115
| | | | Tot | 60 | 98 | 158
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 68.0% | 56.2% | 79.8%
| | | | Sp | 98.0% | 95.2% | 100.0%
| | | | PPV | 95.3% | 89.1% | 100.0%
| | | | NPV | 83.5% | 76.7% | 90.3%
| | | | 4) Possible additional 2×2 tables:
| | | | Combinations of markers at 98% specificity:
| | | | CA-125 II + CA-72.4: Se 67%
| | | | CA-125 II + CA-72-4 +M-CSF: Se 70%
| | | | CA-125 II + CA-72-4 +M-CSF + CA-15-3: Se 68%
| | | | Additional 2×2 tables possible for some models, but at specificity fixed at 95%.
| | | | 5) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Single marker sensitivities all lower at fixed specificity.
Takano, Okamoto, Fukushima, et al., 2000 | Geographical location: | Age: | Screening only (n [%]): | 1) CK19 expression in PBMCs - ovarian cancer vs. benign ovarian tumors: | | | | Comments:
#4960 | Tokyo, Japan | NR | NR | | | | | - No definition of positive or negative expression provided; must assume the ability to detect any expression with PCR is the cutoff.; - Authors note poor performance of this test to distinguish cancers from controls or benign tumors.
| Study dates: NR | Menopausal status (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 21 | 10 | 31 | Reference standard: -
| 59 | Race/ethnicity (n [%]): | Additional data used for diagnosis: | T- | 4 | 4 | 8 | Verification bias: -
| Type of population: | NR | NR | Tot | 25 | 14 | 39 | Test reliability/variability: -
| Ovarian cancer, benign ovarian tumor, or healthy control | Risk factors (n [%]): | | | | | | Sample size: -
| Genomic test(s) used: | NR | | | | Lower | Upper | Statistical tests: -
| CK19 expression in peripheral blood mononuclear cells (PBMCs) | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Ovarian cancer: 25 (42%) | | Se | 84.0% | 69.6% | 98.4% | Definition of +/- on screening test: -
| Surgical pathology (not specified but assumed) | Benign ovarian mass: 14 (24%) | | Sp | 28.6% | 4.9% | 52.2% | Grade: C
| Reference standard applied to all test negatives?: | Healthy controls: 20 (34%) | | PPV | 67.7% | 51.3% | 84.2%
| No | Inclusion criteria: | | NPV | 50.0% | 15.4% | 84.6%
| Test reliability established?: | NR
| No | Exclusion criteria: | | 2) CK19 expression in PBMCs - ovarian cancer vs. healthy controls:
| Statistical tests used: | NR
| Not applicable | | | | Dis+ | Dis- | Tot
| Blinding: NR | | | T+ | 21 | 12 | 33
| Definition of positive and negative on screening test: | | | T- | 4 | 8 | 12
| Not given (any present versus none present is assumed based on reading paper) | | | Tot | 25 | 20 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.0% | 69.6% | 98.4%
| | | | Sp | 40.0% | 18.5% | 61.5%
| | | | PPV | 63.6% | 47.2% | 80.0%
| | | | NPV | 66.7% | 40.0% | 93.3%
Tanir, Ozalp, Yalcin, et al., 2003 | Geographical location: | Age: | Screening only (n [%]): | 1) Serum VEGF cutoff 68.7 pg/mL - benign and non-neoplastic versus malignant ovarian masses. | | | | Comments:
#2630 | Eskisehir, Turkey | Non-neoplastic: | NR | Se 92, Sp 88, LR(+) 3.3, LR(-) 0.11 | | | | - Small n limits clinical interpretation of results
| Study dates: | Mean (SD): 39 (± 2) | Diagnosis of mass: | | | | | Quality assessment:
| Aug 2001–Sep 2002 | Neoplastic: | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| Size of population: | Mean (SD): 56.9 (± 4.2) | Additional data used for diagnosis: Among post-menopausal women, used tumor volume, solid/cystic appearance, presence and thickness of septa, uni-or bilaterality, intratumoral papillary excrescences to determine malignancy of mass | T+ | 11 | 6 | 17 | Verification bias: -
| 63 | Menopausal status (n [%]): | | T- | 1 | 44 | 45 | Test reliability/variability: -
| Type of population: | Pre (< 45): 40 (63%) | | Tot | 12 | 50 | 62 | Sample size: -
| Adnexal mass | Post (> 55): 23 (37%) | | | | | | Statistical tests: +
| Genomic test(s) used: | Race/ethnicity (n [%]): | | | | Lower | Upper | Blinding: -
| Serum VEGF | NR | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| Reference standard: | Risk factors (n [%]): | | Se | 91.7% | 76.0% | 100.0% | Grade: C
| Surgical pathology | NR | | Sp | 88.0% | 79.0% | 97.0%
| Reference standard applied to all test negatives?: | Diagnoses (n [%]): | | PPV | 64.7% | 42.0% | 87.4%
| Yes | Ovarian cancer (group III): 12 (19.3%) | | NPV | 97.8% | 93.5% | 100.0%
| Test reliability established?: | Non-neoplastic benign (group I): 40 (64.5%)
| No | Neoplastic benign (group II): 10 (16.1%) | | 2) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| Statistical tests used: Se, Sp, ROC, positive and negative likelihood ratios | Inclusion criteria: | | AUC for VEGF = 0.938 (95% CI 0.81 to 0.96).
| Blinding: NR | Pelvic mass, planned surgery | | AUC for VEGF (postmenopausal only) = 0.902 (0.70 to 0.98).
| Definition of positive and negative on screening test: | Exclusion criteria:
| 68.7 pg/mL was proposed, as it had best Se, Sp (different cutoffs were examined) | NR
Tempfer, Hefler, Heinzl, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) CYFRA 21-1 cutoff 4.7 mcg/L - ovarian cancer vs. healthy controls: Se 41%, Sp 95%. | | | | Comments:
#6560 | Vienna, Austria | Median: 57.9 (cancer patients), 31.3 (healthy controls) | NR | | | | | - Cancers and controls were not age-matched.; - No cutoffs were established for CYFRA 21-1 and not enough data given to re-create the Se and Sp.
| Study dates: NR | Menopausal status (n [%]): | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 15 | 2 | 17 | Reference standard: -
| 175 | Race/ethnicity (n [%]): | Additional data used for diagnosis: | T- | 22 | 38 | 60 | Verification bias: - (apparently healthy controls didn't have surgery to check for ovarian cancer, and no follow up was specified for them)
| Type of population: | NR | NR | Tot | 37 | 40 | 77 | Test reliability/variability: +
| Adnexal mass | Risk factors (n [%]): | | | | | | Sample size: +
| Other benign conditions | NR | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| CYFRA 21-1 | Ovarian cancer: 37 (21%) | | Se | 40.5% | 24.7% | 56.4% | Definition of +/- on screening test: -
| Reference standard: | Other: | | Sp | 95.0% | 88.2% | 100.0% | Grade: C
| Surgical pathology | - Benign cyst: 90 (51%); - Endometriosis: 10 (6%); - PID: 38 (22%); - Healthy controls: 40 (23%); - Inflammatory bowel disease: 10 (6%); - Cirrhosis: 20 (11%) | | PPV | 88.2% | 72.9% | 100.0%
| Clinical outcome (some patients had known benign conditions and were not operative candidates) | Inclusion criteria: | | NPV | 63.3% | 51.1% | 75.5%
| Reference standard applied to all test negatives?: | Surgery for a pelvic mass, healthy controls, and controls with non-malignant diseases
| N/A | Exclusion criteria: | | 2) CYFRA 21-1 - ovarian cancer vs. benign ovarian cyst:
| Test reliability established?: | NR | | AUC = 0.86. Individual cutoffs not given.
| No | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| Statistical tests used: Se, Sp, ROC curves | | | Intra-assay correlation coefficient is 6.5% at a concentration of 3 mcg/L CYFRA 21-1.
| Blinding: NR
| Definition of positive and negative on screening test:
| CYFRA 21-1 level of 4.7 mcg/L was used to report Se, Sp
Tsukishiro, Suzumori, Nishikawa, et al., 2005 | Geographical location: | Age: | Screening only (n [%]): | 1) SLPI cutoff 50 ng/mL - ovarian cancer vs. benign cysts: | | | | Comments:
#870 | Nagoya, Japan | Malignant: | NR | | | | | Quality assessment:
| Study dates: | Mean (SD): 54 (1.8) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Reference standard: + (except healthy controls)
| 1997-2004 | Benign: | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 42 | 5 | 47 | Verification bias: + (except healthy controls)
| Size of population: | Mean (SD): 50 (4.3) | Additional data used for diagnosis: | T- | 13 | 20 | 33 | Test reliability/variability: - no info
| 118 | Control: | NR | Tot | 55 | 25 | 80 | Sample size: +
| Type of population: | Mean (SD): 49 (4.8) | | | | | | Statistical tests: +
| Adnexal mass | Menopausal status (n [%]): | | | | Lower | Upper | Blinding: -
| Healthy controls | Pre (< 50): 14 | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| Genomic test(s) used: | Post (> 50): 41 | | Se | 76.0% | 64.7% | 87.3% | Grade: B
| Secretory leukocyte protease inhibitor (SLPI) | Race/ethnicity (n [%]): NR | | Sp | 80.0% | 64.3% | 95.7%
| Reference standard: | Risk factors (n [%]): | | PPV | 89.4% | 80.5% | 98.2%
| Surgical pathology | NR | | NPV | 60.6% | 43.9% | 77.3%
| Reference standard applied to all test negatives?: | Diagnoses (n [%]):
| All except healthy controls | Ovarian cancer: 55 (47%) | | 2) SLPI > 50 ng/mL and CA-125 > 30 U/mL - ovarian cancer vs. benign ovarian cysts:
| Test reliability established?: | Benign ovarian mass: 25 (21%)
| No | Healthy controls: 38 (32%) | | | Dis+ | Dis- | Tot
| Statistical tests used: | Inclusion criteria: | | T+ | 52 | 0 | 52
| Se,Sp, ROC | Pre-operative for assessment of ovarian mass, healthy controls | | T- | 3 | 25 | 28
| Blinding: No | Exclusion criteria: | | Tot | 55 | 25 | 80
| Definition of positive and negative on screening test: | “Inflammatory states”, positive blood cultures, CRP > 5 mg/dl, peripheral leukocyte counts >10,000, borderline tumors
| SLPI > 50 ng/mL | | | | | Lower | Upper
| CA-125 > 30 U/mL | | | | Value | 95% CI | 95% CI
| | | | Se | 95.0% | 89.2% | 100.0%
| | | | Sp | 100.0% | 88.0% | 100.0%
| | | | PPV | 100.0% | 94.2% | 100.0%
| | | | NPV | 89.3% | 77.8% | 100.0%
| | | | 3) CA-125 > 30U/mL - ovarian cancer vs. benign ovarian cysts:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 48 | 4 | 52
| | | | T- | 7 | 21 | 28
| | | | Tot | 55 | 25 | 80
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 87.0% | 78.1% | 95.9%
| | | | Sp | 84.0% | 69.6% | 98.4%
| | | | PPV | 92.3% | 85.1% | 99.6%
| | | | NPV | 75.0% | 59.0% | 91.0%
Udagawa, Aoki, Ito, et al., 1998 | Geographical location: | Age: | Screening only (n [%]): | 1) GAT cutoff 16 U/mL - ovarian cancer vs. benign ovarian tumors: | | | | Comments:
#6640 | Tokyo, Japan | Range: 10–89 | 0 | | | | | - Did not separate ovarian cancer from malignancy metastatic to the ovary in analysis for Se/Sp; - Menopausal status not specified; - No age comparison between groups reported
| Study dates: NR | Menopausal status (n [%]): | Diagnosis of mass: NR | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | NR | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 68 | 13 | 81 | Reference standard: -
| 860 | Race/ethnicity (n [%]): | Additional data used for diagnosis: | T- | 68 | 285 | 353 | Verification bias: -
| Type of population: | NR | NR | Tot | 136 | 298 | 434 | Test reliability/variability: -
| Multiple clinical groups, some with cancer (see Diagnoses) | Risk factors (n [%]): | | | | | | Sample size: +
| Genomic test(s) used: | NR | | | | Lower | Upper | Statistical tests: +
| Serum GAT (galactosyltransferase associated with tumor) | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Ovarian cancer: 134 (16%) | | Se | 50.0% | 41.6% | 58.4% | Definition of +/- on screening test: +
| NR | Benign ovarian mass: 193 (22%) | | Sp | 95.6% | 93.3% | 97.9% | Grade: C
| Reference standard applied to all test negatives?: | Healthy controls: 294 (34%) | | PPV | 84.0% | 76.0% | 91.9%
| No | Pregnant: 32 (4%) | | NPV | 80.7% | 76.6% | 84.9%
| Test reliability established?: | Endometriosis: 110 (13%)
| No | Cervical cancer: 40 (5%) | | AUC of GAT = 0.791
| Statistical tests used: Se, Sp, ROC | Endometrial cancer: 48 (6%) | | 2) GAT/CA602/CA546 - ovarian malignancy vs. benign ovarian mass:
| Blinding: NR | Cancer metastatic to ovary: 9 (1%) | | The second and third markers each have one reference to their discovery as putative ovarian cancer markers.
| Definition of positive and negative on screening test: | Inclusion criteria:
| GAT > 16 U/mL (2 SDs over the mean) | NR | | | Dis+ | Dis- | Tot
| CA-602 > 63 U/mL | Exclusion criteria: | | T+ | 115 | 112 | 227
| CA-546 > 12U/mL | NR | | T- | 21 | 186 | 207
| | | | Tot | 136 | 298 | 434
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 78.5% | 90.7%
| | | | Sp | 62.4% | 56.9% | 67.9%
| | | | PPV | 50.7% | 44.2% | 57.2%
| | | | NPV | 89.9% | 85.7% | 94.0%
| | | | 3) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.):
| | | | Coefficient of variation < 5%.
van Haaften-Day, Shen, Xu, et al., 2001 | Geographical location: | Age: NR | Screening only (n [%]): | 1) CA-125 > 35 U/mL, including borderline as Dis+: | | | | Comments:
#4010 | Sydney, Australia; Houston, TX; Durham, NC; Groningen, The Netherlands | Menopausal status (n [%]): | NR | | | | | - Benign masses not included in reported false positive rates; - 95% CIs not universally reported; - Sensitivity generally better for invasive than for borderline
| Study dates: | NR | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| May 1989–Oct 1993 for some subjects (not reported for all) | Race/ethnicity (n [%]): | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 153 | 27 | 180 | Reference standard: +
| Size of population: | NR | Additional data used for diagnosis: | T- | 50 | 167 | 217 | Verification bias: +
| 398 | Risk factors (n [%]): | NR | Tot | 203 | 194 | 397 | Test reliability/variability: +
| Type of population: | NR | | | | | | Sample size: -
| Adnexal mass; 87 healthy subjects | Diagnoses (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | Ovarian cancer: 175 (44.1%) | | | Value | 95% CI | 95% CI | Blinding: -
| CA-125-II | Borderline: 28 (7.1%) | | Se | 75.4% | 69.4% | 81.3% | Definition of +/- on screening test: +
| M-CSF | Benign ovarian mass: 77 (19.4%) | | Sp | 86.1% | 81.2% | 91.0% | Grade: B
| OVX1 | Healthy controls: 117 (29.5%) | | PPV | 85.0% | 79.8% | 90.2%
| Reference standard: | Inclusion criteria: | | NPV | 77.0% | 71.4% | 82.6%
| Surgical pathology | NR
| Reference standard applied to all test negatives?: | Exclusion criteria: | | 2) OVX1 > 7.2 U/mL, cancer + borderline vs. benign and control:
| No | NR
| Test reliability established?: | | | | Dis+ | Dis- | Tot
| Referenced | | | T+ | 38 | 16 | 54
| Statistical tests used: | | | T- | 165 | 178 | 343
| Logistic regression | | | Tot | 203 | 194 | 397
| Blinding: NR
| Definition of positive and negative on screening test: | | | | | Lower | Upper
| Positive if: | | | | Value | 95% CI | 95% CI
| CA-125 II > 35 U/mL | | | Se | 18.7% | 13.4% | 24.1%
| OVX1 > 7.2 | | | Sp | 91.8% | 87.9% | 95.6%
| M-CSF > 3.5 | | | PPV | 70.4% | 58.2% | 82.5%
| | | | NPV | 51.9% | 46.6% | 57.2%
| | | | 3) M-CSF > 3.5 ng/mL, cancer + borderline vs. benign and control:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 69 | 28 | 97
| | | | T- | 134 | 166 | 300
| | | | Tot | 203 | 194 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 34.0% | 27.5% | 40.5%
| | | | Sp | 85.6% | 80.6% | 90.5%
| | | | PPV | 71.1% | 62.1% | 80.2%
| | | | NPV | 55.3% | 49.7% | 61.0%
| | | | 4) All 3 markers, any test above threshold = positive, cancer + borderline vs. benign + healthy control:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 155 | 52 | 207
| | | | T- | 48 | 142 | 190
| | | | Tot | 203 | 194 | 397
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 76.4% | 70.5% | 82.2%
| | | | Sp | 73.2% | 67.0% | 79.4%
| | | | PPV | 74.9% | 69.0% | 80.8%
| | | | NPV | 74.7% | 68.6% | 80.9%
Wakahara, Kikkawa, Nawa, et al., 2001 | Geographical location: | Age: | Screening only (n [%]): 292 (assumed) | 1) CA-19-9 cutoff 37 U/mL, ovarian cancer versus benign ovarian mass: | | | | Comments:
#4120 | Toyohashi, Japan | Mean (SD): 40.3 | Diagnosis of mass: | AUC for CA-19-9 = 0.475 | | | | - The study demonstrates that the tumor markers in question are no better than age as a discriminator of benign versus malignant ovarian masses (AUC for age = 0.685).
| Study dates: | - Benign: 37.5 (13.1) | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | | | | Quality assessment:
| 1994-1999 | - LMP: 41 (19.9) | Additional data used for diagnosis: | | Dis+ | Dis- | Tot | Reference standard: +
| Size of population: | - Cancer: 48.8 (14.7) | Transvaginal sonography; 4 patterns used to determine/describe malignancy | T+ | 24 | 78 | 102 | Verification bias: +
| 292 | Range: 11–79 | | T- | 42 | 127 | 169 | Test reliability/variability: +
| Type of population: | Menopausal status (n [%]): | | Tot | 66 | 205 | 271 | Sample size: +
| Adnexal mass | NR | | | | | | Statistical tests: +
| Genomic test(s) used: | Race/ethnicity (n [%]): | | | | Lower | Upper | Blinding: - (NR)
| CA 19-9, CA 72-4, CA-125 | NR | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| Reference standard: | Risk factors (n [%]): | | Se | 36.4% | 24.8% | 48.0% | Grade: A
| Surgical pathology | NR | | Sp | 62.0% | 55.3% | 68.6%
| Reference standard applied to all test negatives?: | Diagnoses (n [%]): | | PPV | 23.5% | 15.3% | 31.8%
| Yes | Ovarian cancer: 66 (23%) | | NPV | 75.1% | 68.6% | 81.7%
| Test reliability established?: | Borderline: 18 (6.1%)
| Yes | Benign ovarian mass: 208 (71%) | | 2) CA-72-4 cutoff 4 U/mL, ovarian cancer versus benign ovarian mass.
| Statistical tests used: Se, Sp, ROC | Inclusion criteria: | | AUC for CA-72-4 = 0.645
| Blinding: NR | Surgery for an adnexal mass
| Definition of positive and negative on screening test: | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Abnormal defined as: | NR | | T+ | 20 | 18 | 38
| CA-125 > 35U/mL | | | T- | 20 | 108 | 128
| CA-19-9 > 37U/mL | | | Tot | 40 | 126 | 166
| CA-72-4 > 4 U/mL
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 50.0% | 34.5% | 65.5%
| | | | Sp | 85.7% | 79.6% | 91.8%
| | | | PPV | 52.6% | 36.8% | 68.5%
| | | | NPV | 84.4% | 78.1% | 90.7%
Warwas, Haczynska, Gerber, 1997 | Geographical location: | Age: | Screening only (n [%]): | 1) Cathepsin B, cutoff 102.3 - ovarian cancer vs. benign ovarian cysts: | | | | Comments:
#7160 | Wroclaw, Poland | Cancer: | NR | Se: All stages 78.6 %; stage I 60% | | | | - Controls were not age-matched.
| Study dates: | Median: 51 | Diagnosis of mass: | | | | | Quality assessment:
| 1989-1994 | Range: 14–82 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Reference standard: +
| Size of population: | Benign cyst: | Additional data used for diagnosis: | T+ | 59 | 0 | 59 | Verification bias: - (controls did not have surgery)
| 127 | Median: 48 | NR | T- | 16 | 17 | 33 | Test reliability/variability: -
| Type of population: | Range: 35–60 | | Tot | 75 | 17 | 92 | Sample size: - (only 17 with benign cysts)
| Ovarian cancers, benign ovarian cysts, 2 control groups | Healthy controls: | | | | | | Statistical tests: +
| Genomic test(s) used: | Median: 39 | | | | Lower | Upper | Blinding: -
| Cathepsin B-like activity | Range: 28–46 | | | Value | 95% CI | 95% CI | Definition of +/- on screening test: +
| Antipapain activity | Menopausal status (n [%]): | | Se | 78.6% | 69.3% | 87.9% | Grade: C
| Reference standard: | NR | | Sp | 100.0% | 82.4% | 100.0%
| Surgical pathology | Race/ethnicity (n [%]): | | PPV | 100.0% | 94.9% | 100.0%
| None for healthy controls | NR | | NPV | 51.5% | 34.5% | 68.6%
| Reference standard applied to all test negatives?: | Risk factors (n [%]):
| No | NR | | 2) Antipapain activity, cutoff 117.9 mU/L - ovarian cancers vs. benign cysts:
| Test reliability established?: | Diagnoses (n [%]): | | Se: All stages 22.6%, stage I 50%
| No | Ovarian cancer: 75 (59%)
| Statistical tests used: Se | Benign ovarian mass: 17 (13%) | | | Dis+ | Dis- | Tot
| Blinding: NR | Healthy controls: 15 (12%) | | T+ | 17 | 0 | 17
| Definition of positive and negative on screening test: | Uterine fibroids: 20 (16%) | | T- | 58 | 17 | 75
| The mean value for benign ovarian cysts plus 2 SDs = 102.3 mIU/L (cathepsin b); 117.9 nU/L (anti-papain activity) | Inclusion criteria: | | Tot | 75 | 17 | 92
| | Surgery for ovarian mass, uterine fibroids, or control group (no surgery)
| | Exclusion criteria: | | | | Lower | Upper
| | NR | | | Value | 95% CI | 95% CI
| | | | Se | 22.6% | 13.1% | 32.1%
| | | | Sp | 100.0% | 82.4% | 100.0%
| | | | PPV | 100.0% | 82.4% | 100.0%
| | | | NPV | 22.7% | 13.2% | 32.1%
Weitzel, Ding, Larson, et al., 2000 | Geographical location: | Age: | Screening only (n [%]): | 1) Existence of a rare HRAS1 allele; ovarian cancer vs. healthy controls; OR for having cancer with a rare allele is 1.76 (95%CI 1.08 to 2.87). Risk appears to increase with the presence of 2 rare alleles (OR 2.86, 0.75 to 10.94). | | | | Comments:
#11800 | Duarte, CA | Ovarian cancer: | NR | | | | | - Some cancer patient samples were blood; others were tissue (controls were all blood) which could introduce error if there was a somatic allelic deletion in the cancer tissue only. The authors performed extra testing on 24 samples for which both blood and tissue were available and concluded that the results were concordant.; - Authors conclude that HRAS allele status may modify ovarian cancer risk.
| Study dates: NR | Mean (SD): 53.2 (13.3) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Controls: | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 29 | 14 | 43 | Reference standard: +
| 244 | Mean (SD): 52.5 (15.4) | Additional data used for diagnosis: | T- | 107 | 94 | 201 | Verification bias: - (controls did not have surgery)
| Type of population: | Menopausal status (n [%]): | NR | Tot | 136 | 108 | 244 | Test reliability/variability: -
| Ovarian cancer or control | NR | | | | | | Sample size: +
| Genomic test(s) used: | Race/ethnicity (n [%]): | | | | Lower | Upper | Statistical tests: +
| Rare HRAS1 allele polymorphisms | Caucasian 244 (100%) | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | Risk factors (n [%]): | | Se | 21.5% | 14.6% | 28.4% | Definition of +/- on screening test: +
| Surgical pathology or clinical status (controls) | NR | | Sp | 86.6% | 80.2% | 93.0% | Grade: B
| Reference standard applied to all test negatives?: | Diagnoses (n [%]): | | PPV | 67.4% | 53.4% | 81.4%
| No (controls did not have follow up or surgery) | Ovarian cancer: 136 (56%) | | NPV | 46.8% | 39.9% | 53.7%
| Test reliability established?: | Healthy controls: 108 (44%)
| No | Inclusion criteria:
| Statistical tests used: Odds ratios | - Cases: epithelial ovarian cancer
| Blinding: NR | - Controls: age and race matched, no history of cancer and ovaries intact
| Definition of positive and negative on screening test: | Exclusion criteria:
| Presence or absence of HRAS1 polymorphism as determined by PCR; a number of techniques are described depending on the type of sample obtained (blood, tissue, or both) | Prior oophorectomy, history of cancer (for control group)
Yuce, Baykal, Genc, et al., 2001 | Geographical location: | Age: | Screening only (n [%]): None | 1) Serum LDH cutoff 512.28 U/mL - ovarian cancer vs. benign ovarian mass: | | | | Comments:
#4220 | Ankara, Turkey | Benign masses: | Diagnosis of mass: | | | | | - Cutoffs were determined “statistically” but exact method of determination not specified.; - N is fairly low.; - Peritoneal fluid was not always available in benign cases and washings were obtained in these cases. This would introduce a variable dilution effect on the samples and possibly lead to a false lower LDH level in the benign controls, subsequently falsely enhancing the calculated Se for cancers.; - Authors claim LDH adds to the Se of CA-125 without detracting significantly from Sp.
| Study dates: | Mean: 45.3 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | | Dis+ | Dis- | Tot | Quality assessment:
| Dec 1998–Jun 1999 | Range: 22–77 | Additional data used for diagnosis: | T+ | 5 | 2 | 7 | Reference standard: +
| Size of population: | Ovarian cancer: | NR | T- | 22 | 36 | 58 | Verification bias: +
| 65 | Mean: 58.6 | | Tot | 27 | 38 | 65 | Test reliability/variability: +
| Type of population: | Range: 20–78 | | | | | | Sample size: -
| Adnexal mass | Menopausal status (n [%]): | | | | Lower | Upper | Statistical tests: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Blinding: -
| LDH - serum and peritoneal fluid | Race/ethnicity (n [%]): | | Se | 18.5% | 3.9% | 33.1% | Definition of +/- on screening test: +
| Reference standard: | NR | | Sp | 94.7% | 87.6% | 100.0% | Grade: B
| Surgical pathology | Risk factors (n [%]): | | PPV | 71.4% | 38.0% | 100.0%
| Reference standard applied to all test negatives?: | NR | | NPV | 62.1% | 49.6% | 74.6%
| Yes | Diagnoses (n [%]):
| Test reliability established?: | Ovarian cancer: 27 (41.5%) | | 2) Peritoneal LDH cutoff 650 U/mL - ovarian cancer vs. benign ovarian mass:
| Yes | Benign ovarian mass: 38 (58.5%)
| Statistical tests used: Se, Sp, PPV, NPV | Inclusion criteria: | | | Dis+ | Dis- | Tot
| Blinding: NR | Ovarian mass for surgery | | T+ | 13 | 3 | 16
| Definition of positive and negative on screening test: | Exclusion criteria: | | T- | 14 | 35 | 49
| Serum LDH: 512.28 U/mL | NR | | Tot | 27 | 38 | 65
| Peritoneal LDH: 650 U/mL
| Serum CA-125: 129 U/mL | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 48.1% | 29.3% | 66.9%
| | | | Sp | 92.1% | 83.5% | 100.0%
| | | | PPV | 81.3% | 62.1% | 100.0%
| | | | NPV | 71.4% | 58.8% | 84.1%
| | | | 3) Peritoneal LDH cutoff 650 U/mL and serum cA125 cutoff 129 U/mL - ovarian cancer vs. benign ovarian mass:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 20 | 4 | 24
| | | | T- | 7 | 34 | 41
| | | | Tot | 27 | 38 | 65
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 74.1% | 57.6% | 90.6%
| | | | Sp | 89.9% | 80.3% | 99.5%
| | | | PPV | 83.3% | 68.4% | 98.2%
| | | | NPV | 82.9% | 71.4% | 94.4%
Zakrzewska, Borawska, Poznanski, et al., 1999 | Geographical location: | Age: | Screening only (n [%]): | 1) CA 72-4 cutoff 9.8 U/mL - ovarian cancer vs. benign ovarian neoplasm: | | | | Comments:
#5960 | Bialystok, Poland | Cancer: | NR | | | | | - Authors also present data on sensitivity of each marker for detecting various histologic subtypes of ovarian cancer, which does not have relevance for clinical management.
| Study dates: NR | Mean: 47 | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Range: 38–72 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 39 | 0 | 39 | Reference standard: +
| 96 | Menopausal status (n [%]): | Additional data used for diagnosis: | T- | 31 | 26 | 57 | Verification bias: -
| Type of population: | NR | NR | Tot | 70 | 26 | 96 | Test reliability/variability: +
| Patients with ovarian neoplasms | Race/ethnicity (n [%]): | | | | | | Sample size: +
| Genomic test(s) used: | NR | | | | Lower | Upper | Statistical tests: -
| CEA, CA-72-4, CA-125 | Risk factors (n [%]): | | | Value | 95% CI | 95% CI | Blinding: -
| Reference standard: | NR | | Se | 55.7% | 44.1% | 67.4% | Definition of +/- on screening test: +
| Surgical pathology | Diagnoses (n [%]): | | Sp | 100.0% | 88.5% | 100.0%
| Reference standard applied to all test negatives?: | Ovarian cancer: 70 (73%) | | PPV | 100.0% | 92.3% | 100.0% | Grade: B
| Yes | Benign ovarian neoplasm: 26 (27%) | | NPV | 45.6% | 32.7% | 58.5%
| Test reliability established?: | Inclusion criteria:
| Yes | Ovarian cancer or benign ovarian neoplasm | | 2) CEA cutoff 5 ng/mL - ovarian cancer vs. benign ovarian neoplasm:
| Statistical tests used: | Exclusion criteria:
| Wilcoxin test for significance | NR | | | Dis+ | Dis- | Tot
| Blinding: NR | | | T+ | 7 | 0 | 7
| Definition of positive and negative on screening test: | | | T- | 63 | 26 | 89
| CA-125: < 35 U/mL | | | Tot | 70 | 26 | 96
| CA 72-4: < 9.8 U/mL
| CEA: < 5 ng/mL | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 10.0% | 3.0% | 17.0%
| | | | Sp | 100.0% | 88.5% | 100.0%
| | | | PPV | 100.0% | 57.1% | 100.0%
| | | | NPV | 29.2% | 19.8% | 38.7%
Zhang, Bast, Yu, et al., 2004 | Geographical location: | Age: | Screening only (n [%]): | 1) Three-biomarker multivariate model: ovarian cancer vs. healthy controls (validation set): | | | | Comments:
#790 | Baltimore, MD | Ovarian cancer, test set: | NR | | | | | - Age different between cases and healthy controls; - The 3 biomarkers identified were all “acute phase reactants” not likely to be secreted by tumor cells.
| Study dates: NR | Mean (SD): 52 (16) | Diagnosis of mass: | | Dis+ | Dis- | Tot | Quality assessment:
| Size of population: | Median: 54 | - Symptomatic (n [%]): NR; - Asymptomatic, detected by exam (n [%]): NR; - Asymptomatic, detected by imaging (n [%]): NR | T+ | 107 | 2 | 109 | Reference standard: -
| 503 for proteomic profiling (discovery set) + 142 for testing identified markers (validation set) = 645 | Menopausal: 57.9% | Additional data used for diagnosis: | T- | 31 | 61 | 92 | Verification bias: +
| Type of population: | Healthy control, test set: | NR | Tot | 138 | 63 | 201 | Test reliability/variability: + ( a validation set was used)
| Ovarian cancers versus various clinical groups | Mean (SD): 39 (11) | | | | | | Sample size: +
| Genomic test(s) used: | Median: 38 | | | | Lower | Upper | Statistical tests: +
| Proteomics: | Menopausal: 20.5% | | | Value | 95% CI | 95% CI | Blinding: -
| SELDI mass spectrometry (Ciphergen ProteinChip Biomarker System) | Ovarian cancer, validation set: | | Se | 77.5% | 70.6% | 84.5% | Definition of +/- on screening test: - (a predictive model was used, no cutoffs given in text)
| Reference standard: | Mean (SD): 57 (13) | | Sp | 96.8% | 92.5% | 100.0% | Grade: B
| NR | Median: 57 | | PPV | 98.2% | 95.6% | 100.0%
| Reference standard applied to all test negatives?: | Menopausal: 74.6% | | NPV | 66.3% | 56.6% | 76.0%
| NR | Healthy control, validation set:
| Test reliability established?: | Mean (SD): 44 (10)
| No | Median: 45
| Statistical tests used: | Menopausal: 34.9%
| After identification of 3 biomarkers using proteomics platform, a multivariate model was constructed using the 3 biomarkers to predict malignancy, with or without incorporation of CA-125 information. Models were evaluated using Se, Sp, ROC | Benign mass, validation set:
| Blinding: NR | Mean (SD): 53 (16)
| Definition of positive and negative on screening test: | Median: 51
| Used a combination of variables identified from multiple logistic regression based on mass spectroscopy. Peaks occurring at m/z 12,828; 28043 and 3,272 were used. | Menopausal: 55.5%
| | Menopausal status (n [%]):
| | See above
| | Race/ethnicity (n [%]):
| | NR
| | Risk factors (n [%]):
| | NR
| | Diagnoses (n [%]):
| | Ovarian cancer: 194 (30%)
| | Borderline: 28 (4%)
| | Recurrent ovarian cancer: 14 (2%)
| | Benign pelvic mass: 166 (26%)
| | Healthy controls: 183 (28%)
| | Other:
| | - Breast cancer: 20 (3%)
| | - Colon cancer: 20 (3%)
| | - Prostate cancer: 20 (3%)
| | Inclusion criteria: Clinical groups listed above
| | Exclusion criteria:
| | NR

Table 3 Evidence Table - Question 4: What is the evidence that genomic testing in women with clinical suspicion of ovarian cancer or with already-diagnosed ovarian cancer changes clinical management and leads to improved health outcomes?

Study | Study Design | Patients | Outcome Measures | Results | | | | Comments/Quality Scoring
Ayhan, Tuncer, and Ayhan, 1998 | Geographical location: | Age: | Use of test results: No change in management (prediction only) | 1) p53 expression to predict residual disease at SLL - all patients: | | | | Comments:
#6460 | Ankara, Turkey | Mean: 52.8 | Outcomes measured: | Out+ = positive SLL | | | | Cohort was non-uniform in terms of stage of disease (5 pts Stage I–II; 43 pts Stage III)
| Study dates: | Menopausal status (n [%]): | Cancer progression on second-look laparotomy (SLL) | Out- = negative SLL | | | | Quality assessment:
| 1988-1994 | NR | | T+ = p53 overexpressed | | | | For cohort study:
| Study type: | Race/ethnicity (n [%]): | | T- = p53 not overexpressed | | | | Unbiased selection of the cohort (prospective recruitment of subjects): Unknown
| Cohort | NR | | | | | | Large sample size: -
| Size of population: | Risk factors (n [%]): | | | Out+ | Out- | Tot | Adequate description of the cohort: -
| 48 | NR | | T+ | 12 | 8 | 20 | Use of validated method for genomic test: +
| Genomic test(s) used: | Diagnoses (n [%]): | | T- | 10 | 18 | 28 | Use of validated method for ascertaining clinical outcomes: +
| p53 - immunohistochemistry | Ovarian cancer: 48 (100%) | | Tot | 22 | 26 | 48 | Adequate follow-up period: +
| Reference standard: | Treatment (n [%]): | | | | | | Completeness of follow-up: +
| Surgical pathology | Surgery: 48 (100%) | | | | Lower | Upper | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | Chemotherapy (platinum): 48 (100%) | | | Value | 95% CI | 95% CI | Grade: B
| Yes | Inclusion criteria: | | Se | 54.5% | 33.7% | 75.4%
| Statistical tests used: | Ovarian carcinoma subjected to primary surgery and cisplatinum-based chemotherapy followed by second-look laparotomy | | Sp | 69.2% | 51.5% | 87.0%
| Chi square | Exclusion criteria: | | PPV | 60.0% | 38.5% | 81.5%
| Definition of positive and negative on screening test: | NR | | NPV | 64.3% | 46.5% | 82.0%
| NR | | | 2) p53 expression to predict residual disease at SLL - serous stage III only (T/Out as described above):
| | | | | Out+ | Out- | Tot
| | | | T+ | 9 | 5 | 14
| | | | T- | 6 | 10 | 16
| | | | Tot | 15 | 15 | 30
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 60.0% | 35.2% | 84.8%
| | | | Sp | 66.7% | 42.8% | 90.5%
| | | | PPV | 64.3% | 39.2% | 89.4%
| | | | NPV | 62.5% | 38.8% | 86.2%
Baekelandt, Holm, Trope, et al., 1999 | Geographical location: | Age: | Use of test results: No change in management (prediction only) | 1) Cathespin-D levels to predict residual disease after to primary chemotherapy: | | | | Comments:
#6000 | Oslo, Norway | Median: 54 | Outcomes measured: | Out+ = macroscopic residual or no response to chemo | | | | - Same population as Baekelandt et al., 1999 (#830)
| Study dates: | Range: 21–70 | Cancer mortality | Out- = complete pathologic response or microscopic residual disease only | | | | - Lumping together “complete pathologic response” and “microscopic disease only” is somewhat arbitrary. Would be more appropriate to assess complete pathologic responders (negative SLL) versus anyone with detectable disease (positive SLL).
| 1988-1993 | Menopausal status (n [%]): | Cancer progression or regression with primary chemotherapy as assessed at time of second-look laparotomy (SLL) | T+ = cathepsin D positive IHC | | | | Quality assessment:
| Study type: | NR | | T- = cathepsin D negative IHC | | | | For cohort study:
| Cohort | Race/ethnicity (n [%]): | | | Dis+ | Dis- | Tot | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Size of population: | NR | | T+ | 78 | 22 | 100 | Large sample size: +
| 185 | Risk factors (n [%]): | | T- | 61 | 14 | 75 | Adequate description of the cohort: +
| Genomic test(s) used: | NR | | Tot | 139 | 36 | 175 | Use of validated method for genomic test: +
| Cathepsin-D | Diagnoses (n [%]): | | | | | | Use of validated method for ascertaining clinical outcomes: +
| nm23 | Ovarian cancer: 185 (100%) | | | | Lower | Upper | Adequate follow-up period: +
| Immunohistochemistry (IHC) | Treatment (n [%]): | | | Value | 95% CI | 95% CI | Completeness of follow-up: +
| Reference standard: | Surgery: First surgery, 185 (100%) | | Se | 56.1% | 47.9% | 64.4% | Analysis (multivariate adjustments) and reporting of results: +
| Surgical pathology | Chemotherapy (platinum): 185 (100%) | | Sp | 38.9% | 23.0% | 54.8% | Grade: A
| Test reliability established?: | Other (epirubicin): 185 (100%) | | PPV | 78.0% | 69.9% | 86.1%
| Yes | Inclusion criteria: | | NPV | 18.7% | 9.8% | 27.5%
| Statistical tests used: | Consecutive patients in a multicenter trial on consolidation treatment after second-look laparotomy in stage III ovarian cancer patients. Patient age < 71 years, Karnofsky index ≥ 60, histologically verified and previously untreated stage III epithelial ovarian cancer and s-creatinin < 115 μmol/L. | | 2) nm23 levels to predict residual disease after primary chemotherapy (T/Out as described above):
| Differences in proportions were evaluated by the chi-square or Fisher's exact test. Disease-free and corrected survival rates using Kaplan-Meier, log-rank test, and Cox proportional hazards regression model. | Exclusion criteria:
| Definition of positive and negative on screening test: | NR | | | Dis+ | Dis- | Tot
| Positive > 10% moderate or strong staining | | | T+ | 100 | 24 | 124
| | | | T- | 39 | 12 | 51
| | | | Tot | 139 | 36 | 175
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 71.9% | 64.5% | 79.4%
| | | | Sp | 33.3% | 17.9% | 48.7%
| | | | PPV | 80.6% | 73.7% | 87.6%
| | | | NPV | 23.5% | 11.9% | 35.2%
Baekelandt, Kristensen, Nesland, et al., 1999 | Geographical location: | Age: | Use of test results: No change in management (prediction only) | 1) p53 expression to predict residual disease at SLL: | | | | Comments:
#830 | Oslo, Norway | Median: 54 | Outcomes measured: | Out+ = macroscopic disease at SLL | | | | - Same population as Baekelandt et al., 1999 (#6000)
| Study dates: | Range: 21–70 | Cancer mortality | Out- = complete pathologic response or microscopic residual only | | | | - Cutoffs for defining positive or negative immunostaining are rather arbitrary and were not defined for mdm2.
| 1988-1993 | Menopausal status (n [%]): | Cancer progression or regression | T+ = p53 expression ≥ 5% tumor cells | | | | - Lumping together “complete pathologic response” and “microscopic disease only” is somewhat arbitrary. Would be more appropriate to assess complete pathologic responders (negative SLL) versus anyone with detectable disease (positive SLL).
| Study type: | NR | Findings at SLL (complete pathologic response, microscopic or macroscopic disease) | T- = p53 negative or < 5% staining | | | | Quality assessment:
| Cohort | Race/ethnicity (n [%]): | | | | | | For cohort study:
| Size of population: | NR | | | Dis+ | Dis- | Tot | Unbiased selection of the cohort (prospective recruitment of subjects): +
| 185 | Risk factors (n [%]): | | T+ | 64 | 20 | 84 | Large sample size: +
| Genomic test(s) used: | NR | | T- | 75 | 16 | 91 | Adequate description of the cohort: +
| P53, mdm2, bcl-2 by Immunohistochemistry (IHC) | Diagnoses (n [%]): | | Tot | 139 | 36 | 175 | Use of validated method for genomic test: +/- (cutoffs indistinct)
| Reference standard: Surgical pathology | Ovarian cancer: 185 (100%) | | | | | | Use of validated method for ascertaining clinical outcomes: +
| Test reliability established?: | Treatment (n [%]): | | | | Lower | Upper | Adequate follow-up period: +
| Yes | Surgery: First surgery 185 (100%) | | | Value | 95% CI | 95% CI | Completeness of follow-up: +
| Statistical tests used: | Chemotherapy (platinum): 185 (100%) | | Se | 46.0% | 37.8% | 54.3% | Analysis (multivariate adjustments) and reporting of results: +
| Differences in proportions were evaluated by the chi-square or Fisher's exact test. Disease-free and corrected survival rates using Kaplan-Meier, log-rank test, and Cox proportional hazards regression model. | Other (epirubicin): 185 (100%) | | Sp | 44.4% | 28.2% | 60.7% | Grade: A
| Definition of positive and negative on screening test: | Inclusion criteria: | | PPV | 76.2% | 67.1% | 85.3%
| For p53 and bcl-2: immunostaining of at least 5% of tumor cells | Consecutive patients in a multicenter trial on consolidation treatment after second-look laparotomy (SLL) in stage III ovarian cancer patients. Patient age < 71 years, Karnofsky index ≥ 60, histologically verified and previously untreated stage III epithelial ovarian cancer and s-creatinin < 115 μmol/L. | | NPV | 17.6% | 9.8% | 25.4%
| For mdm2: not specified | Exclusion criteria: | | 2) mdm2 expression to predict residual disease at SLL:
| | NR | | Out+/Out- = see above
| | | | T+ = mdm2 staining (percentage of cells not specified)
| | | | T- = mdm2 negative (percentage not specified)
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 25 | 4 | 29
| | | | T- | 114 | 32 | 146
| | | | Tot | 139 | 36 | 175
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 18.0% | 11.6% | 24.4%
| | | | Sp | 88.9% | 78.6% | 99.2%
| | | | PPV | 86.2% | 73.7% | 98.8%
| | | | NPV | 21.9% | 15.2% | 28.6%
| | | | 3) bcl-2 expression to predict residual disease at SLL:
| | | | Out+/Out- = see above
| | | | T+ = ≥ 5% of tumor cells stain positive for bcl-2
| | | | T- = < 5% tumor cells stain positive for bcl-2
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 49 | 19 | 68
| | | | T- | 90 | 17 | 107
| | | | Tot | 139 | 36 | 175
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 35.3% | 27.3% | 43.2%
| | | | Sp | 47.2% | 30.9% | 63.5%
| | | | PPV | 72.1% | 61.4% | 82.7%
| | | | NPV | 15.9% | 9.0% | 22.8%
| | | | 4) Hazard Ratio or other relevant information:
| | | | Overall survival was lower in patients with p53 expression and loss of bcl-2 expression using Kaplan Meier analysis.
Balbi, Cardone, Passaro, et al., 2005 | Geographical location: | Age: NR | Use of test results: No change in management (prediction only) | 1) Ability of CA-125 criteria to measure response to platinum when compared to conventional criteria: | | | | Comments:
#90 | Naples, Italy | Menopausal status (n [%]): | Outcomes measured: | Out+ = response to chemo by standard criteria | | | | - This study validates the use of CA-125 to follow patients in clinical trials. Many patients with ovarian cancer have no measurable disease and are not eligible for clinical trials. This paper lends some evidence to support following patients for response to chemo with CA-125 alone.
| Study dates: | NR | Response to treatment where response was defined as two samples where there was a 50% decrease, confirmed by a 4^th^ sample or a serial decrease over three sample of greater than 75% | Dis -= no response by standard criteria | | | | Quality assessment:
| 1992-2002 | Race/ethnicity (n [%]): | | T+ = response by CA-125 criteria | | | | For cohort study:
| Study type: | NR | | T- = no response by CA-125 criteria | | | | Unbiased selection of the cohort (prospective recruitment of subjects): Unknown
| Cohort | Risk factors (n [%]): | | | Out+ | Out- | Tot | Large sample size: +
| Size of population: | NR | | T+ | 32 | 2 | 34 | Adequate description of the cohort: -
| 150 | Diagnoses (n [%]): | | T- | 8 | 24 | 32 | Use of validated method for ascertaining clinical outcomes: +
| Genomic test(s) used: | Ovarian cancer: 150 (100%) | | Tot | 40 | 26 | 66 | Use of validated method for genomic test: +
| CA-125 | Treatment (n [%]): | | | | | | Adequate follow-up period: +
| Reference standard: | Surgery: 150 (100%) | | | | Lower | Upper | Completeness of follow-up: +
| Radiographic imaging: size of measurable lesions on CT, MRI, ultrasound, or physical examination. Response, stable disease, or disease progression as determined by WHO criteria. | Chemotherapy: | | | Value | 95% CI | 95% CI | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | - Single agent Platinum: 96 (64%) | | Se | 80.0% | 67.6% | 92.4% | Grade: A
| Yes | - Single agent Taxol: 54 (46%) | | Sp | 92.3% | 82.1% | 100.0%
| Statistical tests used: | Inclusion criteria: | | PPV | 94.1% | 86.2% | 100.0%
| Chi-square test | Treated with adjuvant chemo after optimal surgery for epithelial carcinoma of the ovary. Had to have CA-125 measurements performed on at least three serum samples, with at least one sample having a level more than 40 U/mL at the start of therapy. Maximum period during which a response may occur is the first 6 months after the start of treatment. The final sample had to be at least 28 days after the previous sample. Also needed to have at least one bidimensionally measurable lesion as evidenced by CT, MRI, US or physical exam. | | NPV | 75.0% | 60.0% | 90.0%
| Definition of positive and negative on screening test: | Exclusion criteria: | | 2) Ability of CA-125 criteria to measure response to paclitaxel when compared to conventional criteria (T/Out defined as above):
| CA-125 < 30 U/mL considered normal | NR
| Response to therapy by CA-125 criteria: | | | | Out+ | Out- | Tot
| “50% response” = 50% decrease in CA-125 from pre-treatment level after 2 samples | | | T+ | 22 | 2 | 24
| “75% response” = 75% drop in CA-125 from pre-treatment level after 3 samples | | | T- | 4 | 19 | 23
| | | | Tot | 26 | 21 | 47
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 84.6% | 70.7% | 98.5%
| | | | Sp | 90.5% | 77.9% | 100.0%
| | | | PPV | 91.7% | 80.6% | 100.0%
| | | | NPV | 82.6% | 67.1% | 98.1%
Berchuck, Iversen, Lancaster, et al., 2004 | Geographical location: | Age: | Use of test results: No change in management (prediction only) | 1) Microarray for prediction of ability to debulk stage III/IV cancer (n = 44): | | | | Comments:
#1740 | Durham, NC | Median: 63 (optimal debulked), 57 (suboptimally debulked) | Outcomes measured: | Out+ = optimal debulking performed | | | | - No separate validation set; leave-one-out cross validation used.
| Study dates: | Menopausal status (n [%]): | Optimal or suboptimal debulking | Out- = suboptimal debulking performed | | | | Quality assessment:
| 1988-2001 | NR | | T+ = chip predicts optimal debulking | | | | For cohort study:
| Study type: | Race/ethnicity (n [%]): | | T- = chip predicts suboptimal debulking | | | | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort | White: 17 (89%) of optimal and 18 (72%) of suboptimal | | | | | | Large sample size: -
| Size of population: | Black: 2 (11%) of optimal, and 3 (12%) or suboptimal | | | Out+ | Out- | Tot | Adequate description of the cohort: -
| 49 | Risk factors (n [%]): | | T+ | 12 | 5 | 17 | Use of validated method for genomic test: - (no validation set)
| Genomic test(s) used: | NR | | T- | 7 | 20 | 27 | Use of validated method for ascertaining clinical outcomes: +
| Microarray analysis using Affymetrix U133A GeneChip | Diagnoses (n [%]): | | Tot | 19 | 25 | 44 | Adequate follow-up period: +
| Reference standard: | Ovarian cancer: 49 (100%) | | | | | | Completeness of follow-up: +
| Degree of surgical cytoreduction (optimal = all residual tumor nodules are < 1 cm in diameter; suboptimal = at least one tumor nodule > 2 cm) | Treatment (n [%]): | | | | Lower | Upper | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | Surgery: 49 (100%) | | | Value | 95% CI | 95% CI | Grade: A
| NR | Chemotherapy (platinum): 49 (100%) | | Se | 63.2% | 41.5% | 84.8%
| Statistical tests used: | Inclusion criteria: | | Sp | 80.0% | 64.3% | 95.7%
| Multivariable predictive modelling; within-sample validation | Treated for serous ovarian cancer, all patients were < 75 years, and none had died of causes other than ovarian cancer | | PPV | 70.6% | 48.9% | 92.2%
| Definition of positive and negative on screening test: | Exclusion criteria: | | NPV | 74.1% | 57.5% | 90.6%
| Optimal debulking prediction | NR
Berek, Chung, Kaldi, et al., 1991 | Geographical location: | Age: NR | Use of test results: No change in management (prediction only) | 1) IL-6 to predict macroscopic versus microscopic disease: | | | | Comments:
#12230 | Los Angeles, CA | Menopausal status (n [%]): | Outcomes measured: | Out+ = macroscopic disease present | | | | - Unclear whether surgery was primary exploration or a second-look laparotomy. Because the clinical situation is not well defined it is unclear how management would be changed with this test.
| Study dates: | NR | Cancer mortality | Out- = microscopic disease present | | | | - Reasons/reference for choosing a cutoff level of 0.2 U/mL not given.
| NR | Race/ethnicity (n [%]): | Quality of life | T+ = IL6 positive | | | | - Used case-control method, with subjects drawn from different known disease status categories (macro, micro, control)
| Study type: | NR | Quantity of measurable disease at laparotomy | T- = IL6 negative | | | | Quality assessment:
| Cohort | Risk factors (n [%]): | | | | | | For cohort study:
| Size of population: | NR | | | Out+ | Out- | Tot | Unbiased selection of the cohort (prospective recruitment of subjects): -
| 48 | Diagnoses (n [%]): | | T+ | 16 | 2 | 18 | Large sample size: -
| Genomic test(s) used: | Ovarian cancer: 36 (66%) | | T- | 5 | 13 | 18 | Adequate description of the cohort: -
| IL-6 | Healthy controls: 12 (34%) | | Tot | 21 | 15 | 36 | Use of validated method for genomic test: - (not clear there is an established level for cutoff)
| Reference standard: Surgical pathology | Treatment (n [%]): | | | | | | Use of validated method for ascertaining clinical outcomes: +
| Test reliability established?: | NR | | | | Lower | Upper | Adequate follow-up period: +
| Yes | Inclusion criteria: | | | Value | 95% CI | 95% CI | Completeness of follow-up: +
| Statistical tests used: | Histologically documented epithelial ovarian cancer; plan to undergo surgery | | Se | 76.2% | 58.0% | 94.4% | Analysis (multivariate adjustments) and reporting of results: -
| Student's t-test | Exclusion criteria: | | Sp | 86.7% | 69.5% | 100.0% | Grade: B
| Definition of positive and negative on screening test: | NR | | PPV | 88.9% | 74.4% | 100.0%
| IL-6 > 0.20 U/mL elevated | | | NPV | 72.2% | 51.5% | 92.9%
| | | | 2) IL-6 to predict degree of macroscopic disease:
| | | | Out+ = > 2 cm disease
| | | | Out- = < 2 cm
| | | | T+ = IL6 positive
| | | | T- = IL6 negative
| | | | | Out+ | Out- | Tot
| | | | T+ | 8 | 8 | 16
| | | | T- | 1 | 4 | 5
| | | | Tot | 9 | 12 | 21
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 88.9% | 68.4% | 100.0%
| | | | Sp | 33.3% | 6.7% | 60.0%
| | | | PPV | 50.0% | 25.5% | 74.5%
| | | | NPV | 80.0% | 44.9% | 100.0%
Diamandis, Scorilas, Fracchioli, et al., 2003 | Geographical location: | Age: | Use of test results: | 1) hK6 > 4.4 μg/L for predicting presence of residual tumor | | | | Comments:
#2850 | Toronto, Canada | Healthy: | No change in management (prediction only) | | | | | Includes women with different stages of ovarian cancer (St I - 32; St II 11; St III 73; St IV 8; St unknown 22).
| Study dates: | Mean (SD): 52 | Outcomes measured: | | Dis + | Dis - | Tot | Quality assessment:
| NR | Median: 49 | Residual tumor | T + | 43 | 24 | 67 | For case-control study:
| Study type: | Range: 26–72 | Recurrence | T - | 9 | 52 | 61 | Valid ascertainment of cases: +
| Case-control | Benign disease: | Response to chemotherapy | Tot | 52 | 76 | 128 | Unbiased selection of cases: -
| Size of population: | Mean (SD): 46 | Response to chemotherapy was assessed as follows: complete response was defined as a resolution of all evidence of disease for at least 1 month; a decrease (lasting at least 1 month) of at least 50% in the diameters of all measurable lesions without the development of new lesions was termed partial response. Stable disease was defined as a decrease of <25% in the product of the diameters of all measurable lesions, an increase of ≥25% was termed as a progressive disease. | | | | | Appropriateness of the control population: -
| 97 healthy controls | Median: 45 | | | | Lower | Upper | Verification that the control is free of cancer: -
| 141 benign disease | Range: 21–76 | | | Value | 95% CI | 95% CI | Comparability of cases and controls with respect to potential
| 146 ovarian cancer | Ovarian Cancer: | | Se | 82.7% | 72.4% | 93.0% | confounders: -
| Genomic test(s) used: | Mean (SD): 56 | | Sp | 68.4% | 58.0% | 78.9% | Appropriateness of statistical analyses: +
| Human kallikrien 6 (hK6) | Median: 57 | | PPV | 64.2% | 52.7% | 75.7% | Study is based on case series with normal patients/benign disease as controls.
| CA-125 | Range: 28–78 | | NPV | 85.2% | 76.3% | 94.1% | Grade: B
| Reference standard: | Menopausal status Ovarian cancer only (n [%]): | | 2) hK6 > 4.4 μg/L for predicting debulking success - optimal debulking defined residual disease < 1cm diameter
| Surgical pathology | 103/146 (71%)
| Test reliability established?: | Race/ethnicity (n [%]): | | | Dis+ | Dis- | Tot
| Yes | NR (pooled cases from Italy, Netherlands, Belgium, Finland) | | T+ | 40 | 28 | 68
| Statistical tests used: | Risk factors (n [%]): | | T- | 9 | 53 | 62
| ROC curve, paired t-tests, Kaplan Meier, Cox proportional hazards | NR | | Tot | 49 | 81 | 130
| Definition of positive and negative on screening test: | Diagnoses (n [%]):
| hK6 - 4.2 μg/L | Ovarian cancer: 146 | | | | Lower | Upper
| hK6- 4.4 μg/L | Benign ovarian mass: 141 | | | Value | 95% CI | 95% CI
| CA-125 > 23KU/L low | Healthy controls: 97 | | Se | 81.6% | 70.8% | 92.5%
| CA-125 23–60 slightly elevated | Treatment (n [%]): | | Sp | 65.4% | 55.1% | 75.8%
| CA-125 > 60KU/L elevated | Chemotherapy: | | PPV | 58.8% | 47.1% | 70.5%
| | Platinum: 146 | | NPV | 85.5% | 76.7% | 94.3%
| | Inclusion criteria: | | 3) hK6 > 4.4 μg/L for predicting response to chemotherapy - complete/partial remission defined as no disease
| | None stated
| | Exclusion criteria: | | | Dis+ | Dis- | Tot
| | None stated | | T+ | 17 | 46 | 63
| | | | T- | 4 | 61 | 65
| | | | Tot | 21 | 107 | 128
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 81.0% | 64.2% | 97.7%
| | | | Sp | 57.0% | 47.6% | 66.4%
| | | | PPV | 27.0% | 16.0% | 37.9%
| | | | NPV | 93.8% | 88.0% | 99.7%
| | | | 4) Hazard Ratio or other relevant information:
| | | | hK6 positive - 4.10 (2.28 to 7.36)
Folk, Botsford, and Musa, 1995 | Geographical location: | Age: | Use of test results: | 1) CA-125 (after 3^rd^ course of Chemo) ≥ 35 to predict residual disease at SLL | | | | Comments:
#8260 | Syracuse, NY | Mean (SD): 55.2 | No change in management (prediction only) | | | | | None
| Study dates: | Range: 25–85 | Outcomes measured: | | Dis+ | Dis- | Tot | Quality assessment:
| 1989-93 | Menopausal status (n [%]): | Cancer progression on second-look laparotomy (SLL) | T+ | 3 | 0 | 3 | For cohort study:
| Study type: | NR | | T- | 24 | 18 | 42 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Not specified - ad hoc | Race/ethnicity (n [%]): | | Tot | 27 | 18 | 45 | Large sample size: -
| Size of population: | NR | | | | | | Adequate description of the cohort: +
| 60 | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CA-125 | Diagnoses (n [%]): | | Se | 11.1% | 0.0% | 23.0% | Adequate follow-up period: +
| Reference standard: | Ovarian cancer: 60 (100%) | | Sp | 100.0% | 83.3% | 100.0% | Completeness of follow-up: +
| Surgical pathology | Treatment (n [%]): | | PPV | 100.0% | 0.0% | 100.0% | Analysis (multivariate adjustments) and reporting of results: +
| Clinical outcome | Surgery: 60 | | NPV | 42.9% | 27.9% | 57.8% | Selection of patients not described - case series.
| Test reliability established?: | Chemotherapy: 60 | | 2) CA-125 (after 3^rd^ course of Chemo) ≥ 20 U/ml | | | | Grade: B
| Not stated | Variable regimens
| Statistical tests used: | Inclusion criteria: | | | Dis+ | Dis- | Tot
| t-test | None specified | | T+ | 6 | 5 | 11
| Definition of positive and negative on screening test: | Exclusion criteria: | | T- | 21 | 13 | 34
| CA-125 < 35IU/ml | None specified | | Tot | 27 | 18 | 45
| CA-125 < 20IU/ml for response to therapy
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 22.2% | 6.5% | 37.9%
| | | | Sp | 72.2% | 51.5% | 92.9%
| | | | PPV | 54.5% | 25.1% | 84.0%
| | | | NPV | 38.2% | 21.9% | 54.6%
| | | | 3) CA-125 (immediately prior to SLL) ≥ 35 U/ml; SLL positive or negative
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 9 | 0 | 9
| | | | T- | 18 | 18 | 36
| | | | Tot | 27 | 18 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 33.3% | 15.6% | 51.1%
| | | | Sp | 100.0% | 83.3% | 100.0%
| | | | PPV | 100.0% | 66.7% | 100.0%
| | | | NPV | 50.0% | 33.7% | 66.3%
| | | | 4) CA-125 (immediately prior to SLL) ≥ 20 U/ml
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 7 | 2 | 9
| | | | T- | 18 | 18 | 36
| | | | Tot | 25 | 20 | 45
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 28.0% | 10.4% | 45.6%
| | | | Sp | 90.0% | 76.9% | 100.0%
| | | | PPV | 77.8% | 50.6% | 100.0%
| | | | NPV | 50.0% | 33.7% | 66.3%
Gadducci, Cosio, Fanucchi, et al., 2004 | Geographical location: | Age: | Use of test results: Prediction of outcome of chemotherapy | 1) CA-125 half-life ≤ 14 days to predict complete response to treatment | | | | Comments:
#1810 | Pisa, Italy | Mean (SD): 58 | Outcomes measured: | | | | | Case series - not sure how selected
| Study dates: | Range: 27–73 | Response to treatment | | Dis+ | Dis- | Tot | Study population includes women at different stages (II-II n=60; IV n=11)
| 1996-2000 | Menopausal status (n [%]): | Progression-free survival | T+ | 26 | 10 | 36 | Study combines women with no response by clinical evaluation (who were not considered for SLL) with women who required SLL for evaluation of response.
| Study type: | NR | Overall survival | T- | 16 | 19 | 35 | Quality assessment:
| Other (retrospective series) | Race/ethnicity (n [%]): | | Tot | 42 | 29 | 71 | For cohort study:
| Size of population: | Italian | | | | | | Unbiased selection of the cohort (prospective recruitment of subjects): -
| 71 | Risk factors (n [%]): | | | | Lower | Upper | Large sample size: -
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Adequate description of the cohort: +
| CA-125 | Diagnoses (n [%]): | | Se | 61.9% | 47.2% | 76.6% | Use of validated method for genomic test: +
| Reference standard: Surgical pathology | Ovarian cancer: 71 (100%) | | Sp | 65.5% | 48.2% | 82.8% | Use of validated method for ascertaining clinical outcomes: +
| Clinical outcome (based on exam, sonography, and radiology) | Treatment (n [%]): | | PPV | 72.2% | 57.6% | 86.9% | Adequate follow-up period: +
| Test reliability established?: | Surgery: 71 (100%) | | NPV | 54.3% | 37.8% | 70.8% | Completeness of follow-up: +
| Not stated | Chemotherapy: 71 | | 2) CA-125 percentage reduction after first cycle of chemotherapy > 71% to predict complete response to treatment | | | | Analysis (multivariate adjustments) and reporting of results: +
| Statistical tests used: | Platinum: 71 | | | | | | Grade: B
| Chi square, logistic regression | Paclitaxel: 71 | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | Inclusion criteria: | | T+ | 25 | 10 | 35
| CA-125 half life ≤ 14 days | Patients with Stage IIc-IV cancer | | T- | 17 | 19 | 36
| CA-125 % reduction after 1^st^ cycle of chemo | Exclusion criteria: | | Tot | 42 | 29 | 71
| ≤ 71% | None stated
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 59.5% | 44.7% | 74.4%
| | | | Sp | 65.5% | 48.2% | 82.8%
| | | | PPV | 71.4% | 56.5% | 86.4%
| | | | NPV | 52.8% | 36.5% | 69.1%
| | | | 3) Hazard Ratio or other relevant information:
| | | | Serum 125 half life
| | | | Complete response to treatment
| | | | OR 3.362 (1.178–9.594)
| | | | Progression free survival
| | | | HR 2.739 (1.425–6.262)
| | | | Overall survival
| | | | HR 3.113 (1.214–7.980)
Gadducci, Ferdeghini, Cosio, et al., 2001 | Geographical location: | Age: | Use of test results: | 1) No disease - defined as complete responders. Of 39 with advanced (III–IV) disease. 4 did not have SLL so data not presented in paper). | | | | Comments:
#4180 | Pisa Italy | Cases: | Not used | CYFRA 21-1 - < 1.9 is negative | | | | - Unclear as to how cases detected. Of 60 cases, data presented for only 35 cases stage II–IV disease.
| Study dates: | Median: 58.5 | Outcomes measured: | | | | | Quality assessment:
| NR | Range: 23–80 | Complete responders | | Dis+ | Dis- | Tot | For cohort study:
| Study type: | Benign disease: | | T+ | 20 | 5 | 25 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Other (ad hoc) | Median: 39 | | T- | 4 | 6 | 10 | Large sample size: -
| Size of population: | Range: 20–82 | | Tot | 24 | 11 | 35 | Adequate description of the cohort: +
| 60 with cancer | Menopausal status (n [%]): | | | | | | Use of validated method for genomic test: +
| 59 with benign disease used to determine cutpoints | NR | | | | Lower | Upper | Use of validated method for ascertaining clinical outcomes: +
| Genomic test(s) used: | Race/ethnicity (n [%]): | | | Value | 95% CI | 95% CI | Adequate follow-up period: -
| CYFRA 21-1 | NR | | Se | 83.3% | 68.4% | 98.2% | Completeness of follow-up: -
| CA-125 | Risk factors (n [%]): | | Sp | 54.5% | 25.1% | 84.0% | Analysis (multivariate adjustments) and reporting of results: -
| Reference standard: | NR | | PPV | 80.0% | 64.3% | 95.7% | Grade: B
| Surgical pathology | Diagnoses (n [%]): | | NPV | 60.0% | 29.6% | 90.4%
| Clinical outcome | Ovarian cancer: 60 | | 2) CYFRA 21-1 < 4.8 is negative
| Test reliability established?: | Borderline: 59
| Not stated | Info. limited to 39 patients with advanced ovarian cancer | | | Dis+ | Dis- | Tot
| Statistical tests used: | Treatment (n [%]): | | T+ | 16 | 2 | 18
| Fisher's exact tests, Mann Whitney U, Spearman rank, logistic regression | Surgery: 0? | | T- | 8 | 9 | 17
| Definition of positive and negative on screening test: | Chemotherapy: 39 | | Tot | 24 | 11 | 35
| Used the 25,50 and 75 quantiles of pre-operative CYFRA 21-1 - 1.9, 4.8 and 14.4 ng/ml | Platinum: 34
| | Inclusion criteria: | | | | Lower | Upper
| | 60 consecutive patients with untreated ovarian cancer | | | Value | 95% CI | 95% CI
| | Exclusion criteria: | | Se | 66.7% | 47.8% | 85.5%
| | None stated | | Sp | 81.8% | 59.0% | 100.0%
| | | | PPV | 88.9% | 74.4% | 100.0%
| | | | NPV | 52.9% | 29.2% | 76.7%
| | | | 3) CYFRA 21-1<14.4 is negative
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 8 | 0 | 8
| | | | T- | 16 | 11 | 27
| | | | Tot | 24 | 11 | 35
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 33.3% | 14.5% | 52.2%
| | | | Sp | 100.0% | 72.7% | 100.0%
| | | | PPV | 100.0% | 62.5% | 100.0%
| | | | NPV | 40.7% | 22.2% | 59.3%
Gemer, Lurian, Gdalevich, et al., 2005 | Geographical location: | Age: | Use of test results: | 1) Test characteristics of CA-125 > 400 to predict suboptimal debulking: | | | | Comments:
#13320 | Ashkelon, Beer Sheva, Tzrifin, Haifa, Kfar Saba, Rehovot, Petah Tikva, and Jerusalem, Israel | Median: 62 | Prediction of debulking (theoretical - retrospective study, no change in management) | | | | | None
| Study dates: | Menopausal status (n [%]): | Outcomes measured: | | Dis+ | Dis- | Tot | Quality assessment:
| NR | NR | Suboptimal debulking | T+ | 126 | 104 | 230 | For cohort study:
| Study type: | Race/ethnicity (n [%]): | | T- | 56 | 138 | 194 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort | NR | | Tot | 182 | 242 | 424 | Large sample size: +
| Size of population: | Risk factors (n [%]): | | | | | | Adequate description of the cohort: +
| 424 | NR | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CA-125 | Ovarian cancer: | | Se | 69.2% | 62.5% | 75.9% | Adequate follow-up period: +
| Reference standard: | - Stage IIIA 25 (5.9%) | | Sp | 57.0% | 50.8% | 63.2% | Completeness of follow-up: +
| Clinical outcome (suboptimal debulking) | - Stage IIIB 75 (17.7%) | | PPV | 54.8% | 48.4% | 61.2% | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | - Stage IIIC 296 (69.8%) | | NPV | 71.1% | 64.8% | 77.5% | Grade: A (but no linkage to change in management)
| Yes | - Stage IV 28 (6.6%) | | Area under ROC: 0.65
| Statistical tests used: | Treatment (n [%]):
| Sensitivity, specificity, ROC curve | Cytoreductive surgery 100%
| Definition of positive and negative on screening test: | Inclusion criteria:
| CA-125 at different cutpoints | Stage III and IV ovarian cancer undergoing primary cytoreductive surgery (diameter of largest residual nodule ≤ 1 cm)
| | Exclusion criteria:
| | None specified
Gemer, Segal, and Kopmar, 2001 | Geographical location: | Age: | Use of test results: | 1) CA-125 < 500 U/mL to predict optimal cytoreduction: | | | | Comments:
#4430 | Ashkelon, Israel | Median: 65 | Not used for management | | | | | - Case series restricted to Stage III
| Study dates: | Range: 42–78 | Outcomes measured: | | Dis+ | Dis- | Tot | Quality assessment:
| NR | Menopausal status (n [%]): | Optimal cytoreduction, defined by the Gynecology Oncology Group as the diameter of the largest residual nodule measure < 1cm. | T+ | 20 | 6 | 26 | For cohort study:
| Study type: | NR | | T- | 4 | 10 | 14 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Other (retrospective case series) | Race/ethnicity (n [%]): | | Tot | 24 | 16 | 40 | Large sample size: -
| Size of population: | Israeli | | | | | | Adequate description of the cohort: +
| 40 stage III patients | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CA-125 | Diagnoses (n [%]): | | Se | 83.3% | 68.4% | 98.2% | Adequate follow-up period: +
| Reference standard: | Ovarian cancer: 40 (100%) | | Sp | 62.5% | 38.8% | 86.2% | Completeness of follow-up: +
| Pathology | Treatment (n [%]): | | PPV | 76.9% | 60.7% | 93.1% | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | Surgery: 40 | | NPV | 71.4% | 47.8% | 95.1% | Grade: C
| Not stated | Inclusion criteria: | | 2) CA-125 < 1500 U/mL to predict optimal cytoreduction:
| Statistical tests used: | Stage III
| ANOVA, t-test, chi-square | Exclusion criteria: | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | None stated | | T+ | 24 | 8 | 32
| CA-125 > 500 U/mL | | | T- | 0 | 8 | 8
| CA-125 > 1500 U/mL | | | Tot | 24 | 16 | 40
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 100.0% | 87.5% | 100.0%
| | | | Sp | 50.0% | 25.5% | 74.5%
| | | | PPV | 75.0% | 60.0% | 90.0%
| | | | NPV | 100.0% | 62.5% | 100.0%
Gronlund, Hansen, Hogdall, et al., 2004 | Geographical location: | Age: | Use of test results: Prediction of response to second-line chemotherapy with topotecan (n = 64) or platinum/paclitaxel (n = 60) | 1) GCIG criteria (at least 50% decrease = response), complete and partial response vs. no change or progression (sensitivity for detecting response); only 72 subjects evaluable: | | | | Comments:
#11660 | Copenhagen, Denmark | Median: 59.4 | Outcomes measured: | | | | | None
| Study dates: | Range: 34.8–77.2 | Tumor volume | | Out+ | Out- | Tot | Quality assessment:
| Aug 1994–Jan 2001 | Menopausal status (n [%]): | | T+ | 27 | 14 | 41 | For cohort study:
| Study type: | NR | | T- | 1 | 30 | 31 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Case series | Race/ethnicity (n [%]): | | Tot | 28 | 44 | 72 | Large sample size: -
| Size of population: | NR | | | | | | Adequate description of the cohort: +
| 124 | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test:-
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CA-125 change, using 2 criteria: | Diagnoses (n [%]): | | Se | 96.4% | 89.6% | 100.0% | Adequate follow-up period: +
| Reference standard: | Ovarian cancer: 124 (100%, all recurrent) | | Sp | 68.2% | 54.4% | 81.9% | Completeness of follow-up: +
| Clinical outcome using US or CT for ascertainment of tumor volume | Treatment (n [%]): | | PPV | 65.9% | 51.3% | 80.4% | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | Surgery: 124 | | NPV | 96.8% | 90.6% | 100.0% | Grade: B
| Yes | Chemotherapy: 124 | | 2) Hazard Ratio or other relevant information:
| Statistical tests used: | Platinum: 60 | | Unable to do 2×2 table for ratio; performance was best when measured after 3^rd^ cycle of chemotherapy (n = 73); reported sensitivity 91% (95% CI, specificity 61% (95% CI 43 to 76%).
| Sensitivity, specificity, Fisher's exact | Taxol: 60
| Definition of positive and negative on screening test:; 1) GCIG: 2 pretreatment samples at least 70 u/mL, with at least 2 additional samples after start of treatment; Response=≥ 50% decrease by 4^th^ sample; 2) CA-125 ratio: Pretreatment level at least 70 u/mL; ratio of posttreatment to pretreatment value ≤ 0.5 | Topotecan: 64
| | Inclusion criteria:
| | Recurrent disease after primary surgery/chemotherapy
| | Exclusion criteria:
| | NR
Heinrich, Bottcher-Luiz, Andrade, et al., 2004 | Geographical location: | Age: NR | Use of test results: | 1) CA-125 expression (mod-strong homogeneous cytoplasmic staining) for staging of borderline Ov tumors (FIGO stage II or III vs stage I): | | | | Comments:
#780 | Campinas, Sao Paulo, Brazil, and Denver, CO | Menopausal status (n [%]): NR | Potential for herceptin therapy | | | | | - Abnormal FISH results (HER-2) were found in only 7 patients, thus no association reported with FIGO stage.
| Study dates: NR | Race/ethnicity (n [%]): | Staging | | Dis+ | Dis- | Tot | - No association of CA-125 or HER-2 with FIGO stage in borderline ovarian tumors.
| Study type: | NR | Outcomes measured: | T+ | 10 | 12 | 22 | Quality assessment:
| Cohort (retrospective) | Risk factors (n [%]): | Stage | T- | 6 | 17 | 23 | For cohort study:
| Size of population: | NR | Tumor progression | Tot | 16 | 29 | 45 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| 74 women | Diagnoses (n [%]): | | | | | | Large sample size: -
| Genomic test(s) used: | Borderline: 45 (100%) | | | | Lower | Upper | Adequate description of the cohort: -
| HER-2 | Treatment (n [%]): | | | Value | 95% CI | 95% CI | Use of validated method for genomic test: -
| CA-125 | Surgery: 45 (100%) | | Se | 62.5% | 38.8% | 86.2% | Use of validated method for ascertaining clinical outcomes: -
| Reference standard: | Inclusion criteria: | | Sp | 58.6% | 40.7% | 76.5% | Adequate follow-up period: +
| Surgical pathology | Patients with borderline ovarian tumors and samples available in tissue bank | | PPV | 45.5% | 24.6% | 66.3% | Completeness of follow-up: +
| Clinical outcome (tumor progression) | Exclusion criteria: | | NPV | 73.9% | 56.0% | 91.9% | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | “Inadequate follow-up information” | | 2) None of the 45 tumors showed HER-2 overexpression. | | | | Grade: C
| NR
| Statistical tests used:
| None
| Definition of positive and negative on screening test:
| Yes
Hogdall, Hogdall, Hording, et al., 1996 | Geographical location: | Age: NR | Use of test results: | 1) TN ≤ 9.3 mg/l to predict presence of residual tumor at SLL after primary resection and chemotherapy for ovarian cancer: | | | | Comments:
#7730 | Copenhagen, Denmark | Menopausal status(n [%]): NR | Prediction of residual tumor | | | | | - This study provides reliable data for use of tumor markers to detect residual tumor - possibly obviating the need for second-look surgery. It is evaluated as a diagnostic test.
| Study dates: | Race/ethnicity (n [%]): | Outcomes measured: | | Dis+ | Dis- | Tot | - This study did not estimate the impact of testing on clinical management.
| Sep 94 - Jun 87 | NR | Presence of residual tumor after adjuvant chemotherapy at second-look laparotomy (SLL) | T+ | 9 | 0 | 9 | Quality assessment:
| Study type: | Risk factors (n [%]): | | T- | 29 | 30 | 59 | For cohort study:
| Cohort | NR | | Tot | 38 | 30 | 68 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Size of population: | Diagnoses (n [%]): | | | | | | Large sample size: +
| 63 second-look; 5 third-look in 65 patients | Ovarian cancer: 100% | | | | Lower | Upper | Adequate description of the cohort: +
| Genomic test(s) used: | Treatment (n [%]): | | | Value | 95% CI | 95% CI | Use of validated method for genomic test: +
| Tetranectin (TN) | Chemotherapy: | | Se | 23.70% | 10.20% | 37.20% | Use of validated method for ascertaining clinical outcomes: + (outcome data collected as part of RCT comparing two chemo regimens)
| CA-125 | Platinum: 50% | | Sp | 100.00% | 90.00% | 100.00% | Adequate follow-up period: +
| CASA | Other (Cyclo- phosphamide, Adriamycin and 5-FU [CAF]): 50% | | PPV | 100.00% | 66.70% | 100.00% | Completeness of follow-up: +
| Reference standard: | Inclusion criteria: | | NPV | 50.80% | 38.10% | 63.60% | Analysis (multivariate adjustments) and reporting of results: -
| Surgical pathology | Participants in a RCT comparing chemo regimens after primary surgery for ovarian cancer | | 2) CASA ≥ 10 U/ml to predict presence of residual tumor at SLL after primary resection and chemotherapy for ovarian cancer: | | | | Grade: A
| Test reliability established?: | Exclusion criteria:
| Tetranectin - yes | NR | | | Dis+ | Dis- | Tot
| Statistical tests used: | | | T+ | 12 | 0 | 12
| Sensitivity, specificity | | | T- | 26 | 29 | 55
| Definition of positive and negative on screening test: | | | Tot | 38 | 29 | 67
| TN ≤ 9.3 mg/l
| CASA ≥ 10 U/ml | | | | | Lower | Upper
| CA-125 ≥ 35 U/ml | | | | Value | 95% CI | 95% CI
| | | | Se | 31.60% | 16.80% | 46.40%
| | | | Sp | 100.00% | 89.70% | 100.00%
| | | | PPV | 100.00% | 75.00% | 100.00%
| | | | NPV | 52.70% | 39.50% | 65.90%
| | | | Additional tables reported for
| | | | CA-125 ≥ 10 U/ml
| | | | CA-125 ≥ 35 U/ml
| | | | CASA ≥ 10 or CA-125 ≥ 35
| | | | CASA ≥ 10 or CA-125 ≥ 10
| | | | CASA ≥ 10 or CA-125 ≥ 35 or TN ≤ 9.3
| | | | CASA ≥ 10 or CA-125 ≥ 10 or TN ≤ 9.3
Izquierdo, van der Zee, Vermorken, et al., 1995 | Geographical location: | Age: | Use of test results: Prediction of response to chemotherapy | 1) Pgp expression negative to predict response (partial or none vs complete) to induction chemotherapy: | | | | Comments:
#8010 | Amsterdam and Groningen, The Netherlands | Mean (SD): 66 | Outcomes measured: | | | | | Study combines women with no response by clinical evaluation (who were not considered for SLL) with women who required SLL for evaluation of response.
| Study dates: | Range: 29–84 | Cancer mortality | | Dis+ | Dis- | Tot | Quality assessment:
| 1984-1993 | Menopausal status (n [%]): NR | Response by second-look surgery (SLL) or clinical and/or radiographic evaluation (WHO criteria) | T+ | 32 | 8 | 40 | For cohort study:
| Study type: | Race/ethnicity (n [%]): | | T- | 9 | 0 | 9 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Cohort/retrospective case series | NR | | Tot | 41 | 8 | 49 | Large sample size: -
| Size of population: | Risk factors (n [%]): | | | | | | Adequate description of the cohort: +
| 57 women/tumors | NR | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| Markers Lrp, Mrp, and Pgp | Ovarian cancer: 57 (100%) | | Se | 78.0% | 65.4% | 90.7% | Adequate follow-up period: +
| Reference standard: | Treatment (n [%]): | | Sp | 0.0% | 0.0% | 0.0% | Completeness of follow-up: +
| Surgical pathology | Surgery: 57 (100%) | | PPV | 80.0% | 67.6% | 92.4% | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | Chemotherapy: | | NPV | 0.0% | 0.0% | 0.0% | Grade: B
| Yes | Platinum: 50 (88%) | | 2) Mrp expression negative to predict response (partial or none vs complete) to induction chemotherapy:
| Statistical tests used: | Inclusion criteria:
| Sensitivity, specificity, survival analysis | Banked frozen specimens from women who underwent initial surgery for stage II or IV Ov Ca | | | Dis+ | Dis- | Tot
| Definition of positive and negative on screening test: | Exclusion criteria: | | T+ | 13 | 3 | 16
| Yes, more than 10% of cells stained; kappa test of reliability 0.553–0.854 (blind interpretation) | None specified | | T- | 28 | 5 | 33
| | | | Tot | 41 | 8 | 49
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 31.7% | 17.5% | 46.0%
| | | | Sp | 62.5% | 29.0% | 96.0%
| | | | PPV | 81.3% | 62.1% | 100.0%
| | | | NPV | 15.2% | 2.9% | 27.4%
| | | | 3) Lrp expression negative to predict response (partial or none vs complete) to induction chemotherapy
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 5 | 5 | 10
| | | | T- | 36 | 3 | 39
| | | | Tot | 41 | 8 | 49
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 12.2% | 2.2% | 22.2%
| | | | Sp | 37.5% | 4.0% | 71.0%
| | | | PPV | 50.0% | 19.0% | 81.0%
| | | | NPV | 7.7% | 0.0% | 16.1%
| | | | 4) Hazard Ratio or other relevant information:
| | | | No association between Pgp or Mrp and either progression-free survival or overall survival in univariate survival analysis.
| | | | Lrp-positive tumors had shorter progression-free (9 mo vs 28 mo; p = 0.003) and overall survival (median 15 mo vs 42 mo; p = 0.007) than Lrp-negative tumors.
| | | | Lrp remained a significant predictor (p = 0.009) of survival in a multivariable survival analysis controlling for FIGO stage, residual tumor after initial surgery, tumor grade, and presence of ascites.
Kamazawa, Kigawa, Kanamori, et al., 2002 | Geographical location: | Age: | Use of test results: | 1) MDR-1 expression < 100 to predict response to chemotherapy: | | | | Comments:
#3550 | Yonago, Japan | Mean (SD): 55.2 | Predictor of response to paclitaxel-based chemotherapy | | | | | - Cut-off was selected post hoc to obtain 100% sensitivity.
| Study dates: | Range: 21–72 | Outcomes measured: | | Dis+ | Dis- | Tot | - Note there is an error in the text of the article in reported specificity for MDR. We chose the value of 80% to be consistent with the description of data and Figure 4; Se and PPV were reported correctly according to this interpretation.
| 2000-2001 | Menopausal status (n [%]): | Complete or partial response to chemotherapy as measured by CT/MR/US | T+ | 21 | 1 | 22 | Quality assessment:
| Study type: | NR | | T- | 0 | 5 | 5 | For cohort study:
| Cohort/case series | Race/ethnicity (n [%]): | | Tot | 21 | 6 | 27 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Size of population: | NR | | | | | | Large sample size: -
| 27 women | Risk factors (n [%]): | | | | Lower | Upper | Adequate description of the cohort: -
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for genomic test: -
| MDR-1 | Diagnoses (n [%]): | | Se | 100.0% | 85.7% | 100.0% | Use of validated method for ascertaining clinical outcomes: +
| MRP-1 | Ovarian cancer: 27 (100%) | | Sp | 80.0% | 48.0% | 100.0% | Adequate follow-up period: +
| MRP-2 by RT-PCR | Treatment (n [%]): | | PPV | 95.5% | 86.8% | 100.0% | Completeness of follow-up: +
| Reference standard: | Surgery: 27 (100%) | | NPV | 100.0% | 40.0% | 100.0% | Analysis (multivariate adjustments) and reporting of results: -
| Surgical pathology | Chemotherapy: | | Tests of MRP-1 and MRP-2 did not differ between responders and non-responders (Figure; 2×2 not provided) | | | | Grade: B
| Clinical outcome (response, CR, PR, NC) | Platinum: 27 (100%)
| Test reliability established?: | Inclusion criteria:
| No | Residual disease after primary surgery
| Statistical tests used: | Exclusion criteria:
| t-test, sensitivity, specificity | Borderline malignancy
| Definition of positive and negative on screening test:
| MDR-1 gene expression of 100
Kierke-gaard, Mogensen, Mogensen, et al., 1995 | Geographical location: | Age: | Use of test results: Prediction of positive second-look laparotomy | 1) CASA > 8 U/ml for diagnosis of tumor at SLL: | | | | Comments:
#7940 | Aarhus, Denmark | Median: 54.6 | Outcomes measured: | | | | | - There was a difference between patient with macroscopic and microscopic tumor at SLL. Markers were more sensitive for macroscopic tumor, and less sensitive for microscopic tumor (28% vs 11% for CASA; 51% vs 16% for CA-125).
| Study dates: | Range: 27–70 | Presence of residual disease at second-look | | Dis+ | Dis- | Tot | Quality assessment:
| Sep 1987 – Dec 1992 | Menopausal status (n [%]): | | T+ | 13 | 0 | 13 | For cohort study:
| Study type: | NR | | T- | 45 | 35 | 80 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort | Race/ethnicity (n [%]): | | Tot | 58 | 35 | 93 | Large sample size: -
| Size of population: | NR | | | | | | Adequate description of the cohort: +
| 93 women from 265 consecutive patients | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: -
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CASA | Diagnoses (n [%]): | | Se | 22.4% | 11.7% | 33.1% | Adequate follow-up period: +
| CA-125 | Ovarian cancer: 93 (100%) | | Sp | 100.0% | 91.4% | 100.0% | Completeness of follow-up: +
| Reference standard: | Treatment (n [%]): | | PPV | 100.0% | 76.9% | 100.0% | Analysis (multivariate adjustments) and reporting of results: +
| Surgical pathology | Surgery: 93 (100%) | | NPV | 43.8% | 32.9% | 54.6% | Grade: B
| Test reliability established?: | Chemotherapy: | | 2) CA-125 > 15 U/ml for diagnosis of tumor at SLL:
| No | Platinum: 93 (100%)
| Statistical tests used: | Inclusion criteria: | | | Dis+ | Dis- | Tot
| Sensitivity, specificity, Cox | Epithelial ovarian cancer FIGO stage II, III or IV, with no residual tumor at primary surgery | | T+ | 23 | 0 | 23
| Definition of positive and negative on screening test: | Exclusion criteria: | | T- | 35 | 35 | 70
| Yes | NR | | Tot | 58 | 35 | 93
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 39.7% | 27.1% | 52.2%
| | | | Sp | 100.0% | 91.4% | 100.0%
| | | | PPV | 100.0% | 87.0% | 100.0%
| | | | NPV | 50.0% | 38.3% | 61.7%
| | | | 3) CASA > 8 U/ml OR CA-125 > 15 U/ml for diagnosis of tumor at SLL:
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 27 | 0 | 27
| | | | T- | 31 | 35 | 66
| | | | Tot | 58 | 35 | 93
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 46.6% | 33.7% | 59.4%
| | | | Sp | 100.0% | 91.4% | 100.0%
| | | | PPV | 100.0% | 88.9% | 100.0%
| | | | NPV | 53.0% | 41.0% | 65.1%
| | | | 4) Hazard Ratio or other relevant information:
| | | | In multivariable model for survival (controlling for age, histopathology, FIGO stage and grade):
| | | | RR CA-125 > 35 U/ml = 2.9 (2.1 to 3.7; p = 0.007)
| | | | RR for CASA > 8 U.ml = 2.2 (1.5 to 3.0; p = 0.043)
Kupry-janczyk, Szymanska, Madry, et al., 2003 | Geographical location: | Age: | Use of test results: Prediction of tumor response to platinum-based chemotherapy | 1) TP53 expression positive to predict response to chemotherapy (CR or PR vs. NC or PD): | | | | Comments:
#2830 | Krakow, Poland | Median: 53.2 | Outcomes measured: | | | | | - This is more of a pilot study than one suggesting a clinical use for this marker.
| Study dates: | Range: 24–77 | Cancer mortality | | Dis+ | Dis- | Tot | Quality assessment:
| NR | Menopausal status (n [%]): | Tumor response (WHO criteria) | T+ | 98 | 37 | 135 | For cohort study:
| Study type: | NR | | T- | 57 | 37 | 94 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort/retrospective series | Race/ethnicity (n [%]): | | Tot | 155 | 74 | 229 | Large sample size: +
| Size of population: | NR | | | | | | Adequate description of the cohort: -
| 229 patients from 548 cases submitted | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: -
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| TP53 | Diagnoses (n [%]): | | Se | 63.2% | 55.6% | 70.8% | Adequate follow-up period: +
| Reference standard: | Ovarian cancer: 229 (100%) | | Sp | 50.0% | 38.6% | 61.4% | Completeness of follow-up: +
| Clinical outcome (tumor response by WHO clinical criteria) | Treatment (n [%]): | | PPV | 72.6% | 65.1% | 80.1% | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | Surgery: 229 (100%) | | NPV | 39.4% | 29.5% | 49.2% | Grade: B
| No | Chemotherapy (platinum): 229 (100%)
| Statistical tests used: | Inclusion criteria:
| 2×2, CPH model | Ov Ca FIGO IIB-IV, platinum chemotherapy and available tumor tissue in bank
| Definition of positive and negative on screening test: | Exclusion criteria:
| Yes | Chemo before staging laparotomy
Lassus, Leminen, Vayrynen, et al., 2004 | Geographical location: | Age: | Use of test results: Prediction of response | 1) ERBB2 gene copy number = 2 (vs. 3–5 or > 5) to predict response to chemotherapy (CR or PR vs. NR or PD): | | | | Comments:
#1360 | Helsinki, Finland | < 57 years: 38% | Outcomes measured: | | | | | None
| Study dates: | ≥ 57 years: 62% | Cancer mortality | | Dis+ | Dis- | Tot | Quality assessment:
| 1980-2000 | Menopausal status (n [%]): | Response to chemotherapy | T+ | 234 | 30 | 264 | For cohort study:
| Study type: | NR | | T- | 66 | 51 | 117 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort | Race/ethnicity (n [%]): | | Tot | 300 | 81 | 381 | Large sample size: +
| Size of population: | 98% white/Finnish | | | | | | Adequate description of the cohort: -
| 401 women | Risk factors (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: -
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| ERBB2 | Diagnoses (n [%]): | | Se | 78.0% | 73.3% | 82.7% | Adequate follow-up period: +
| Tissue protein microarray | Ovarian cancer: 401 (100%) | | Sp | 63.0% | 52.5% | 73.5% | Completeness of follow-up: +
| Reference standard: | Treatment (n [%]): | | PPV | 88.6% | 84.8% | 92.5% | Analysis (multivariate adjustments) and reporting of results: +
| Surgical pathology | Surgery: 401 (100%) | | NPV | 43.6% | 34.6% | 52.6% | Grade: B
| CT/MR | Chemotherapy: | | 2) Hazard Ratio or other relevant information:
| Death | Platinum: 345 (96%) | | In multivariable survival analysis ERBB2 copy number status was an independent prognostic factor (HR 2.14 [1.34 to 3.42] for > 5 gene copies, and HR 1.70 [1.17 to 2.46] for 3–5 gene copies compared to 2 copies).
| Test reliability established?: | Taxol: | | Other independent prognostic factors included:
| No | Other (not specified): 13 (3%) | | Grade (1, 2 or 3)
| Statistical tests used: | No chemotherapy: 42 (10%) | | Residual tumor > 1cm
| Survival analysis | Inclusion criteria: | | Age ≥ 57 years
| Definition of positive and negative on screening test: | Ov Ca treated at Helsinki Univ, with data for both primary treatment and survival status. | | FIGO stage (I, II, II IV)
| No | Exclusion criteria:
| | Non-serous tumors
Luo, Katsaros, Scorilas, et al., 2003 | Geographical location: | Age: | Use of test results: | 1) hK10 < 843 ng/L to predict response to chemotherapy (CR/PR vs NC/PD): | | | | Comments:
#2930 | Turin, Italy; Groningen, The Netherlands; Leuven, Belgium; Helsinki, Finland | Ovarian Ca | Prediction of response to chemotherapy | | | | | None
| Study dates: | Mean (SD): 52 | Outcomes measured: | | Dis+ | Dis- | Tot | Quality assessment:
| NR | Median: 49 | Cancer mortality | T+ | 74 | 7 | 81 | For cohort study:
| Study type: | Range: 26–72 | Tumor response to chemotherapy | T- | 44 | 14 | 58 | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Cohort/case series | Menopausal status (n [%]): | | Tot | 118 | 21 | 139 | Large sample size: -
| Size of population: | NR | | | | | | Adequate description of the cohort: -
| 146 Ov Ca | Race/ethnicity (n [%]): | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | NR | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| hK10 | Risk factors (n [%]): | | Se | 62.7% | 54.0% | 71.4% | Adequate follow-up period: +
| Reference standard: | NR | | Sp | 66.7% | 46.5% | 86.8% | Completeness of follow-up: +
| Surgical pathology | Diagnoses (n [%]): | | PPV | 91.4% | 85.2% | 97.5% | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | Ovarian cancer: 146 (100%) | | NPV | 24.1% | 13.1% | 35.2% | Grade: B
| Referenced | Benign ovarian mass: 141 | | 2) Hazard Ratio or other relevant information:
| Statistical tests used: | Healthy controls: 97 | | hK10 positive (> 843 ng/L) was NOT associated with PFS, HR = 1.31 (0.65 to 2.62; p = 0.45).
| Survival analysis | Treatment (n [%]): | | hK10 positive was associated with OS, HR = 3.43 (1.23 to 5.54; p = 0.018).
| Definition of positive and negative on screening test: | Surgery: 146 (100%)
| No | Chemotherapy: NR
| | Inclusion criteria:
| | Not described
| | Exclusion criteria:
| | NR
Memarzadeh, Lee, Berek, et al., 2003 | Geographical location: | Age: | Use of test results: Predicting optimal cytoreduction | 1) CA-125 > 912 U/mL to predict suboptimal cytoreduction | | | | Comments:
#2790 | Los Angeles, CA | Median: 59 | Outcomes measured: | Out+ = suboptimal | | | | - Retrospective. Unclear whether any patients were excluded (data not given).
| Study dates: | Range: 23–83 | Ability to perform optimal cytoreductive surgery | Out- = Optimal | | | | - No validation set to confirm their cutoff level as valid.
| 1989-2001 | Menopausal status (n [%]): | | T+ = above cutoff | | | | - No determination of other predictors of optimal debulking other than CA-125 or confounding variables.
| Study type: | NR | | T- = below cutoff | | | | Quality assessment:
| Case-control | Race/ethnicity (n [%]): NR | | | | | | For case-control study:
| Cases = optimally cytoreduced | Risk factors (n [%]): | | | Dis+ | Dis- | Tot | Valid ascertainment of cases: +
| Controls = suboptimally cytoreduced | NR | | T+ | 14 | 31 | 45 | Unbiased selection of cases: +
| Size of population: | Diagnoses (n [%]): | | T- | 12 | 42 | 54 | Appropriateness of the control population: +
| 99 | Ovarian cancer: 99 (100%) | | Tot | 26 | 73 | 99 | Verification that the control is free of cancer: N/A
| Genomic test(s) used: | Treatment (n [%]): | | | | | | Comparability of cases and controls with respect to potential
| CA-125 | Surgery: 99 (100%) | | | | Lower | Upper | confounders: -
| Reference standard: Clinical outcome: optimal versus suboptimal cytoreduction. Optimal is defined as all residual tumor nodules less than 1 cm. | Inclusion criteria: | | | Value | 95% CI | 95% CI | Validated dietary assessment method: N/A
| Test reliability established?: | Stage IIIC-IV ovarian cancer who had primary cytoreductive surgery | | Se | 53.8% | 34.7% | 73.0% | Appropriateness of statistical analyses: +
| Yes | Exclusion criteria: | | Sp | 57.5% | 46.2% | 68.9% | Grade: B
| Statistical tests used: Sensitivity, specificity, ROC | Borderline tumors | | PPV | 31.1% | 17.6% | 44.6%
| Definition of positive and negative on screening test: | | | NPV | 77.8% | 66.7% | 88.9%
| Cutoff CA-125 912 U/ml determined using ROC
Obeidat, Latimer, and Crawford, 2004 | Geographical location: | Age: | Use of test results: Predicting optimal cytoreduction | 1) CA-125 ≥ 500U/ml to predict sub-optimal cytoreduction: | | | | Comments:
#1800 | Irbid, Jordan | Median: | Outcomes measured: | Out+ = suboptimal cytoreduction | | | | - Not able to reproduce the 95% CIs reported in paper.
| Study dates: | Optimal debulking: 57 | Optimal surgical cytoreduction | Out- = optimal cytoreduction | | | | Quality assessment:
| 1/00–12/01 | Suboptimal: 63.5 | | T+ = CA-125 > 500 | | | | For case-control study:
| Study type: | Range: | | T- = CA-125 < 500 | | | | Valid ascertainment of cases: +
| Case-control | Optimal: 30–79 | | | | | | Unbiased selection of cases: +
| Size of population: | Suboptimal: 49–78 | | | Out+ | Out- | Tot | Appropriateness of the control population: +
| 40 | Menopausal status (n [%]): | | T+ | 13 | 6 | 19 | Verification that the control is free of cancer: N/A
| Genomic test(s) used: | NR | | T- | 5 | 16 | 21 | Comparability of cases and controls with respect to potential
| CA-125 | Race/ethnicity (n [%]): NR | | Tot | 18 | 22 | 40 | confounders:+
| Reference standard: | Risk factors (n [%]): | | | | | | Validated dietary assessment method: N/A
| Clinical outcome: optimal surgical cytoreduction, GOG criteria, largest remaining tumor nodule ≤ 1 cm | NR | | | | Lower | Upper | Appropriateness of statistical analyses: +
| Test reliability established?: | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Grade: A
| Yes | Ovarian cancer: 40 (100%) | | Se | 72.0% | 51.3% | 92.7%
| Statistical tests used: | Treatment (n [%]): | | Sp | 73.0% | 54.4% | 91.6%
| Sensitivity, specificity, ROC curves | Surgery: 40 (100%) | | PPV | 68.4% | 47.5% | 89.3%
| Definition of positive and negative on screening test: | Inclusion criteria: | | NPV | 76.2% | 58.0% | 94.4%
| CA-125 > 500 U/mL | Stage III ovarian cancer
| | Exclusion criteria:
| | Borderline malignancy
Rustin, Marples, Nelstrop, et al., 2001 | Geographical location: | Age: NR | Use of test results: Change/delay in treatment | 1) Ability of CA-125 doubling to diagnose ovarian cancer progression as measured by clinical signs or radiography: | | | | Comments:
#4110 | Northwood, UK | Menopausal status (n [%]): | Outcomes measured: | Out+ = patients whose disease progressed | | | | - No specific measurement criteria were used as gold standard (eg, RECIST criteria for target lesion size)
| Study dates: | NR | Cancer progression based on clinical criteria | Out- = patients whose disease did not progress | | | | - Few outcome negatives (patients who did not progress) limits ability to calculate SP and NPV
| 1981-1999 | Race/ethnicity (n [%]): NR | | T+ = CA-125 doubled | | | | Quality assessment:
| Study type: | Risk factors (n [%]): | | T- = CA-125 did not double | | | | For case-control study:
| Case-control | NR | | | | | | Valid ascertainment of cases: +
| Size of population: | Diagnoses (n [%]): | | | Out+ | Out- | Tot | Unbiased selection of cases: -
| 300 → 88 who had persistent elevation of CA-125 following primary chemotherapy were the basis for this paper's analysis | Ovarian cancer: 300 (100%) | | T+ | 80 | 1 | 81 | Appropriateness of the control population: +
| Genomic test(s) used: | Treatment (n [%]): | | T- | 5 | 2 | 7 | Verification that the control is free of cancer: - (no minimum follow up specified to confirm lack of progression)
| CA-125 | Chemotherapy (type not specified): 300 (100%) | | Tot | 85 | 3 | 88 | Comparability of cases and controls with respect to potential confounders: -
| Reference standard: | Inclusion criteria: Treatment with first line chemotherapy for ovarian cancer; at least one CA-125 available; CA-125 elevated above normal range persistently post-treatment | | | | | | Validated dietary assessment method: NA
| Clinical outcome: radiographic evidence of disease progression or clinical evidence of progression | Exclusion criteria: | | | | Lower | Upper | Appropriateness of statistical analyses: +
| Test reliability established?: | Normal CA-125 at conclusion of primary chemotherapy | | | Value | 95% CI | 95% CI | Grade: C
| Yes | | | Se | 94.1% | 89.1% | 99.1%
| Statistical tests used: | | | Sp | 66.7% | 13.3% | 100.0%
| Sensitivity | | | PPV | 98.8% | 96.4% | 100.0%
| Definition of positive and negative on screening test: | | | NPV | 28.6% | 0.0% | 62.0%
| Elevation of CA-125 to twice the nadir level
Rustin, Nelstrop, Tuxen, et al., 1996 | Geographical location: | Age: NR | Use of test results: | 1) Ability of CA-125 to detect progression | | | | Comments:
#7510 | Northwood, UK | Menopausal status (n [%]): | Treat relapse disease early | Out+ = progression of cancer | | | | - Several possible definitions of CA-125 criteria for progression of cancer were explored (Table 2). Authors chose their “best” definition but no validation set to confirm predictive value.
| Study dates: | NR | Outcomes measured: | Out- = no progression | | | | Quality assessment:
| 12/89–4/94 | Race/ethnicity (n [%]): NR | Cancer progression | T+ = CA-125 double the normal cutoff (30u/ml) | | | | For case-control study:
| Study type: | Risk factors (n [%]): | | T- = CA-125 never doubled the normal cutoff | | | | Valid ascertainment of cases: +
| Case-control | NR | | | | | | Unbiased selection of cases: +
| Size of population: | Diagnoses (n [%]): | | | Out+ | Out- | Tot | Appropriateness of the control population: +
| 255 | Ovarian cancer: 255 (100%) | | T+ | 73 | 4 | 77 | Verification that the control is free of cancer: + follow up at least 12 months
| Genomic test(s) used: | Treatment (n [%]): | | T- | 12 | 42 | 54 | Comparability of cases and controls with respect to potential
| CA-125 | Chemotherapy (carboplatin or cisplatin): 100% | | Tot | 85 | 46 | 131 | confounders: -
| Reference standard: | Inclusion criteria: | | | | | | Validated dietary assessment method: NA
| Clinical outcome: clinical evidence of ovarian cancer progression with follow up at least 12 months | Patients with ovarian cancer enrolled on a large trial of 5 versus 8 cycles of carboplatin or cisplatin. | | | | Lower | Upper | Appropriateness of statistical analyses: +
| Test reliability established?: | Exclusion criteria: | | | Value | 95% CI | 95% CI | Grade: B
| Yes | - Very few (< 4) CA-125 samples available; | | Se | 85.9% | 78.5% | 93.3%
| Statistical tests used: | - Patients who received treatment with a monoclonal antibody; | | Sp | 91.3% | 83.2% | 99.4%
| Sensitivity, specificity, PPV, NPV | - Patients with secondary malignancy; follow up less than 12 months, persistent CA-125 elevation following primary treatment | | PPV | 94.8% | 89.8% | 99.8%
| Definition of positive and negative on screening test: | | | NPV | 77.8% | 66.7% | 88.9%
| Upper limit of normal CA-125 is 30 U/ml. | | | 2) Ability of CA-125 to predict early progression:
| Definition of progression is a doubling of the CA15 from a baseline level | | | Out+ = progression of cancer
| ≤ 30. | | | Out- = no progression
| | | | T+ = 2 consecutive CA-125 more than double the normal cutoff (30u/ml)
| | | | T- = did not meet T+ criteria above
| | | | | Out+ | Out- | Tot
| | | | T+ | 73 | 1 | 74
| | | | T- | 14 | 42 | 56
| | | | Tot | 87 | 43 | 130
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 83.9% | 76.2% | 91.6%
| | | | Sp | 97.7% | 93.2% | 100.0%
| | | | PPV | 98.6% | 96.0% | 100.0%
| | | | NPV | 75.0% | 63.7% | 86.3%
Santillan, Garg, Zahurak, et al., 2005 | Geographical location: | Age: | Use of test results: Prediction of recurrence | 1) Recurrence; positive test = absolute change in CA-125 ≥ 5 | | | | Comments:
#13220 | Baltimore, MD | Mean: 55 | Outcomes measured: | | | | | None
| Study dates: | Range: 43–71 | Cancer recurrence | | Dis+ | Dis- | Tot | Quality assessment:
| Sep 1997–Mar 2003 | Menopausal status (n [%]): | | T+ | 22 | 1 | 23 | For cohort study:
| Study type: | NR | | T- | 0 | 16 | 16 | Unbiased selection of the cohort (prospective recruitment of subjects): +
| Cohort | Race/ethnicity (n [%]): NR | | Tot | 22 | 17 | 39 | Large sample size: -
| Size of population: | Risk factors (n [%]): | | | | | | Adequate description of the cohort: +
| 39 | NR | | | | Lower | Upper | Use of validated method for genomic test: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | Value | 95% CI | 95% CI | Use of validated method for ascertaining clinical outcomes: +
| CA-125 | Ovarian cancer: 39 (100%) | | Se | 100.0% | 86.4% | 100.0% | Adequate follow-up period: -
| Reference standard: | Treatment (n [%]): | | Sp | 94.1% | 82.9% | 100.0% | Completeness of follow-up: -
| Clinical outcome: Recurrent disease (pathology or radiologic evidence of recurrence) | NR | | PPV | 95.7% | 87.3% | 100.0% | Analysis (multivariate adjustments) and reporting of results: -
| Test reliability established?: | Inclusion criteria: | | NPV | 100.0% | 81.3% | 100.0% | Grade: C
| Yes | - CA-125 > 35 at diagnosis
| Statistical tests used: | - Complete response to initial therapy with CA-125
| Fisher's exact test, t-test | < 35
| Definition of positive and negative on screening test: | - At least 3 serial serum CA-125 measurements
| Absolute change in CA-125 post-treatment ≥ 5 | - Clinical or radiologic determination of disease status at last visit
| | Exclusion criteria:
| | None specified
Saygili, Guclu, Uslu, et al., 2002 | Geographical location: | Age: | Use of test results: Determine whether patients will be resectable | 1) CA-125 > 500 U/mL to predict sub-optimal surgical cytoreduction: | | | | Comments:
#3680 | Izmir, Turkey | Mean (SD): 56 | Outcomes measured: | Out+ = suboptimal | | | | - No comment on confounding variables/other predictors of optimal debulking between the groups
| Study dates: | Range: 46–64 | Ability to optimally cytoreduce ovarian cancer | Out- = optimal | | | | Quality assessment:
| 1994-2001 | Menopausal status (n [%]): | | T+ = CA-125>500 | | | | For case-control study:
| Study type: | NR | | T- = CA-125<500 | | | | Valid ascertainment of cases:+
| Case-control | Race/ethnicity (n [%]): NR | | | | | | Unbiased selection of cases: - (unclear whether consecutive)
| Size of population: | Risk factors (n [%]): | | | Dis+ | Dis- | Tot | Appropriateness of the control population: +
| 92 | NR | | T+ | 33 | 12 | 45 | Verification that the control is free of cancer: N/A
| Genomic test(s) used: | Diagnoses (n [%]): | | T- | 11 | 36 | 47 | Comparability of cases and controls with respect to potential
| CA-125 | Ovarian cancer: 92 (100%) | | Tot | 44 | 48 | 92 | confounders: -
| Reference standard: | Treatment (n [%]): | | | | | | Validated dietary assessment method: N/A
| Surgical pathology | Surgery: 92 (100%) | | | | Lower | Upper | Appropriateness of statistical analyses: +
| Clinical outcome: Surgical cytoreduction of all tumor nodules to less than 1 cm (optimal cytoreduction) | Chemotherapy: NR | | | Value | 95% CI | 95% CI | Grade: C
| Test reliability established?: | Inclusion criteria: | | Se | 75.0% | 62.2% | 87.8%
| Yes | Stage IIIC ovarian cancer, patient undergoing primary surgery | | Sp | 75.0% | 62.8% | 87.3%
| Statistical tests used: | Exclusion criteria: | | PPV | 73.3% | 60.4% | 86.3%
| Sensitivity, specificity, ROC | Pre-operative chemotherapy | | NPV | 76.6% | 64.5% | 88.7%
| Definition of positive and negative on screening test:
| CA-125 cutoff 500 U/ml established using ROC curve
Senapad, Neungton, Thirapaka-wong, et al., 2000 | Geographical location: | Age: | Use of test results: | 1) CA-125 > 10 U/mL to predict positive second-look laparotomy | | | | Comments:
#5170 | Bangkok, Thailand | Median: 45 | Potential use of authors' criteria to predict negative second-look laparotomy (and therefore avoid surgery) | Out+ = positive second-look | | | | - Authors suggest a subset of patients with low levels of CA-125 and TPS could forgo second-look due to the NPV of 88.9 achieved with a combination of the 2 markers.
| Study dates: | Range: 27–72 | Outcomes measured: | Out- = negative second-look | | | | - Second-look laparotomy is no longer standard of care in United States, making this less relevant
| 5/95–12/98 | Menopausal status (n [%]): | Pathology results at second-look laparotomy | T+ = CA-125 > 10 | | | | Quality assessment:
| Study type: | NR | | T- = CA-125 < 10 | | | | For case-control study:
| Cohort | Race/ethnicity (n [%]): NR | | | | | | Valid ascertainment of cases: +
| Size of population: | Risk factors (n [%]): | | | Dis+ | Dis- | Tot | Unbiased selection of cases: - not specified
| 33 | NR | | T+ | 11 | 11 | 22 | Appropriateness of the control population: +
| Genomic test(s) used: | Diagnoses (n [%]): | | T- | 8 | 3 | 11 | Verification that the control is free of cancer: +
| CA-125, TPS | Ovarian cancer: 33 (100%) | | Tot | 19 | 14 | 33 | Comparability of cases and controls with respect to potential
| Reference standard: ] | Treatment (n [%]): | | | | | | confounders: -
| Surgical pathology at second-look laparotomy | Chemotherapy (cisplatinum, paraplatin, or the paclitaxel combination regime): 33 (100%) | | | | Lower | Upper | Validated dietary assessment method: N/A
| Test reliability established?: | Inclusion criteria: | | | Value | 95% CI | 95% CI | Appropriateness of statistical analyses: +
| CA-125 - yes | - Non-mucinous epithelial ovarian cancer, stage III–IV | | Se | 57.9% | 35.7% | 80.1% | Grade: B
| TPS - no | - All achieved a complete response with primary chemotherapy (no physical exam or radiographic evidence of disease) | | Sp | 21.4% | 0.0% | 42.9%
| Statistical tests used: | - All underwent second-look laparotomy following completion of 6 cycles of chemotherapy | | PPV | 50.0% | 29.1% | 70.9%
| Sensitivity, specificity, PPV, NPV | Exclusion criteria: | | NPV | 27.3% | 1.0% | 53.6%
| Definition of positive and negative on screening test: | - Non complete responders | | 2) Combination of CA-125 > 10 and TPS>50 to predict positive SLL
| For prediction of negative second-look laparotomy: | - Patients who did not receive second-look laparotomy | | Out+ = positive SLL
| CA-125 < 10 u/ml | | | Out- = negative SLL
| TPS < 50 U/ml | | | T+ = CA-125 > 10 and TPS > 50
| | | | T- = doesn't meet T+ criteria above
| | | | | Dis+ | Dis- | Tot
| | | | T+ | 11 | 13 | 24
| | | | T- | 8 | 1 | 9
| | | | Tot | 19 | 14 | 33
| | | | | | Lower | Upper
| | | | | Value | 95% CI | 95% CI
| | | | Se | 57.9% | 35.7% | 80.1%
| | | | Sp | 7.1% | 0.0% | 20.6%
| | | | PPV | 45.8% | 25.9% | 65.8%
| | | | NPV | 11.1% | 0.0% | 31.6%
Wong, Dai, Lele, et al., 2000 | Geographical location: Buffalo, NY | Age: | Use of test results: | 1) Ability of CA-125 performed after 3 cycles chemotherapy to predict positive second-look laparotomy performed after 6 cycles chemotherapy: | | | | Comments:
#5400 | Study dates: | Mean: 58.9 | No use in the current study | Out+ = positive pathology at second-look | | | | - Study demonstrates that early normalization of CA-125 after only 3 cycles chemo does not accurately predict who will have a negative second-look laparotomy, does predict improved overall survival.
| 1/90–12/96 | Menopausal status (n [%]): | Outcomes measured: | Out- = negative pathology at second-look | | | | Quality assessment:
| Study type: | NR | Pathology results at second-look laparotomy/laparoscopy, if performed | T+ = CA-125 > 35U/ml | | | | For case-control study:
| Case-control | Race/ethnicity (n [%]): NR | Overall survival | T- = CA-125 < 35U/ml | | | | Valid ascertainment of cases: +
| Size of population: | Risk factors (n [%]): | | | | | | Unbiased selection of cases:+
| 72 | NR | | | Out+ | Out- | Tot | Appropriateness of the control population: +
| Genomic test(s) used: | Diagnoses (n [%]): | | T+ | 5 | 1 | 6 | Verification that the control is free of cancer: +
| CA-125 | Ovarian cancer: 72 (100%) | | T- | 23 | 17 | 40 | Comparability of cases and controls with respect to potential
| Reference standard: | Treatment (n [%]): | | Tot | 28 | 18 | 46 | confounders: -
| Surgical pathology | Primary surgery: 72 (100%) | | | | | | Validated dietary assessment method: N/A
| Test reliability established?: | Second-look surgery: 46 (64%) | | | | Lower | Upper | Appropriateness of statistical analyses+:
| Yes | Chemotherapy (platinum-based): 70 (97%) | | | Value | 95% CI | 95% CI | Grade: B
| Statistical tests used: | - Cisplatin/cytoxan: 43 (60%) | | Se | 17.9% | 3.7% | 32.1%
| Sensitivity, specificity, NPV | - Cisplatin/taxol: 15 (21%) - Cisplatin/Adria/Cytoxan: 12 (17%) | | Sp | 94.7% | 84.4% | 100.0%
| Definition of positive and negative on screening test: | - Methotrexate/Cytoxan: 2 (3%) | | PPV | 83.3% | 53.5% | 100.0%
| CA-125 < 35U/ml normal | Inclusion criteria: Patients with epithelial ovarian cancer who under-went initial optimal surgical cytoreduction followed by 6 cycles of platinum-based chemotherapy | | NPV | 42.5% | 27.2% | 57.8%
| | Exclusion criteria: | | 2) Other relevant information:
| | Non-epithelial ovarian cancer | | CA-125 in normal range after 3 cycles chemotherapy predicted better median survival (30 months vs. 17 months, P < 0.0001 log rank test).

Table 4 Evidence Table - Question 5: What are the harms of using genomic tests for ovarian cancer prevention and management?

Study | Study Design | Patients | Outcome Measures | Results | Comments/Quality Scoring
Bish, Sutton, Jacobs, et al., 2002 | Geographical location: | Age: | Use of test results: | 1) At baseline, significantly less worry about ovarian cancer compared to breast cancer (7% vs. 34% reported worry often or almost all the time).; 2) Worry about ovarian cancer increased significantly among those with history of breast or ovarian cancer compared to unaffected women, no matter what risk group.; 3) Overall no change in worry in response to counseling. | Comments:
#10530 | London, UK | Mean (SD): 42.3 (12.6) | Counseling regarding BRCA1/BRCA2 testing, options for screening and surveillance | | None
| Study dates: | Range: 18–73 | Outcomes measured: | | Quality assessment:
| May 1997–May 1999 | Menopausal status (n [%]): | Quality of life; - Hospital Anxiety and Depression Scale; - General Health Questionnaire; - Cancer Worry Scale; - Perceived risk of cancer; - Perceived risk of mutation | | For cohort study:
| Study type: | NR | Timing of outcome measurement:; - Pre-consultation; - 2 weeks post-consultation (83% response); - 6 months (85% response); - 12 months (91%) | | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Cohort | Race/ethnicity (n [%]): | Only those with data at all 4 time points (n = 203, 35% of initial cohort scheduled for genetic consultation during time period) were included in the analysis | | Large sample size: -
| Size of population: | 97% White | | | Adequate description of the cohort: +
| 203 | 3% Other | | | Use of validated method for genomic test: +
| Genomic test(s) used: | Definition of “high risk”: | | | Use of validated method for ascertaining clinical outcomes: +
| BRCA1/BRCA2 | Estimated lifetime cancer risk of 1 in 3 or higher | | | Adequate follow-up period: +
| Reference standard: | Diagnoses (n [%]): | | | Completeness of follow-up: - (high dropout rate)
| Clinical outcome (psychological distress) | 46 (24%) with previous history of breast and/or ovarian cancer (1 with ovarian cancer, 4 with both, rest with breast cancer) | | | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | 26 (13.4%) low risk | | | Grade: B
| Yes - validated scale for measuring outcome | 76 (39.2%) moderate
| Statistical tests used: | 46 (23.7%) high risk
| ANOVA, t-tests | Inclusion criteria:
| Definition of positive and negative on screening test: | Referral criteria (any of the following):; - Breast cancer < 40 years - More than 1 primary; - Breast and ovary as 2 primary tumors; - 3 close relatives with breast or ovarian cancer; - 2 close relatives with breast or ovarian cancer if 1 < 50; - 1 1^st^ degree relative with cancer < 40; - 1 1^st^ degree relative with bilateral breast cancer or 2 primaries; - “Very worried about family history”
| Positive BRCA1/BRCA2 | Exclusion criteria:
| | None specified
Claes, Evers-Kiebooms, Denayer, et al., 2005 | Geographical location | Age: | Use of test results: | 1) Intrusive thoughts, depressive symptoms, and breast and ovarian cancer worries improved for those with negative result.; 2) No change from baseline in those with positive test results or those who refused testing.; 3) Problem-solving training results in greater improvement than client-based counseling.; 4) Sex not significant factor in multivariate analysis. | Comments:
#13010 | Leuven, Belgium | Carriers (n = 34) | Counseled about risk, prophylactic surgery | | None
| Study dates: | Mean (SD): 38.4 (11.4) | Outcomes measured: | | Quality assessment:
| 1999-July 2003 | Range: 19–61 | Quality of life; - Coping strategies (Utrecht Coping List); - Perceived impact of test result; - Risk perception; - Sense of control; - Cancer-specific distress (Impact of Event Scale); - General distress (Spielberger STAI) | | For cohort study:
| Study type: | Non-carriers (n = 34) | | | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Cohort | Mean (SD): 35.24 (10.6) | | | Large sample size: -
| Size of population: | Range: 19–64 | | | Adequate description of the cohort: +
| 71 (68 [96%] completed follow-up) | Menopausal status (n [%]): | | | Use of validated method for genomic test: +
| Genomic test(s) used: | NR | | | Use of validated method for ascertaining clinical outcomes: +
| BRCA1/BRCA2 | Race/ethnicity (n [%]): | | | Adequate follow-up period: -
| Reference standard: | NR | | | Completeness of follow-up: -
| Clinical outcome (quality of life measured using validated instruments) | Risk factors (n [%]): | | | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | NR | | | Grade: B
| Yes | Diagnoses (n [%]):
| Statistical tests used: | NR
| Fisher's exact test, t-tests | Inclusion criteria:
| Definition of positive and negative on screening test: | Family members of patients with identified BRCA1/BRCA2 mutations
| Positive BRCA1 or BRCA2 | Exclusion criteria:
| | None specified
McInerney-Leo, Biesecker, Hadley, et al., 2004 | Geographical location | Age: | Use of test results: | 1) Intrusive thoughts, depressive symptoms, and breast and ovarian cancer worries improved for those with negative result.; 2) No change from baseline in those with positive test results or those who refused testing.; 3) Problem-solving training results in greater improvement than client-based counseling.; 4) Sex not significant factor in multivariate analysis. | Comments:
#10100 | Bethesda, Rockville, and Baltimore, MD; Philadelphia, PA | Range: 95 (45%) under 40 (not reported by sex) | Not specified; subjects randomized to problem-solving training or client-centered counseling | | - Same study population as in McInerney-Leo et al., 2005 (#520); - Families in study had participated in previous study necessitating communication between relatives; - Baseline levels of cohesion higher than average, conflict lower than average; - 212 subjects came from only 13 families - thus, many subjects in this study are from the same families, possibly a source of bias
| Study dates: | Menopausal status (n [%]): | Outcomes measured: | | Quality assessment:
| NR | NR; 35% male | - Depression (Center for Epidemiologic Studies Depression Scale); - Self-esteem (Rosenberg Self-Esteem Scale); - Cancer-related distress (Impact of Events Scale, Breast Cancer Worries Scale, Ovarian Cancer Worries Scale) | | For cohort study:
| Study type: | Race/ethnicity (n [%]): | | | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Cohort | “Primarily Caucasian” | | | Large sample size: +
| Size of population: | Risk factors (n [%]): | | | Adequate description of the cohort: +
| 212 (559 invited, 262 agreed and completed baseline, 212 completed baseline and follow-up) | Family history: 212 (100%) | | | Use of validated method for genomic test: +
| Genomic test(s) used: | Diagnoses (n [%]): | | | Use of validated method for ascertaining clinical outcomes: +
| BRCA1/BRCA2 | Ovarian cancer: 0 | | | Adequate follow-up period: -
| Reference standard: | Borderline: 0 | | | Completeness of follow-up: +
| Clinical outcome (measures of family relationships [conflict, cohesiveness, expressiveness], using Family Relationship Index) | Benign ovarian mass: 0 | | | Analysis (multivariate adjustments) and reporting of results: +
| Test reliability established?: | Other: 0 | | | Grade: B
| Yes | Healthy controls: 100%
| Statistical tests used: | Inclusion criteria:
| Paired t-tests, ANOVAs; linear regression | Age > 18, family members with at least one BRCA1 or 2 mutation identified
| Definition of positive and negative on screening test: | Exclusion criteria:
| NA | None specified
McInerney-Leo, Biesecker, Hadley, et al., 2005 | Geographical location: | Age: | Use of test results: | 1) Subjects who declined genetic testing had positive changes in family relationships; expressiveness and cohesiveness increased compared to those who chose testing.; 2) Abnormal test result was associated with decreased expressiveness compared to negative test result (trend, but not significant at p < 0.05).; 3) Sex not significant factor in multivariate analysis. | Comments:
#520 | Bethesda, Rockville, and Baltimore, MD; Philadelphia, PA | Range: “over half over age of 40” | Offered genetic testing | | - Same study population as in McInerney-Leo et al., 2004 (#10100); - Families in study had participated in previous study necessitating communication between relatives; - Baseline levels of cohesion higher than average, conflict lower than average; - 212 subjects came from only 13 families - thus, many subjects in this study are from the same families, possibly a source of bias
| Study dates: NR | Menopausal status (n [%]): | Outcomes measured: | | Quality assessment:
| Study type: | NR; 35% male | Measures of family relationships | | For cohort study:
| Cohort of adult members of families with identified BRCA1/2 mutations | Race/ethnicity (n [%]): | | | Unbiased selection of the cohort (prospective recruitment of subjects): -
| Size of population: | “Primarily Caucasian” | | | Large sample size: +
| 212 (559 invited, 262 agreed and completed baseline, 212 completed baseline and follow-up) | Risk factors (n [%]): | | | Adequate description of the cohort: + (referenced)
| Genomic test(s) used: | Family history: 212 (100%) | | | Use of validated method for genomic test: +
| BRCA1/BRCA2 | Diagnoses (n [%]): | | | Use of validated method for ascertaining clinical outcomes: +
| Reference standard: | Ovarian cancer: 0 | | | Adequate follow-up period: +
| Clinical outcome (measures of family relationships [conflict, cohesiveness, expressiveness] using Family Relationship Index) | Borderline: 0 | | | Completeness of follow-up: -
| Test reliability established?: | Benign ovarian mass: 0 | | | Analysis (multivariate adjustments) and reporting of results: +
| Yes | Other: 0 | | | Grade: B
| Statistical tests used: | Healthy controls: 100%
| Paired t-tests, ANOVAs; linear regression | Inclusion criteria:
| Definition of positive and negative on screening test: | Age > 18, family members with at least one BRCA1 or 2 mutation identified
| NA | Exclusion criteria:
| | None specified

## References Cited in the Evidence Tables

Abdel-Aleem H, Ahmed A, Sabra AM, et al. Serum alpha L-fucosidase enzyme activity in ovarian and other female genital tract tumors. Int J Gynaecol Obstet. 1996;55(3):273-9. [pmid: 9003953].
Ayhan A, Tuncer ZS, Ayhan A. p53 expression in ovarian carcinoma with regard to second-look findings. Eur J Gynaecol Oncol. 1998;19(5):501-2. [pmid: 9863925].
Baekelandt M, Holm R, Trope CG, et al. The significance of metastasis-related factors cathepsin-D and nm23 in advanced ovarian cancer. Ann Oncol. 1999;10(11):1335-41. [pmid: 10631462].
Baekelandt M, Kristensen GB, Nesland JM, et al. Clinical significance of apoptosis-related factors p53, Mdm2, and Bcl-2 in advanced ovarian cancer. J Clin Oncol. 1999;17(7):2061. [pmid: 10561259].
Balbi GC, Cardone A, Passaro M, et al. Comparative evaluation of standard criteria and CA-125 in ovarian cancers treated with platinum or paclitaxel. Eur J Gynaecol Oncol. 2005;26(3):285-7. [pmid: 15991527].
Baron AT, Boardman CH, Lafky JM, et al. Soluble epidermal growth factor receptor (SEG-FR) and cancer antigen 125 (CA125) as screening and diagnostic tests for epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(2):306-18. [pmid: 15734951].
Baron AT, Cora EM, Lafky JM, et al. Soluble epidermal growth factor receptor (sEGFR/sErbB1) as a potential risk, screening, and diagnostic serum biomarker of epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(2):103-13. [pmid: 12582019].
Benetkiewicz M, Wang Y, Schaner M, et al. High-resolution gene copy number and expression profiling of human chromosome 22 in ovarian carcinomas. Genes Chromosom Cancer. 2005;42(3):228-37. [pmid: 15578687].
Berchuck A, Iversen ES, Lancaster JM, et al. Prediction of optimal versus suboptimal cytoreduction of advanced-stage serous ovarian cancer with the use of microarrays. Am J Obstet Gynecol. 2004;190(4):910-25. [pmid: 15118612].
Berek JS, Chung C, Kaldi K, et al. Serum interleukin-6 levels correlate with disease status in patients with epithelial ovarian cancer. Am J Obstet Gynecol. 1991;164(4):1038-42. discussion 1042–3. [pmid: 2014824].
Bish A, Sutton S, Jacobs C, et al. Changes in psychological distress after cancer genetic counselling: a comparison of affected and unaffected women. Br J Cancer. 2002;86(1):43-50. [pmid: 11857010].
Bon GG, Verheijen RH, Zuetenhorst JM, et al. Mucin-like carcinoma-associated antigen serum levels in patients with adenocarcinomas originating from ovary, breast and colon. Gynecol Obstet Invest. 1996;42(1):58-62. [pmid: 8840180].
Brinkmann D, Ryan A, Ayhan A, et al. A molecular genetic and statistical approach for the diagnosis of dual-site cancers. J Natl Cancer Inst. 2004;96(19):1441-6. [pmid: 15467033].
Centers for Disease Control and Prevention (CDC). Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing—Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. Morb Mortal Wkly Rep Surveill Summ. 2004;53(27):603-6.
Chang HW, Lee SM, Goodman SN, et al. Assessment of plasma DNA levels, allelic imbalance, and CA 125 as diagnostic tests for cancer. J Natl Cancer Inst. 2002;94(22):1697-703. [pmid: 12441325].
Cherchi PL, Capobianco G, Ambrosini G, et al. Intracystic evaluation of tumor markers in benign and malignant ovarian pathology. Eur J Gynaecol Oncol. 2002;23(2):163-5. [pmid: 12013118].
Claes E, Evers-Kiebooms G, Denayer L, et al. Predictive genetic testing for hereditary breast and ovarian cancer: psychological distress and illness representations 1 year following disclosure. J Genet Couns. 2005;14(5):349-63. [pmid: 16195942].
Conrads TP, Fusaro VA, Ross S, et al. High-resolution serum proteomic features for ovarian cancer detection. Endocr Relat Cancer. 2004;11(2):163-78. [pmid: 15163296].
Cooper BC, Ritchie JM, Broghammer CL, et al. Preoperative serum vascular endothelial growth factor levels: significance in ovarian cancer. Clin Cancer Res. 2002;8(10):3193-7. [pmid: 12374688].
Czekierdowski A. Studies on angiogenesis in the benign and malignant ovarian neoplasms with the use of color and pulsed Doppler sonography and serum CA-125, CA-19.9, CA-72.4 and vascular endothelial growth factor measurements. Ann Univ Mariae Curie Sklodowska [Med]. 2002;57(1):113-31.
Darai E, Bringuier AF, Walker-Combrouze F, et al. Soluble adhesion molecules in serum and cyst fluid from patients with cystic tumours of the ovary. Hum Reprod. 1998;13(10):2831-5. [pmid: 9804241].
Diamandis EP, Scorilas A, Fracchioli S, et al. Human kallikrein 6 (hK6): a new potential serum biomarker for diagnosis and prognosis of ovarian carcinoma. J Clin Oncol. 2003;21(6):1035-43. [pmid: 12637468].
Fayed ST, Ahmad SM, Kassim SK, et al. The value of CA 125 and CA72-4 in management of patients with epithelial ovarian cancer. Dis Markers. 1998;14(3):155-60. [pmid: 10427474].
Filella X, Ballesta AM, Fox M, et al. Multicentre clinical evaluation of the COBAS CORE CEA, CA 125 II and PSA tumor marker assays. Int J Biol Markers. 1996;11(1):40-5. [pmid: 8740641].
Folk JJ, Botsford M, Musa AG. Monitoring cancer antigen 125 levels in induction chemotherapy for epithelial ovarian carcinoma and predicting outcome of second-look procedure. Gynecol Oncol. 1995;57(2):178-82. [pmid: 7729730].
Gadducci A, Baicchi U, Marrai R, et al. Preoperative evaluation of D-dimer and CA 125 levels in differentiating benign from malignant ovarian masses. Gynecol Oncol. 1996;60(2):197-202. [pmid: 8631538].
Gadducci A, Cosio S, Fanucchi A, et al. The predictive and prognostic value of serum CA 125 half-life during paclitaxel/platinum-based chemotherapy in patients with advanced ovarian carcinoma. Gynecol Oncol. 2004;93(1):131-6. [pmid: 15047226].
Gadducci A, Ferdeghini M, Cosio S, et al. The clinical relevance of serum CYFRA 21-1 assay in patients with ovarian cancer. Int J Gynecol Cancer. 2001;11(4):277-82. [pmid: 11520365].
Gemer O, Lurian M, Gdalevich M, et al. A multicenter study of CA 125 level as a predictor of non-optimal primary cytoreduction of advanced epithelial ovarian cancer. Eur J Surg Oncol. 2005;31(9):1006-10. [pmid: 16005601].
Gemer O, Segal S, Kopmar A. Preoperative CA-125 level as a predictor of non optimal cytoreduction of advanced epithelial ovarian cancer. Acta Obstet Gynecol Scand. 2001;80(6):583-5. [pmid: 11380298].
Gorelik E, Landsittel DP, Marrangoni AM, et al. Multiplexed immunobead-based cytokine profiling for early detection of ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(4):981-7. [pmid: 15824174].
Gronlund B, Hansen HH, Hogdall C, et al. Do CA125 response criteria overestimate tumour response in second-line treatment of epithelial ovarian carcinoma?. Br J Cancer. 2004;90(2):377-82. [pmid: 14735180].
Hasholzner U, Baumgartner L, Stieber P, et al. Clinical significance of the tumour markers CA 125 II and CA 72-4 in ovarian carcinoma. Int J Cancer. 1996;69(4):329-34. [pmid: 8797878].
Hefler L, Mayerhofer K, Nardi A, et al. Serum soluble Fas levels in ovarian cancer. Obstet Gynecol. 2000;96(1):65-9. [pmid: 10862844].
Heinrich JK, Bottcher-Luiz F, Andrade LL, et al. HER-2 and cancer antigen 125 evaluation in ovarian borderline tumors by immunohistochemistry and fluorescence in situ hybridization. Int J Gynecol Cancer. 2004;14(6):1078-85. [pmid: 15571613].
Heinzelmann-Schwarz VA, Gardiner-Garden M, Henshall SM, et al. Overexpression of the cell adhesion molecules DDR1, Claudin 3, and Ep-CAM in metaplastic ovarian epithelium and ovarian cancer. Clin Cancer Res. 2004;10(13):4427-36. [pmid: 15240533].
Hellström I, Raycraft J, Hayden-Ledbetter M, et al. The HE4 (WFDC2) protein is a biomarker for ovarian carcinoma. Cancer Res. 2003;63(13):3695-700. [pmid: 12839961].
Hibbs K, Skubitz KM, Pambuccian SE, et al. Differential gene expression in ovarian carcinoma: identification of potential biomarkers. Am J Pathol. 2004;165(2):397-414. [pmid: 15277215]. [pmcid: 1618570].
Hofmann M, Ruschenburg I. mRNA detection of tumor-rejection genes BAGE, GAGE, and MAGE in peritoneal fluid from patients with ovarian carcinoma as a potential diagnostic tool. Cancer. 2002;96(3):187-93. [pmid: 12115308].
Hogdall CK, Hogdall EV, Hording U, et al. Use of tetranectin, CA-125 and CASA to predict residual tumor and survival at second- and third-look operations for ovarian cancer. Acta Oncol. 1996;35(1):63-9. [pmid: 8619942].
Hubl W, Chan DW, Van Ingen HE, et al. Multicenter evaluation of the Elecsys CA 125 II assay. Anticancer Res. 1999;19(4A):2727-33. [pmid: 10470230].
Hurteau JA, Woolas RP, Jacobs IJ, et al. Soluble interleukin-2 receptor alpha is elevated in sera of patients with benign ovarian neoplasms and epithelial ovarian cancer. Cancer. 1995;76(9):1615-20. [pmid: 8635066].
Inaba N, Negishi Y, Fukasawa I, et al. Cytokeratin fragment 21-1 in gynecologic malignancy: comparison with cancer antigen 125 and squamous cell carcinoma-related antigen. Tumour Biol. 1995;16(6):345-52. [pmid: 7569681].
Izquierdo MA, van der Zee AG, Vermorken JB, et al. Drug resistance-associated marker Lrp for prediction of response to chemotherapy and prognoses in advanced ovarian carcinoma. J Natl Cancer Inst. 1995;87(16):1230-7. [pmid: 7563169].
Janatova M, Pohlreich P, Matous B. Detection of the most frequent mutations in BRCA1 gene on polyacrylamide gels containing Spreadex Polymer NAB. Neoplasma. 2003;50(4):246-50. [pmid: 12937835].
Kamazawa S, Kigawa J, Kanamori Y, et al. Multidrug resistance gene-1 is a useful predictor of Paclitaxel-based chemotherapy for patients with ovarian cancer. Gynecol Oncol. 2002;86(2):171-6. [pmid: 12144824].
Kenemans P, Verstraeten AA, van Kamp GJ, et al. The second generation CA 125 assays. Ann Med. 1995;27(1):107-13. [pmid: 7741988].
Kierkegaard O, Mogensen O, Mogensen B, et al. Predictive and prognostic values of cancer-associated serum antigen (CASA) and cancer antigen 125 (CA 125) levels prior to second-look laparotomy for ovarian cancer. Gynecol Oncol. 1995;59(2):251-4. [pmid: 7590482].
Kim JH, Herlyn D, Wong KK, et al. Identification of epithelial cell adhesion molecule autoantibody in patients with ovarian cancer. Clin Cancer Res. 2003;9(13):4782-91. [pmid: 14581349].
Kozak KR, Amneus MW, Pusey SM, et al. Identification of biomarkers for ovarian cancer using strong anion-exchange ProteinChips: potential use in diagnosis and prognosis. Proc Natl Acad Sci U S A. 2003;100(21):12343-8. [pmid: 14523236]. [pmcid: 218760].
Kupryjanczyk J, Szymanska T, Madry R, et al. Evaluation of clinical significance of TP53, BCL-2, BAX and MEK1 expression in 229 ovarian carcinomas treated with platinum-based regimen. Br J Cancer. 2003;88(6):848-54. [pmid: 12644821].
Lassus H, Leminen A, Vayrynen A, et al. ERBB2 amplification is superior to protein expression status in predicting patient outcome in serous ovarian carcinoma. Gynecol Oncol. 2004;92(1):31-9. [pmid: 14751135].
Lee H, Park G, Jung JH, et al. Diagnostic approach using the expression profiling of the P53 tumor suppressor gene and its related proteins in ovarian epithelial tumors. Int J Gynecol Cancer. 2005;15(3):453-61. [pmid: 15882169].
Li L, Tang H, Wu Z, et al. Data mining techniques for cancer detection using serum proteomic profiling. Artif Intell Med. 2004;32(2):71-83. [pmid: 15364092].
Liu Y. Serum proteomic pattern analysis for early cancer detection. Technology in Cancer Research & Treatment. 2006;5(1):61-6. [pmid: 16417403].
Luo LY, Bunting P, Scorilas A, et al. Human kallikrein 10: a novel tumor marker for ovarian carcinoma?. Clin Chim Acta. 2001;306(12):111-8. [pmid: 11282101].
Luo LY, Katsaros D, Scorilas A, et al. The serum concentration of human kallikrein 10 represents a novel biomarker for ovarian cancer diagnosis and prognosis. Cancer Res. 2003;63(4):807-11. [pmid: 12591730].
Mabrouk RA, Ali-Labib R. Detection of urokinase plasminogen activator receptor and c-erbB-2 in sera of patients with breast and ovarian carcinoma. Clin Biochem. 2003;36(7):537-43. [pmid: 14563447].
Makhlouf AM, Fathalla MM, Zakhary MA, et al. Sulfatides in ovarian tumors: clinicopathological correlates. Int J Gynecol Cancer. 2004;14(1):89-93. [pmid: 14764034].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families: effectiveness of problem-solving training as a counseling intervention. Am J Med Genet A. 2004;130(3):221-7. [pmid: 15378542].
McInerney-Leo A, Biesecker BB, Hadley DW, et al. BRCA1/2 testing in hereditary breast and ovarian cancer families II: impact on relationships. Am J Med Genet A. 2005;133(2):165-9. [pmid: 15633195].
McIntosh MW, Drescher C, Karlan B, et al. Combining CA 125 and SMR serum markers for diagnosis and early detection of ovarian carcinoma. Gynecol Oncol. 2004;95(1):9-15. [pmid: 15385104].
Medl M, Ogris E, Peters-Engl C, et al. TATI (tumour-associated trypsin inhibitor) as a marker of ovarian cancer. Br J Cancer. 1995;71(5):1051-4. [pmid: 7734298].
Meinhold-Heerlein I, Bauerschlag D, Hilpert F, et al. Molecular and prognostic distinction between serous ovarian carcinomas of varying grade and malignant potential. Oncogene. 2005;24(6):1053-65. [pmid: 15558012].
Memarzadeh S, Lee SB, Berek JS, et al. CA125 levels are a weak predictor of optimal cytoreductive surgery in patients with advanced epithelial ovarian cancer. Int J Gynecol Cancer. 2003;13(2):120-4. [pmid: 12657110].
Mok SC, Chao J, Skates S, et al. Prostasin, a potential serum marker for ovarian cancer: identification through microarray technology. J Natl Cancer Inst. 2001;93(19):1458-64. [pmid: 11584061].
Mor G, Visintin I, Lai Y, et al. Serum protein markers for early detection of ovarian cancer. Proc Natl Acad Sci U S A. 2005;102(21):7677-82. [pmid: 15890779]. [pmcid: 1140439].
Mouchawar J, Hensley-Alford S, Laurion S, et al. Impact of direct-to-consumer advertising for hereditary breast cancer testing on genetic services at a managed care organization: a naturally-occurring experiment. Genet Med. 2005;7(3):191-7. [pmid: 15775755].
Obeidat B, Latimer J, Crawford R. Can optimal primary cytoreduction be predicted in advanced stage epithelial ovarian cancer? Role of preoperative serum CA-125 level. Gynecol Obstet Invest. 2004;57(3):153-6. [pmid: 14726621].
Obermair A, Tempfer C, Hefler L, et al. Concentration of vascular endothelial growth factor (VEGF) in the serum of patients with suspected ovarian cancer. Br J Cancer. 1998;77(11):1870-4. [pmid: 9667661].
Oehler MK, Caffier H. Diagnostic value of serum VEGF in women with ovarian tumors. Anticancer Res. 1999;19(4A):2519-22. [pmid: 10470186].
Onsrud M, Shabana A, Austgulen R. Soluble tumor necrosis factor receptors and CA 125 in serum as markers for epithelial ovarian cancer. Tumour Biol. 1996;17(2):90-6. [pmid: 8658018].
Opala T, Drews K, Rzymski P, et al. Evaluation of soluble intracellular adhesion molecule-1 (sICAM-1) in benign and malignant ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):255-7. [pmid: 12807235].
Opala T, Rzymski P, Wilczak M, et al. Evaluation of soluble tumour necrosis factor alpha receptors p55 and p75 in ovarian cancer patients. Eur J Gynaecol Oncol. 2005;26(1):43-6. [pmid: 15754999].
Peters-Engl C, Medl M, Ogris E, et al. Tumor-associated trypsin inhibitor (TATI) and cancer antigen 125 (CA125) in patients with epithelial ovarian cancer. Anticancer Res. 1995;15(6B):2727-30. [pmid: 8669854].
Petricoin EF, Ardekani AM, Hitt BA, et al. Use of proteomic patterns in serum to identify ovarian cancer. Lancet. 2002;359(9306):572-7. [pmid: 11867112].
Rai AJ, Zhang Z, Rosenzweig J, et al. Proteomic approaches to tumor marker discovery. Arch Pathol Lab Med. 2002;126(12):1518-26. [pmid: 12456215].
Riisbro R, Stephens RW, Brunner N, et al. Soluble urokinase plasminogen activator receptor in preoperatively obtained plasma from patients with gynecological cancer or benign gynecological diseases. Gynecol Oncol. 2001;82(3):523-31. [pmid: 11520150].
Rustin GJ, Marples M, Nelstrop AE, et al. Use of CA-125 to define progression of ovarian cancer in patients with persistently elevated levels. J Clin Oncol. 2001;19(20):4054-7. [pmid: 11600607].
Rustin GJ, Nelstrop AE, Tuxen MK, et al. Defining progression of ovarian carcinoma during follow-up according to CA 125: a North Thames Ovary Group Study. Ann Oncol. 1996;7(4):361-4. [pmid: 8805927].
Santillan A, Garg R, Zahurak ML, et al. Risk of epithelial ovarian cancer recurrence in patients with rising serum CA-125 levels within the normal range. J Clin Oncol. 2005;23(36):9338-43. [pmid: 16361633].
Sapi E, Okpokwasili NI, Rutherford T. Detection of telomerase-positive circulating epithelial cells in ovarian cancer patients. Cancer Detect Prev. 2002;26(2):158-67. [pmid: 12102151].
Saygili U, Guclu S, Uslu T, et al. Can serum CA-125 levels predict the optimal primary cytoreduction in patients with advanced ovarian carcinoma?. Gynecol Oncol. 2002;86(1):57-61. [pmid: 12079301].
Schutter EM, Mijatovic V, Kok A, et al. Urinary gonadotropin peptide (UGP) and serum CA 125 in gynaecologic practice, a clinical prospective study. Anticancer Res. 1999;19(6C):5551-7. [pmid: 10697615].
Schutter EM, Sohn C, Kristen P, et al. Estimation of probability of malignancy using a logistic model combining physical examination, ultrasound, serum CA 125, and serum CA 72-4 in postmenopausal women with a pelvic mass: an international multicenter study. Gynecol Oncol. 1998;69(1):56-63. [pmid: 9570999].
Sedlaczek P, Frydecka I, Gabrys M, et al. Comparative analysis of CA125, tissue polypeptide specific antigen, and soluble interleukin-2 receptor alpha levels in sera, cyst, and ascitic fluids from patients with ovarian carcinoma. Cancer. 2002;95(9):1886-93. [pmid: 12404282].
Senapad S, Neungton S, Thirapakawong C, et al. Predictive value of the combined serum CA 125 and TPS during chemotherapy and before second-look laparotomy in epithelial ovarian cancer. Anticancer Res. 2000;20(2B):1297-300. [pmid: 10810438].
Skates SJ, Horick N, Yu Y, et al. Preoperative sensitivity and specificity for early-stage ovarian cancer when combining cancer antigen CA-125II, CA 15-3, CA 72-4, and macrophage colony-stimulating factor using mixtures of multivariate normal distributions. J Clin Oncol. 2004;22(20):4059-66. [pmid: 15381683].
Sorace JM, Zhan M. A data review and re-assessment of ovarian cancer serum proteomic profiling. BMC Bioinformatics. 2003;4(1):24. [pmid: 12795817]. [pmcid: 165662].
Takano H, Okamoto A, Fukushima K, et al. Low specificity of cytokeratin 19 mRNA expression in the peripheral blood cells from patients with ovarian tumors. Oncol Rep. 2000;7(5):1023-5. [pmid: 10948333].
Tamakoshi K, Kikkawa F, Hasegawa N, et al. Clinical value of a new serum tumor marker, CA125II, in gynecologic disease: comparison with CA125. Gynecol Obstet Invest. 1995;39(2):125-9. [pmid: 7737582].
Tanir HM, Ozalp S, Yalcin OT, et al. Preoperative serum vascular endothelial growth factor (VEGF) in ovarian masses. Eur J Gynaecol Oncol. 2003;24(34):271-4. [pmid: 12807238].
Tempfer C, Hefler L, Heinzl H, et al. CYFRA 21-1 serum levels in women with adnexal masses and inflammatory diseases. Br J Cancer. 1998;78(8):1108-12. [pmid: 9792159].
Thougaard AV, Hogdall CK, Kjaer SK, et al. Determination of serum tetranectin: technical and clinical evaluation of three sandwich immunoassays. Clin Chim Acta. 1998;276(1):19-34. [pmid: 9760017].
Tsukishiro S, Suzumori N, Nishikawa H, et al. Use of serum secretory leukocyte protease inhibitor levels in patients to improve specificity of ovarian cancer diagnosis. Gynecol Oncol. 2005;96(2):516-9. [pmid: 15661245].
Tuxen MK, Soletormos G, Petersen PH, et al. Interpretation of sequential measurements of cancer antigen 125 (CA 125), carcinoembryonic antigen (CEA), and tissue polypeptide antigen (TPA) based on analytical imprecision and biological variation in the monitoring of ovarian cancer. Clin Chem Lab Med. 2001;39(6):531-8. [pmid: 11506467].
Tuxen MK, Soletormos G, Rustin GJ, et al. Biological variation and analytical imprecision of CA 125 in patients with ovarian cancer. Scand J Clin Lab Invest. 2000;60(8):713-21. [pmid: 11218154].
Udagawa Y, Aoki D, Ito K, et al. Clinical characteristics of a newly developed ovarian tumour marker, galactosyltransferase associated with tumour (GAT). Eur J Cancer. 1998;34(4):489-95. [pmid: 9713298].
van Haaften-Day C, Shen Y, Xu F, et al. OVX1, macrophage-colony stimulating factor, and CA-125-II as tumor markers for epithelial ovarian carcinoma: a critical appraisal. Cancer. 2001;92(11):2837-44. [pmid: 11753957].
van Ingen HE, Chan DW, Hubl W, et al. Analytical and clinical evaluation of an electrochemiluminescence immunoassay for the determination of CA 125. Clin Chem. 1998;44(12):2530-6. [pmid: 9836722].
Wakahara F, Kikkawa F, Nawa A, et al. Diagnostic efficacy of tumor markers, sonography, and intraoperative frozen section for ovarian tumors. Gynecol Obstet Invest. 2001;52(3):147-52. [pmid: 11598354].
Warwas M, Haczynska H, Gerber J, et al. Cathepsin B-like activity as a serum tumour marker in ovarian carcinoma. Eur J Clin Chem Clin Biochem. 1997;35(4):301-4. [pmid: 9166974].
Weitzel JN, Ding S, Larson GP, et al. The HRAS1 minisatellite locus and risk of ovarian cancer. Cancer Res. 2000;60(2):259-61. [pmid: 10667571].
Wen WH, Bernstein L, Lescallett J, et al. Comparison of TP53 mutations identified by oligonucleotide microarray and conventional DNA sequence analysis. Cancer Res. 2000;60(10):2716-22. [pmid: 10825146].
Wong C, Dai ZM, Lele SB, et al. Comparison of CA 125 after three courses of chemotherapy and results of second-look surgery. Eur J Gynaecol Oncol. 2000;21(1):70-3. [pmid: 10726624].
Wu B, Abbott T, Fishman D, et al. Comparison of statistical methods for classification of ovarian cancer using mass spectrometry data. Bioinformatics. 2003;19(13):1636-43. [pmid: 12967959].
Yu JK, Zheng S, Tang Y, et al. An integrated approach utilizing proteomics and bioinformatics to detect ovarian cancer. J Zhejiang Univ Sci B. 2005;6(4):227-31. [pmid: 15754417]. [pmcid: 1389728].
Yu JS, Ongarello S, Fiedler R, et al. Ovarian cancer identification based on dimensionality reduction for high-throughput mass spectrometry data. Bioinformatics. 2005;21(10):2200-9. [pmid: 15784749].
Yuce K, Baykal C, Genc C, et al. Diagnostic and prognostic value of serum and peritoneal fluid lactate dehydrogenase in epithelial ovarian cancer. Eur J Gynaecol Oncol. 2001;22(3):228-32. [pmid: 11501779].
Zakrzewska I, Borawska R, Poznanski J, et al. Significance of some tumor markers in differential diagnosis of ovarian tumor. Rocz Akad Med Bialymst. 1999;44:235-43. [pmid: 10697438].
Zarrinkar PP, Mainquist JK, Zamora M, et al. Arrays of arrays for high-throughput gene expression profiling. Genome Res. 2001;11(7):1256-61. [pmid: 11435408]. [pmcid: 311063].
Zhang Z, Bast RC Jr, Yu Y, et al. Three biomarkers identified from serum proteomic analysis for the detection of early stage ovarian cancer. Cancer Res. 2004;64(16):5882-90. [pmid: 15313933].
Zhu W, Wang X, Ma Y, et al. Detection of cancer-specific markers amid massive mass spectral data. Proc Natl Acad Sci U S A. 2003;100(25):14666-71. [pmid: 14657331]. [pmcid: 299756].