# Appendix C: Sample Data Abstraction Forms

Question 1: What is the evidence that ovarian cancer genomic tests performed in a typical clinical laboratory actually measure what they are purported to measure?

Study | Study Design | Description of Test(s) | Patient Characteristics | Results | Comments/Quality Scoring
StudyID | Geographical location | Genomic test(s) used: | Age: | [For each test reported, please provide a 2×2 table and report or calculate sensitivity, specificity, NPV, and PPV (all with confidence intervals); alternatively, for continuous variables, report the correlation coefficient or other measure of association. Also include data on reproducibility (inter- and intra-assay coefficient of variation, kappa, etc.).] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| [city & state (U.S.) or city & country (foreign)]: | Type(s) of samples | Mean (SD): | 1) [2×2 table - use this header space to provide information needed for reader to interpret “Test +,” “Test -,” “Ref stand +,” and “Ref stand -” headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Study dates [month & year]: | [delete all that do not apply]: | Median: | 2) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.) | Quality assessment:
| Size of population | Blood or tissue | Range: | | [+ if appropriate quality, - if not; add text to describe]
| [give num/denom for screening studies]: | Cyst fluid | Race/ethnicity (n [%]): | | Reference standard:
| Type of laboratory | Ascites | Diagnoses (n [%]): | | Verification bias:
| [delete all that do not apply]: | | Ovarian cancer: | | Test reliability/variability:
| Clinical lab | | Borderline: | | Sample size:
| Commercial lab | | Benign ovarian mass: | | Statistical tests:
| Hospital-based clinical samples | | Other (specify): | | Blinding:
| Research lab | | Healthy controls: | | Definition of +/- on screening test:
| Not reported | | Inclusion criteria: | | Grade:
| | | Exclusion criteria: | | This article is also relevant to:
| | | | | [delete all that do not apply]
| | | | | Question 2
| | | | | Question 3
| | | | | Question 4
| | | | | Question 5
| | | | | Question 6

Question 2: What is the sensitivity and specificity of genomic tests in detecting ovarian cancer in asymptomatic and symptomatic women, including high-risk women?

Study | Study Design | Patients | Clinical Presentation | Results | Comments/Quality Scoring
StudyID | Geographical location | Age: | Screening only (n [%]): | [For each test reported, please provide a 2×2 table and report or calculate sensitivity, specificity, NPV, and PPV (all with confidence intervals). Also include data on reproducibility (inter- and intra-assay coefficient of variation, kappa, etc.).] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| [city & state (U.S.) or city & country (foreign)]: | Mean (SD): | Diagnosis of mass: | 1) [2×2 table - use this header space to provide information needed for reader to interpret Test +, Test -, Disease +, and Disease - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Study dates [month & year]: | Median: | - Symptomatic (n [%]):; - Asymptomatic, detected by exam (n [%]):; - Asymptomatic, detected by imaging (n [%]) | 2) Data on other test accuracy measures (correlation coefficient, interclass correlation, etc.) | Quality assessment:
| Size of population | Range: | Additional data used for diagnosis: | | [+ if appropriate quality, - if not; add text to describe]
| [give num/denom for screening studies]: | Menopausal status (n [%]): | | | Reference standard:
| Type of population | Pre (< 45): | | | Verification bias:
| [delete all that do not apply]: | Peri (45–55): | | | Test reliability/variability:
| Screening | Post (> 55): | | | Sample size:
| Adnexal mass | Race/ethnicity (n [%]): | | | Statistical tests:
| Other (specify) | Risk factors (n [%]): | | | Blinding:
| Genomic test(s) used: | Family history: | | | Definition of +/- on screening test:
| Reference standard | Genotype: | | | Grade:
| [delete all that do not apply]: | Other (specify): | | | This article is also relevant to:
| Surgical pathology | Diagnoses (n [%]): | | | [delete all that do not apply]
| Clinical outcome (specify) | Ovarian cancer: | | | Question 1
| Reference standard applied to all test negatives?: | Borderline: | | | Question 3
| Test reliability established?: | Benign ovarian mass: | | | Question 4
| Statistical tests used: | Other (specify): | | | Question 5
| Blinding: | Healthy controls: | | | Question 6
| Definition of positive and negative on screening test: | Inclusion criteria:
| | Exclusion criteria:

Question 3: What is the evidence that genomic testing to detect ovarian cancer in asymptomatic women, including high-risk women, changes clinical management and leads to improved health outcomes?

Study | Study Design | Patients | Outcome Measures | Results | Comments/Quality Scoring
StudyID | Geographical location | Age: | Use of test results: [e.g., change in screening test or frequency] | For each outcome measured, report outcomes based on test result; include 95% confidence intervals if available. | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| [city & state (U.S.) or city & country (foreign)]: | Mean (SD): | Outcomes measured: | | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Study dates [month & year]: | Median: | [delete all that do not apply] | | Quality assessment:
| Study type [delete all but one]: | Range: | Cancer incidence | | [+ if appropriate quality, - if not; add text to describe]
| RCT | Menopausal status (n [%]): | Cancer mortality | | For RCT:
| Cohort | Pre (< 45): | Quality of life | | Randomization method:
| Case-control | Peri (45–55): | Other (specify) | | Blinding:
| Other (specify) | Post (> 55): | | | Dropout rate < 20%:
| Size of population: | Race/ethnicity (n [%]): | | | Adequacy of randomization concealment:
| Genomic test(s) used: | Risk factors (n [%]): | | | For cohort study:
| Reference standard: | Family history: | | | Unbiased selection of the cohort (prospective recruitment of subjects):
| [delete all that do not apply] | Genotype: | | | Large sample size:
| Surgical pathology | Other (specify): | | | Adequate description of the cohort:
| Clinical outcome (specify) | Inclusion criteria: | | | Use of validated method for genomic test:
| Test reliability established?: | Exclusion criteria: | | | Use of validated method for ascertaining clinical outcomes:
| Statistical tests used: | | | | Adequate follow-up period:
| Definition of positive and negative on screening test: | | | | Completeness of follow-up:
| | | | | Analysis (multivariate adjustments) and reporting of results:
| | | | | For case-control study:
| | | | | Valid ascertainment of cases:
| | | | | Unbiased selection of cases:
| | | | | Appropriateness of the control population:
| | | | | Verification that the control is free of cancer:
| | | | | Comparability of cases and controls with respect to potential confounders:
| | | | | Validated dietary assessment method:
| | | | | Appropriateness of statistical analyses:
| | | | | Grade:
| | | | | This article is also relevant to:
| | | | | [delete all that do not apply]
| | | | | Question 1
| | | | | Question 2
| | | | | Question 4
| | | | | Question 5
| | | | | Question 6

Question 4: What is the evidence that genomic testing in women with clinical suspicion of ovarian cancer or with already-diagnosed ovarian cancer changes clinical management and leads to improved health outcomes?

Study | Study Design | Patients | Outcome Measures | Results | Comments/Quality Scoring
StudyID | Geographical location | Age: | Use of test results: [e.g., change in screening test or frequency] | [For each outcome measured, report outcomes based on test result. Note that you should only abstract data when 2×2 tables can be constructed. Articles that report only Kaplan Meier curves or Hazard Ratios should not be abstracted.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| [city & state (U.S.) or city & country (foreign)]: | Mean (SD): | Outcomes measured: | 1) [2×2 table - use this space to provide information needed for reader to interpret Test +, Test -, Outcome +, and Outcome - headings in following table.] | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Study dates [month & year]: | Median: | [delete all that do not apply] | 2) [2×2 table - use this space to provide information needed for reader to interpret Test +, Test -, Outcome +, and Outcome - headings in following table.] | Quality assessment:
| Study type [delete all but one]: | Range: | Cancer incidence | 3) Hazard Ratio or other relevant information: | [+ if appropriate quality, - if not; add text to describe]
| RCT | Menopausal status (n [%]): | Cancer mortality | | For RCT:
| Cohort | Pre (< 45): | Quality of life | | Randomization method:
| Case-control | Peri (45–55): | Other (specify) | | Blinding:
| Other (specify) | Post (> 55): | | | Dropout rate < 20%:
| Size of population: | Race/ethnicity (n [%]): | | | Adequacy of randomization concealment:
| Genomic test(s) used: | Risk factors (n [%]): | | | For cohort study:
| Reference standard: | Family history: | | | Unbiased selection of the cohort (prospective recruitment of subjects):
| [delete all that do not apply] | Genotype: | | | Large sample size:
| Surgical pathology | Other (specify): | | | Adequate description of the cohort:
| Clinical outcome (specify) | Diagnoses (n [%]): | | | Use of validated method for genomic test:
| Test reliability established?: | Ovarian cancer: | | | Use of validated method for ascertaining clinical outcomes:
| Statistical tests used: | Borderline: | | | Adequate follow-up period:
| Definition of positive and negative on screening test: | Benign ovarian mass: | | | Completeness of follow-up:
| | Other (specify): | | | Analysis (multivariate adjustments) and reporting of results:
| | Healthy controls: | | | For case-control study:
| | Treatment (n [%]): | | | Valid ascertainment of cases:
| | Surgery: | | | Unbiased selection of cases:
| | Chemotherapy: | | | Appropriateness of the control population:
| | Platinum: | | | Verification that the control is free of cancer:
| | Taxol: | | | Comparability of cases and controls with respect to potential confounders:
| | Other (specify): | | | Validated dietary assessment method:
| | Other (specify): | | | Appropriateness of statistical analyses:
| | Inclusion criteria: | | | Grade:
| | Exclusion criteria: | | | This article is also relevant to:
| | | | | [delete all that do not apply]
| | | | | Question 1
| | | | | Question 2
| | | | | Question 3
| | | | | Question 5
| | | | | Question 6

Question 5: What are the harms of using genomic tests for ovarian cancer prevention and management?

Study | Study Design | Patients | Outcome Measures | Results | Comments/Quality Scoring
StudyID | Geographical location | Age: | Use of test results: [e.g., change in screening test or frequency] | For each outcome measured, report outcomes based on test result. | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| [city & state (U.S.) or city & country (foreign)]: | Mean (SD): | Outcomes measured: | 1) | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION]
| Study dates [month & year]: | Median: | [delete all that do not apply] | 2) | Quality assessment:
| Study type [delete all but one]: | Range: | Complications | 3) | [+ if appropriate quality, - if not; add text to describe]
| RCT | Menopausal status (n [%]): | Quality of life | 4) | For RCT:
| Cohort | Pre (< 45): | Other (specify) | 5) | Randomization method:
| Case-control | Peri (45–55): | | 6) | Blinding:
| Other (specify) | Post (> 55): | | 7) | Dropout rate < 20%:
| Size of population: | Race/ethnicity (n [%]): | | | Adequacy of randomization concealment:
| Genomic test(s) used: | Risk factors (n [%]): | | | For cohort study:
| Reference standard: | Family history: | | | Unbiased selection of the cohort (prospective recruitment of subjects):
| [delete all that do not apply] | Genotype: | | | Large sample size:
| Surgical pathology | Other (specify): | | | Adequate description of the cohort:
| Clinical outcome (specify) | Diagnoses (n [%]): | | | Use of validated method for genomic test:
| Test reliability established?: | Ovarian cancer: | | | Use of validated method for ascertaining clinical outcomes:
| Statistical tests used: | Borderline: | | | Adequate follow-up period:
| Definition of positive and negative on screening test: | Benign ovarian mass: | | | Completeness of follow-up:
| | Other (specify): | | | Analysis (multivariate adjustments) and reporting of results:
| | Healthy controls: | | | For case-control study:
| | Inclusion criteria: | | | Valid ascertainment of cases:
| | Exclusion criteria: | | | Unbiased selection of cases:
| | | | | Appropriateness of the control population:
| | | | | Verification that the control is free of cancer:
| | | | | Comparability of cases and controls with respect to potential confounders:
| | | | | Validated dietary assessment method:
| | | | | Appropriateness of statistical analyses:
| | | | | Grade:
| | | | | This article is also relevant to:
| | | | | [delete all that do not apply]
| | | | | Question 1
| | | | | Question 2
| | | | | Question 3
| | | | | Question 4
| | | | | Question 6