# Appendix B: List of Excluded Studies

All excluded studies listed below were reviewed in their full-text version. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## References

1 Abendstein B, Daxenbichler G, Windbichler G, et al. Predictive value of uPA, PAI-1, HER-2 and VEGF in the serum of ovarian cancer patients. Anticancer Res. 2000;20(1B):569-72. Exclude: non-specific general prognosis. [pmid: 10769727].
2 Adib TR, Henderson S, Perrett C, et al. Predicting biomarkers for ovarian cancer using gene-expression microarrays. Br J Cancer. 2004;90(3):686-92. Exclude: cell line only. [pmid: 14760385].
3 Afify AM, al-Khafaji BM. Diagnostic utility of thyroid transcription factor-1 expression in adenocarcinomas presenting in serous fluids. Acta Cytol. 2002;46(4):675-8. Exclude: no 2×2 table. [pmid: 12146029].
4 Afify AM, Ferguson AW, Davila RM, et al. Expression of CD44S and CD44v5 is more common in stage III than in stage I serous ovarian carcinomas. Appl Immunohistochem Mol Morphol. 2001;9(4):309-14. Exclude: denominator NOT patients. [pmid: 11759056].
5 Ahmed N, Oliva KT, Barker G, et al. Proteomic tracking of serum protein isoforms as screening biomarkers of ovarian cancer. Proteomics. 2005;5(17):4625-36. Exclude: no 2×2 table. [pmid: 16220531].
6 Ahmed N, Riley C, Rice GE, et al. Alpha(v)beta(6) integrin-A marker for the malignant potential of epithelial ovarian cancer. J Histochem Cytochem. 2002;50(10):1371-80. Exclude: denominator NOT patients. [pmid: 12364570].
7 Akahiro J, Konno R, Ito K, et al. Impact of serum interleukin-18 level as a prognostic indicator in patients with epithelial ovarian carcinoma. Int J Clin Oncol. 2004;9(1):42-6. Exclude: no 2×2 table. [pmid: 15162825].
8 Ala-Fossi SL, Aine R, Punnonen R, et al. Is potential to produce inhibins related to prognosis in ovarian granulosa cell tumors?. Eur J Gynaecol Oncol. 2000;21(2):187-9. Exclude: only germ cell or stromal. [pmid: 10843483].
9 Alexe G, Alexe S, Liotta LA, et al. Ovarian cancer detection by logical analysis of proteomic data. Proteomics. 2004;4(3):766-83. Exclude: mathematical model. [pmid: 14997498].
10 Ali-Fehmi R, Che M, Khalifeh I, et al. The effect of cyclooxygenase-2 expression on tumor vascularity in advanced stage ovarian serous carcinoma. Cancer. 2003;98(7):1423-9. Exclude: no 2×2 table. [pmid: 14508829].
11 Altavilla G, Marchetti M, Padovan P, et al. Predictive value of proliferative cellular nuclear antigen (PCNA) and Ki-67 antigen in advanced stage serous papilliferous ovarian cancer. Eur J Gynaecol Oncol. 1996;17(6):524-8. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 8971535].
12 Altevogt P, Fogel M. The role of L1 in the progression of ovarian carcinomas. Zentralbl Gynakol. 2004;126(5):323-5. Exclude: relevant review. [pmid: 15478051].
13 Alvarez Secord A, Sayer R, Snyder SA, et al. The relationship between serum vascular endothelial growth factor, persistent disease, and survival at second-look laparotomy in ovarian cancer. Gynecol Oncol. 2004;94(1):74-9. Exclude: no 2×2 table. [pmid: 15262122].
14 Andersen MR, Nelson J, Peacock S, et al. Worry about ovarian cancer risk and use of screening by high-risk women: how you recruit affects what you find. Am J Med Genet A. 2004;129(2):130-5. Exclude: Background only. [pmid: 15316957].
15 Antonic J, Rakar S. Validity of colour and pulsed Doppler US and tumour marker CA 125 in differentiation between benign and malignant ovarian masses. Eur J Gynaecol Oncol. 1996;17(1):29-35. Exclude: no 2×2 table. [pmid: 8750512].
16 Aranganathan S, Senthil K, Nalini N. A case control study of glycoprotein status in ovarian carcinoma. Clin Biochem. 2005;38(6):535-9. Exclude: no 2×2 table. [pmid: 15885233].
17 Aris VM, Cody MJ, Cheng J, et al. Noise filtering and nonparametric analysis of microarray data underscores discriminating markers of oral, prostate, lung, ovarian and breast cancer. BMC Bioinformatics. 2004;5(1):185. Exclude: denominator NOT patients. [pmid: 15569388]. [pmcid: 538261].
18 Arnold JM, Cummings M, Purdie D, et al. Reduced expression of intercellular adhesion molecule-1 in ovarian adenocarcinomas. Br J Cancer. 2001;85(9):1351-8. Exclude: cell line only. [pmid: 11720474].
19 Arslan AA, Zeleniuch-Jacquotte A, Lundin E, et al. Serum follicle-stimulating hormone and risk of epithelial ovarian cancer in postmenopausal women. Cancer Epidemiol Biomarkers Prev. 2003;12(12):1531-5. Exclude: not diagnostic test. [pmid: 14693749].
20 Attanoos RL, Webb R, Dojcinov SD, et al. Value of mesothelial and epithelial antibodies in distinguishing diffuse peritoneal mesothelioma in females from serous papillary carcinoma of the ovary and peritoneum. Histopathology. 2002;40(3):237-44. Exclude: pathology study. [pmid: 11895489].
21 Auranen A, Grenman S, Kleml PJ. Immunohistochemically detected p53 and HER-2/neu expression and nuclear DNA content in familial epithelial ovarian carcinomas. Cancer. 1997;79(11):2147-53. Exclude: no 2×2 table. [pmid: 9179061].
22 Ayhan A, Ertunc D, Tok EC, et al. Expression of the c-Met in advanced epithelial ovarian cancer and its prognostic significance. Int J Gynecol Cancer. 2005;15(4):618-23. Exclude: no 2×2 table. [pmid: 16014115].
23 Baekelandt M, Holm R, Nesland JM, et al. Expression of apoptosis-related proteins is an independent determinant of patient prognosis in advanced ovarian cancer. J Clin Oncol. 2000;18(22):3775-81. Exclude: non-specific general prognosis. [pmid: 11078490].
24 Baekelandt MM, Holm R, Nesland JM, et al. P-glycoprotein expression is a marker for chemotherapy resistance and prognosis in advanced ovarian cancer. Anticancer Res. 2000;20(2B):1061-7. Exclude: non-specific general prognosis. [pmid: 10810398].
25 Bajetta E, Di Leo A, Biganzoli L, et al. Phase II study of vinorelbine in patients with pretreated advanced ovarian cancer: activity in platinum-resistant disease. J Clin Oncol. 1996;14(9):2546-51. Exclude: unrelated. [pmid: 8823334].
26 Bandopadhyay M, Ganguly AK. Putrescine, DNA, RNA and protein contents in human uterine, breast and rectal cancer. J Postgrad Med. 2000;46(3):172-5. Exclude: denominator NOT patients. [pmid: 11298463].
27 Banks RE, Gearing AJ, Hemingway IK, et al. Circulating intercellular adhesion molecule-1 (ICAM-1), E-selectin and vascular cell adhesion molecule-1 (VCAM-1) in human malignancies. Br J Cancer. 1993;68(1):122-4. Exclude: no OVCA-specific data. [pmid: 7686390].
28 Barbati A, Mariani L, Porpora MG, et al. Serum evaluation of P53 protein in patients with gynaecological cancer. Anticancer Res. 2000;20(2A):1033-5. Exclude: no 2×2 table. [pmid: 10810393].
29 Barbieri F, Lorenzi P, Ragni N, et al. Overexpression of cyclin D1 is associated with poor survival in epithelial ovarian cancer. Oncology. 2004;66(4):310-5. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 15218299].
30 Bard MP, Hegmans JP, Hemmes A, et al. Proteomic analysis of exosomes isolated from human malignant pleural effusions. Am J Respir Cell Mol Biol. 2004;31(1):114-21. Exclude: N=1 case report. [pmid: 14975938].
31 Baron AT, Lafky JM, Boardman CH, et al. Serum sErbB1 and epidermal growth factor levels as tumor biomarkers in women with stage III or IV epithelial ovarian cancer. Cancer Epidemiol Biomarkers Prev. 1999;8(2):129-37. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 10067810].
32 Baron-Hay S, Boyle F, Ferrier A, et al. Elevated serum insulin-like growth factor binding protein-2 as a prognostic marker in patients with ovarian cancer. Clin Cancer Res. 2004;10(5):1796-806. Exclude: no 2×2 table. [pmid: 15014034].
33 Barton DP, Blanchard DK, Michelini-Norris B, et al. High serum and ascitic soluble interleukin-2 receptor alpha levels in advanced epithelial ovarian cancer. Blood. 1993;81(2):424-9. Exclude: no 2×2 table. [pmid: 8422462].
34 Bayani J, Brenton JD, Macgregor PF, et al. Parallel analysis of sporadic primary ovarian carcinomas by spectral karyotyping, comparative genomic hybridization, and expression microarrays. Cancer Res. 2002;62(12):3466-76. Exclude: cell line only. [pmid: 12067990].
35 Bellotti T, Luo Z, Gammerman A, et al. Qualified predictions for microarray and proteomics pattern diagnostics with confidence machines. Int J Neural Syst. 2005;15(4):247-58. Exclude: no 2×2 table. [pmid: 16187401].
36 Ben-Arie A, Hagay Z, Ben-Hur H, et al. Elevated serum alkaline phosphatase may enable early diagnosis of ovarian cancer. Eur J Obstet Gynecol Reprod Biol. 1999;86(1):69-71. Exclude: N=1 case report. [pmid: 10471145].
37 Ben-Hur H, Gurevich P, Ben-Arie A, et al. Apoptosis and apoptosis-related proteins (Fas, Fas ligand, bcl-2, p53) in macrophages of human ovarian epithelial tumors. Eur J Gynaecol Oncol. 2000;21(2):141-5. Exclude: cell line only. [pmid: 10843472].
38 Berchuck A, Iversen ES, Lancaster JM, et al. Patterns of gene expression that characterize long-term survival in advanced stage serous ovarian cancers. Clin Cancer Res. 2005;11(10):3686-96. Exclude: no 2×2 table. [pmid: 15897565].
39 Bergen HR 3rd, Vasmatzis G, Cliby WA, et al. Discovery of ovarian cancer biomarkers in serum using NanoLC electrospray ionization TOF and FT-ICR mass spectrometry. Dis Markers. 2003-2004;19(45):239-49. Exclude: no quantification of reproducibility. [pmid: 15266667].
40 Berker B, Dunder I, Ensari A, et al. Prognostic significance of apoptotic index and bcl-2 and p53 expression in epithelial ovarian carcinoma. Eur J Gynaecol Oncol. 2002;23(6):505-10. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 12556092].
41 Berker B, Dunder I, Ensari A, et al. Prognostic value of p53 accumulation in epithelial ovarian carcinomas. Arch Gynecol Obstet. 2002;266(4):205-9. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 12192480].
42 Bernardini M, Lee CH, Beheshti B, et al. High-resolution mapping of genomic imbalance and identification of gene expression profiles associated with differential chemotherapy response in serous epithelial ovarian cancer. Neoplasia. 2005;7(6):603-13. Exclude: no 2×2 table. [pmid: 16036111]. [pmcid: 1501280].
43 Bese T, Nomir SK. The importance of serum insulin-like growth factor-I level determination in the follow-up of patients with epithelial ovarian cancer. Eur J Gynaecol Oncol. 2001;22(5):372-6. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 11766744].
44 Bild AH, Yao G, Chang JT, et al. Oncogenic pathway signatures in human cancers as a guide to targeted therapies. Nature. 2006;439(7074):353-7. Exclude: no 2×2 table. [pmid: 16273092].
45 Bildrici K, Tel N, Ozalp SS, et al. Prognostic significance of DNA topoisomerase II-alpha (Ki-S1) immunoexpression in endometrial carcinoma. Eur J Gynaecol Oncol. 2002;23(6):540-4. Exclude: not OVCA. [pmid: 12556100].
46 Blandy C, Chabal F, Stoppa-Lyonnet D, et al. Testing participation in BRCA1/2-positive families: initiator role of index cases. Genet Test. 2003;7(3):225-33. Exclude: BRCA-Q5. [pmid: 14658447].
47 Bluman LG, Rimer BK, Regan Sterba K, et al. Attitudes, knowledge, risk perceptions and decision-making among women with breast and/or ovarian cancer considering testing for BRCA1 and BRCA2 and their spouses. Psychooncology. 2003;12(5):410-27. Exclude: BRCA-Q5. [pmid: 12833555].
48 Boente MP, Berchuck A, Rodriguez GC, et al. The effect of interferon gamma on epidermal growth factor receptor expression in normal and malignant ovarian epithelial cells. Am J Obstet Gynecol. 1992;167(6):1877-82. Exclude: cell line only. [pmid: 1361720].
49 Bon GG, Kenemans P, Verstraeten R, et al. Serum tumor marker immunoassays in gynecologic oncology: establishment of reference values. Am J Obstet Gynecol. 1996;174(1 Pt 1):107-14. Exclude: no 2×2 table. [pmid: 8571992].
50 Bonadona V, Saltel P, Desseigne F, et al. Cancer patients who experienced diagnostic genetic testing for cancer susceptibility: reactions and behavior after the disclosure of a positive test result. Cancer Epidemiol Biomarkers Prev. 2002;11(1):97-104. Exclude: Q5 pre-10-2004. [pmid: 11815406].
51 Bonome T, Lee JY, Park DC, et al. Expression profiling of serous low malignant potential, low-grade, and high-grade tumors of the ovary. Cancer Res. 2005;65(22):10602-12. Exclude: no 2×2 table. [pmid: 16288054].
52 Boran N, Kayikcioglu F, Yalvac S, et al. Significance of serum and peritoneal fluid lactate dehydrogenase levels in ovarian cancer. Gynecol Obstet Invest. 2000;49(4):272-4. Exclude: no 2×2 table. [pmid: 10828712].
53 Borgono CA, Grass L, Soosaipillai A, et al. Human kallikrein 14: a new potential biomarker for ovarian and breast cancer. Cancer Res. 2003;63(24):9032-41. Exclude: cell line only. [pmid: 14695222].
54 Bosserhoff AK, Lederer M, Kaufmann M, et al. MIA, a novel serum marker for progression of malignant melanoma. Anticancer Res. 1999;19(4A):2691-3. Exclude: not OVCA. [pmid: 10470221].
55 Bourdon V, Naef F, Rao PH, et al. Genomic and expression analysis of the 12p11–p12 amplicon using EST arrays identifies two novel amplified and overexpressed genes. Cancer Res. 2002;62(21):6218-23. Exclude: cell line only. [pmid: 12414650].
56 Broadstock M, Michie S, Gray J, et al. The psychological consequences of offering mutation searching in the family for those at risk of hereditary breast and ovarian cancer—a pilot study. Psychooncology. 2000;9(6):537-48. Exclude: Q5 pre-10-2004. [pmid: 11180589].
57 Brown RW, Campagna LB, Dunn JK, et al. Immunohistochemical identification of tumor markers in metastatic adenocarcinoma. A diagnostic adjunct in the determination of primary site. Am J Clin Pathol. 1997;107(1):12-9. Exclude: no 2×2 table. [pmid: 8980361].
58 But I, et al. Influence of tumor grade on expression of CA 125 in serum and tissue in patients with serous ovarian carcinoma. Wien Klin Wochenschr. 2003;115(78):255-8. Exclude: no 2×2 table. [pmid: 12778778].
59 Cajigas HE, Fariza E, Scully RE, et al. Enhancement of tumor-associated glycoprotein-72 antigen expression in hormone-related ovarian serous borderline tumors. Cancer. 1991;68(2):348-54. Exclude: no 2×2 table. [pmid: 2070334].
60 Callet N, Delaunay J, Pichon MF. Serum sICAM-1 (soluble intercellular adhesion molecule-1) and M-CSF (macrophage colony-stimulating growth factor) throughout monitoring of 34 non-serous ovarian cancers. Eur J Gynaecol Oncol. 2000;21(2):135-40. Exclude: denominator NOT patients. [pmid: 10843471].
61 Cameron RI, Ashe P, O'Rourke DM, et al. A panel of immunohistochemical stains assists in the distinction between ovarian and renal clear cell carcinoma. Int J Gynecol Pathol. 2003;22(3):272-6. Exclude: pathology study. [pmid: 12819395].
62 Candido Dos Reis FJ, Moreira de Andrade J, Bighetti S. CA 125 and vascular endothelial growth factor in the differential diagnosis of epithelial ovarian tumors. Gynecol Obstet Invest. 2002;54(3):132-6. Exclude: N=7. [pmid: 12571433].
63 Cane P, Azen C, Lopez E, et al. Tumor marker trends in asymptomatic women at risk for ovarian cancer: relevance for ovarian cancer screening. Gynecol Oncol. 1995;57(2):240-5. Exclude: no 2×2 table. [pmid: 7729742].
64 Canzonieri V, Viel A, Visentin MC, et al. Diagnostic and biological determinants in undifferentiated and poorly differentiated ovarian carcinomas. Pathologica. 1995;87(5):492-7. Exclude: no 2×2 table. [pmid: 8868173].
65 Cao D, Ji H, Ronnett BM. Expression of mesothelin, fascin, and prostate stem cell antigen in primary ovarian mucinous tumors and their utility in differentiating primary ovarian mucinous tumors from metastatic pancreatic mucinous carcinomas in the ovary. Int J Gynecol Pathol. 2005;24(1):67-72. Exclude: no 2×2 table. [pmid: 15626919].
66 Carico E, Chicchirichi R, Atlante M, et al. CA 125 in ovarian cysts, serous effusions and peritoneal washings: immunocytochemical expression. Anticancer Res. 1995;15(2):631-4. Exclude: CA125 for diagnosis. [pmid: 7763049].
67 Ceccaroni M, Chieco P, Alboni C, et al. p53 expression, DNA ploidy and mitotic index as prognostic factors in patients with epithelial ovarian carcinoma. Tumori. 2004;90(6):600-6. Exclude: no 2×2 table. [pmid: 15762364].
68 Chan JK, Loizzi V, Magistris A, et al. Differences in prognostic molecular markers between women over and under 45 years of age with advanced ovarian cancer. Clin Cancer Res. 2004;10(24):8538-43. Exclude: no 2×2 table. [pmid: 15623636].
69 Chang HW, Ali SZ, Cho SK, et al. Detection of allelic imbalance in ascitic supernatant by digital single nucleotide polymorphism analysis. Clin Cancer Res. 2002;8(8):2580-5. Exclude: not OVCA. [pmid: 12171887].
70 Chatterjee M, Mohapatra S, Ionan A, et al. Diagnostic markers of ovarian cancer by high-throughput antigen cloning and detection on arrays. Cancer Res. 2006;66(2):1181-90. Exclude: no 2×2 table. [pmid: 16424057]. [pmcid: 2546578].
71 Chen LM, Yamada SD, Fu YS, et al. Molecular similarities between primary peritoneal and primary ovarian carcinomas. Int J Gynecol Cancer. 2003;13(6):749-55. Exclude: no 2×2 table. [pmid: 14675310].
72 Cheng L, Thomas A, Roth LM, et al. OCT4: a novel biomarker for dysgerminoma of the ovary. Am J Surg Pathol. 2004;28(10):1341-6. Exclude: only germ cell or stromal. [pmid: 15371950].
73 Chhieng DC, Yee H, Cangiarella JF, et al. Use of E-cadherin and CD44 aids in the differentiation between reactive mesothelial cells and carcinoma cells in pelvic washings. Cancer. 2000;90(5):299-306. Exclude: non-specific general prognosis. [pmid: 11038427].
74 Chien CH, Huang CC, Lin YH, et al. Detection of serum transforming growth factor-alpha in patients of primary epithelial ovarian cancers by enzyme immunoassay. Gynecol Oncol. 1997;66(3):405-10. Exclude: non-specific general prognosis. [pmid: 9299253].
75 Chou YY, Jeng YM, Kao HL, et al. Differentiation of ovarian mucinous carcinoma and metastatic colorectal adenocarcinoma by immunostaining with beta-catenin. Histopathology. 2003;43(2):151-6. Exclude: stain study. [pmid: 12877730].
76 Chudecka-Glaz A, Rzepka-Gorska I, Kosmowska B. Gonadotropin (LH, FSH) levels in serum and cyst fluid in epithelial tumors of the ovary. Arch Gynecol Obstet. 2004;270(3):151-6. Exclude: no 2×2 table. [pmid: 12883823].
77 Cioffi M, Fratta M, Gazzerro P, et al. OVCA (CA125) second generation: technical aspects and serum levels in controls, patients with liver disease, pregnant women and patients with ovarian disease. Tumori. 1997;83(2):594-8. Exclude: Background only. [pmid: 9226027].
78 Ciris M, Erhan Y, Zekioglu O, et al. Inhibin alpha and beta expression in ovarian stromal tumors and their histological equivalences. Acta Obstet Gynecol Scand. 2004;83(5):491-6. Exclude: only germ cell or stromal. [pmid: 15059165].
79 Codegoni AM, Bertoni F, Patregnani C, et al. Allelic expression of p73 in human ovarian cancers. Ann Oncol. 1999;10(8):949-53. Exclude: no 2×2 table. [pmid: 10509157].
80 Codegoni AM, Castagna S, Mangioni C, et al. DNA-topoisomerase I activity and content in epithelial ovarian cancer. Ann Oncol. 1998;9(3):313-9. Exclude: no 2×2 table. [pmid: 9602266].
81 Collins Y, Tan DF, Pejovic T, et al. Identification of differentially expressed genes in clinically distinct groups of serous ovarian carcinomas using cDNA microarray. Int J Mol Med. 2004;14(1):43-53. Exclude: non-specific general prognosis. [pmid: 15202015].
82 Colombet I, Xu Y, Jaulent MC, et al. A generic computerized method for estimate of familial risks. Proc AMIA Symp 2002;175–9. Exclude: Background only.
83 Cooke I, O'Brien M, Charnock FM, et al. Inhibin as a marker for ovarian cancer. Br J Cancer. 1995;71(5):1046-50. Exclude: no 2×2 table. [pmid: 7734297].
84 Cooper BC, Sood AK, Davis CS, et al. Preoperative CA 125 levels: an independent prognostic factor for epithelial ovarian cancer. Obstet Gynecol. 2002;100(1):59-64. Exclude: no 2×2 table. [pmid: 12100804].
85 Coyne JC, Kruus L, Racioppo M, et al. What do ratings of cancer-specific distress mean among women at high risk of breast and ovarian cancer?. Am J Med Genet A. 2003;116(3):222-8. Exclude: BRCA-Q5. [pmid: 12503096].
86 Cruickshank DJ, Haites N, Anderson S, et al. The multidisciplinary management of a family with epithelial ovarian cancer. Br J Obstet Gynaecol. 1992;99(3):226-31. Exclude: no data on harms. [pmid: 1606122].
87 Crump C, McIntosh MW, Urban N, et al. Ovarian cancer tumor marker behavior in asymptomatic healthy women: implications for screening. Cancer Epidemiol Biomarkers Prev. 2000;9(10):1107-11. Exclude: no 2×2 table. [pmid: 11045795].
88 Davidson B, Goldberg I, Givant-Horwitz V, et al. Caveolin-1 expression in ovarian carcinoma is MDR1 independent. Am J Clin Pathol. 2002;117(2):225-34. Exclude: no 2×2 table. [pmid: 11863219].
89 Davidson B, Goldberg I, Gotlieb WH, et al. High levels of MMP-2, MMP-9, MT1-MMP and TIMP-2 mRNA correlate with poor survival in ovarian carcinoma. Clin Exp Metastasis. 1999;17(10):799-808. Exclude: non-specific general prognosis. [pmid: 11089877].
90 Davidson B, Gotlieb WH, Ben-Baruch G, et al. Expression of carbohydrate antigens in advanced-stage ovarian carcinomas and their metastases-A clinicopathologic study. Gynecol Oncol. 2000;77(1):35-43. Exclude: non-specific general prognosis. [pmid: 10739688].
91 de Bruijn HW, ten Hoor KA, van der Zee AG. Serum and cystic fluid levels of soluble interleukin-2 receptor-alpha in patients with epithelial ovarian tumors are correlated. Tumour Biol. 1998;19(3):160-6. Exclude: no 2×2 table. [pmid: 9591042].
92 De Cecco L, Marchionni L, Gariboldi M, et al. Gene expression profiling of advanced ovarian cancer: characterization of a molecular signature involving fibroblast growth factor 2. Oncogene. 2004;23(49):8171-83. Exclude: non-specific general prognosis. [pmid: 15377994].
93 De Jaco P, Asselain B, Orlandi C, et al. Evaluation of circulating tumor necrosis factor-alpha in patients with gynecological malignancies. Int J Cancer. 1991;48(3):375-8. Exclude: no 2×2 table. [pmid: 2040531].
94 de la Cuesta R, Maestro ML, Solana J, et al. Tissue quantification of CA 125 in epithelial ovarian cancer. Int J Biol Markers. 1999;14(2):106-14. Exclude: no 2×2 table. [pmid: 10399630].
95 Dehaven K, Taylor DD, Gercel-Taylor C. Comparison of serum vascular endothelial growth levels between patients with and without ovarian malignancies. Int J Gynecol Cancer. 2002;12(6):715-9. Exclude: no 2×2 table. [pmid: 12445248].
96 Dehn H, Hogdall EV, Johansen JS, et al. Plasma YKL-40, as a prognostic tumor marker in recurrent ovarian cancer. Acta Obstet Gynecol Scand. 2003;82(3):287-93. Exclude: recurrence prognosis. [pmid: 12694127].
97 Demirkiran F, Kumbak B, Bese T, et al. Vascular endothelial growth factor in adnexal masses. Int J Gynaecol Obstet. 2003;83(1):53-8. Exclude: no 2×2 table. [pmid: 14511872].
98 den Ouden M, Ubachs JM, Stoot JE, et al. Thrombin-antithrombin III and D-dimer plasma levels in patients with benign or malignant ovarian tumours. Scand J Clin Lab Invest. 1998;58(7):555-9. Exclude: no 2×2 table. [pmid: 9890338].
99 Deng HB, Parekh HK, Chow KC, et al. Increased expression of dihydrodiol dehydrogenase induces resistance to cisplatin in human ovarian carcinoma cells. J Biol Chem. 2002;277(17):15035-43. Exclude: cell line only. [pmid: 11842089].
100 Denison SR, Becker NA, Ferber MJ, et al. Transcriptional profiling reveals that several common fragile-site genes are downregulated in ovarian cancer. Genes Chromosom Cancer. 2002;34(4):406-15. Exclude: no 2×2 table. [pmid: 12112530].
101 Denkert C, Kobel M, Pest S, et al. Expression of cyclooxygenase 2 is an independent prognostic factor in human ovarian carcinoma. Am J Pathol. 2002;160(3):893-903. Exclude: no 2×2 table. [pmid: 11891188]. [pmcid: 1867167].
102 Depasquale S, Lambert-Messerlian G, Quddus MR, et al. Molecular analysis of inhibin A and activin A subunit gene loci in epithelial ovarian cancer. Int J Gynecol Cancer. 2002;12(5):443-7. Exclude: no 2×2 table. [pmid: 12366660].
103 Diamandis EP, Borgono CA, Scorilas A, et al. Immunofluorometric quantification of human kallikrein 5 expression in ovarian cancer cytosols and its association with unfavorable patient prognosis. Tumour Biol. 2003;24(6):299-309. Exclude: no 2×2 table. [pmid: 15004490].
104 Ding W, Tang Q, Espina V, et al. A transforming growth factor-beta receptor-interacting protein frequently mutated in human ovarian cancer. Cancer Res. 2005;65(15):6526-33. Exclude: cell line only. [pmid: 16061631].
105 Donnerstag B, Baum RP, Oltrogge JB, et al. A preliminary study on the functional analysis of peripheral blood lymphocytes from ovarian cancer patients developing HAMA after immunoscintigraphy. Int J Biol Markers. 1994;9(2):115-20. Exclude: no 2×2 table. [pmid: 7930762].
106 Donninger H, Bonome T, Radonovich M, et al. Whole genome expression profiling of advance stage papillary serous ovarian cancer reveals activated pathways. Oncogene. 2004;23(49):8065-77. Exclude: no 2×2 table. [pmid: 15361855].
107 Donovan JT, Shiraki W, Pekow PS, et al. Reliability of quantitating proliferative cell nuclear antigen in epithelial ovarian tumors. Anal Quant Cytol Histol. 1994;16(2):85-9. Exclude: non-specific general prognosis. [pmid: 7913806].
108 Duan Z, Lamendola DE, Duan Y, et al. Description of paclitaxel resistance-associated genes in ovarian and breast cancer cell lines. Cancer Chemother Pharmacol. 2005;55(3):277-85. Exclude: cell line only. [pmid: 15565326].
109 Dupont J, Tanwar MK, Thaler HT, et al. Early detection and prognosis of ovarian cancer using serum YKL-40. J Clin Oncol. 2004;22(16):3330-9. Exclude: non-specific general prognosis. [pmid: 15310777].
110 El-Shalakany A, Abou-Talib Y, Shalaby HS, et al. Preoperative serum inhibin levels in patients with ovarian tumors. J Obstet Gynaecol Res. 2004;30(2):155-61. Exclude: not asymptomatic women. [pmid: 15009621].
111 Emmert-Buck MR, Chuaqui R, Zhuang Z, et al. Molecular analysis of synchronous uterine and ovarian endometrioid tumors. Int J Gynecol Pathol. 1997;16(2):143-8. Exclude: not asymptomatic women. [pmid: 9100068].
112 Engelen MJ, de Bruijn HW, Hollema H, et al. Serum CA 125, carcinoembryonic antigen, and CA 19-9 as tumor markers in borderline ovarian tumors. Gynecol Oncol. 2000;78(1):16-20. Exclude: no 2×2 table. [pmid: 10873403].
113 Erkinheimo TL, Lassus H, Finne P, et al. Elevated cyclooxygenase-2 expression is associated with altered expression of p53 and SMAD4, amplification of HER-2/neu, and poor outcome in serous ovarian carcinoma. Clin Cancer Res. 2004;10(2):538-45. Exclude: no 2×2 table. [pmid: 14760075].
114 Fajac A, Benard J, Lhomme C, et al. c-erbB2 gene amplification and protein expression in ovarian epithelial tumors: evaluation of their respective prognostic significance by multivariate analysis. Int J Cancer. 1995;64(2):146-51. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 7615357].
115 Fang CY, Miller SM, Malick J, et al. Psychosocial correlates of intention to undergo prophylactic oophorectomy among women with a family history of ovarian cancer [erratum appears in Prev Med. 2004 Jul;39(1):222]. Prev Med. 2003;37(5):424-31. Exclude: Q5 pre-10-2004. [pmid: 14572427].
116 Farley J, Smith LM, Darcy KM, et al. Cyclin E expression is a significant predictor of survival in advanced, suboptimally debulked ovarian epithelial cancers: a Gynecologic Oncology Group study. Cancer Res. 2003;63(6):1235-41. Exclude: no 2×2 table. [pmid: 12649182].
117 Flemming P, Wellmann A, Maschek H, et al. Monoclonal antibodies against inhibin represent key markers of adult granulosa cell tumors of the ovary even in their metastases. A report of three cases with late metastasis, being previously misinterpreted as hemangiopericytoma. Am J Surg Pathol. 1995;19(8):927-33. Exclude: only germ cell or stromal. [pmid: 7611539].
118 Fogel M, Gutwein P, Mechtersheimer S, et al. L1 expression as a predictor of progression and survival in patients with uterine and ovarian carcinomas. Lancet. 2003;362(9387):869-75. Exclude: no 2×2 table. [pmid: 13678974].
119 Franco K, Belinson J, Casey G, et al. Adjustment to perceived ovarian cancer risk. Psychooncology. 2000;9(5):411-7. Exclude: Q5 pre-10-2004. [pmid: 11038479].
120 Frasci G, Conforti S, Zullo F, et al. A risk model for ovarian carcinoma patients using CA 125: time to normalization renders second-look laparotomy redundant. Cancer. 1996;77(6):1122-30. Exclude: mathematical model. [pmid: 8635133].
121 Frias AE Jr, Li H, Keeney GL, et al. Preoperative serum level of inhibin A is an independent prognostic factor for the survival of postmenopausal women with epithelial ovarian carcinoma. Cancer. 1999;85(2):465-71. Exclude: no 2×2 table. [pmid: 10023716].
122 Fujiwaki R, Hata K, Nakayama K, et al. Thymidylate synthase expression in epithelial ovarian cancer: relationship with thymidine phosphorylase expression and prognosis. Oncology. 2000;59(2):152-7. Exclude: no 2×2 table. [pmid: 10971175].
123 Fung ET, Yip TT, Lomas L, et al. Classification of cancer types by measuring variants of host response proteins using SELDI serum assays. Int J Cancer. 2005;115(5):783-9. Exclude: no 2×2 table. [pmid: 15704152].
124 Furey TS, Cristianini N, Duffy N, et al. Support vector machine classification and validation of cancer tissue samples using microarray expression data. Bioinformatics. 2000;16(10):906-14. Exclude: mathematical model. [pmid: 11120680].
125 Gadducci A, Marrai R, Baicchi U, et al. The measurement of plasma D-dimer (DD) levels in the follow-up of patients with ovarian cancer. Anticancer Res. 1995;15(6B):2683-6. Exclude: multiple samples per patient. [pmid: 8669847].
126 Gansler TS, Hardman W 3rd, Hunt DA, et al. Increased expression of fatty acid synthase (OA-519) in ovarian neoplasms predicts shorter survival. Hum Pathol. 1997;28(6):686-92. Exclude: no 2×2 table. [pmid: 9191002].
127 Garcia MJ, Pole JC, Chin SF, et al. A 1 Mb minimal amplicon at 8p11–12 in breast cancer identifies new candidate oncogenes. Oncogene. 2005;24(33):5235-45. Exclude: cell line only. [pmid: 15897872].
128 Garzetti GG, Ciavattini A, Lucarini G, et al. Increased serum 72 KDa metalloproteinase in serous ovarian tumors: comparison with CA 125. Anticancer Res. 1996;16(4A):2123-7. Exclude: no 2×2 table. [pmid: 8712754].
129 Gebauer G, Rieger M, Jager W, et al. IMMULITE OM-MA assay: a useful diagnostic tool in patients with benign and malignant ovarian tumors. Anticancer Res. 1999;19(4A):2535-6. Exclude: no 2×2 table. [pmid: 10470190].
130 Gebauer G, Rieger M, Jager W, et al. Prognostic relevance of soluble interleukin-2 receptors in patients with ovarian tumors. Anticancer Res. 1999;19(4A):2509-11. Exclude: non-specific general prognosis. [pmid: 10470184].
131 Geisler JP, Geisler HE, Miller GA, et al. p53 and bcl-2 in epithelial ovarian carcinoma: their value as prognostic indicators at a median follow-up of 60 months. Gynecol Oncol. 2000;77(2):278-82. Exclude: no 2×2 table. [pmid: 10785478].
132 Geisler JP, Tammela JE, Manahan KJ, et al. HSP27 in patients with ovarian carcinoma: still an independent prognostic indicator at 60 months follow-up. Eur J Gynaecol Oncol. 2004;25(2):165-8. Exclude: no 2×2 table. [pmid: 15032273].
133 Georgescu CV, Florescu M, Simionescu C. Value of immunohistochemistry in confirming undifferentiated ovarian carcinomas. Rom J Morphol Embryol. 1999-2004;45:133-42. Exclude: no 2×2 table. [pmid: 15847387].
134 Ghimenti C, Sensi E, Presciuttini S, et al. Germline mutations of the BRCA1-associated ring domain (BARD1) gene in breast and breast/ovarian families negative for BRCA1 and BRCA2 alterations. Genes Chromosom Cancer. 2002;33(3):235-42. Exclude: not OVCA. [pmid: 11807980].
135 Gilks CB, Vanderhyden BC, Zhu S, et al. Distinction between serous tumors of low malignant potential and serous carcinomas based on global mRNA expression profiling. Gynecol Oncol. 2005;96(3):684-94. Exclude: no 2×2 table. [pmid: 15721412].
136 Goff BA, Ries JA, Els LP, et al. Immunophenotype of ovarian cancer as predictor of clinical outcome: evaluation at primary surgery and second-look procedure. Gynecol Oncol. 1998;70(3):378-85. Exclude: no 2×2 table. [pmid: 9790791].
137 Goff BA, Shy K, Greer BE, et al. Overexpression and relationships of HER-2/neu, epidermal growth factor receptor, p53, Ki-67, and tumor necrosis factor alpha in epithelial ovarian cancer. Eur J Gynaecol Oncol. 1996;17(6):487-92. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 8971524].
138 Goldstein NS, Bassi D, Uzieblo A. WT1 is an integral component of an antibody panel to distinguish pancreaticobiliary and some ovarian epithelial neoplasms. Am J Clin Pathol. 2001;116(2):246-52. Exclude: no 2×2 table. [pmid: 11488072].
139 Griaznova IM, Borisenko SA, Markarov OV, et al. [Serum ferritin and trophoblastic globulin in genital tumors in women]. [Russian]. Vopr Onkol. 1990;36(2):181-7. Exclude: non-English article. [pmid: 2180208].
140 Groisman GM, Meir A, Sabo E. The value of Cdx2 immunostaining in differentiating primary ovarian carcinomas from colonic carcinomas metastatic to the ovaries. Int J Gynecol Pathol. 2004;23(1):52-7. Exclude: pathology study. [pmid: 14668551].
141 Grosen EA, Granger GA, Gatanaga M, et al. Measurement of the soluble membrane receptors for tumor necrosis factor and lymphotoxin in the sera of patients with gynecologic malignancy. Gynecol Oncol. 1993;50(1):68-77. Exclude: not OVCA. [pmid: 8394276].
142 Halbert CH, Schwartz MD, Wenzel L, et al. Predictors of cognitive appraisals following genetic testing for BRCA1 and BRCA2 mutations. J Behav Med. 2004;27(4):373-92. Exclude: Q5 pre-10-2004. [pmid: 15559734].
143 Halbert CH, Wenzel L, Lerman C, et al. Predictors of participation in psychosocial telephone counseling following genetic testing for BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2004;13(5):875-81. Exclude: no 2×2 table. [pmid: 15159322].
144 Hallowell N. A qualitative study of the information needs of high-risk women undergoing prophylactic oophorectomy. Psychooncology. 2000;9(6):486-95. Exclude: no data on harms. [pmid: 11180583].
145 Hanemaaijer R, Sier CF, Visser H, et al. MMP-9 activity in urine from patients with various tumors, as measured by a novel MMP activity assay using modified urokinase as a substrate. Ann N Y Acad Sci. 1999;878:141-9. Exclude: no 2×2 table. [pmid: 10415726].
146 Hartmann LC, Lu KH, Linette GP, et al. Gene expression profiles predict early relapse in ovarian cancer after platinum-paclitaxel chemotherapy. Clin Cancer Res. 2005;11(6):2149-55. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 15788660].
147 Hata K, Nagami H, Iida K, et al. Expression of thymidine phosphorylase in malignant ovarian tumors: correlation with microvessel density and an ultrasound-derived index of angiogenesis. Ultrasound Obstet Gynecol. 1998;12(3):201-6. Exclude: cell line only. [pmid: 9793193].
148 Hazelton D, Nicosia RF, Nicosia SV. Vascular endothelial growth factor levels in ovarian cyst fluid correlate with malignancy. Clin Cancer Res. 1999;5(4):823-9. Exclude: no 2×2 table. [pmid: 10213218].
149 He QY, Zhou Y, Wong E, et al. Proteomic analysis of a preneoplastic phenotype in ovarian surface epithelial cells derived from prophylactic oophorectomies. Gynecol Oncol. 2005;98(1):68-76. Exclude: cell line only. [pmid: 15913737].
150 Hefler L, Tempfer C, Heinzl H, et al. M3/M21 serum levels in women with adnexal masses and inflammatory diseases. Int J Cancer. 1998;79(4):434-8. Exclude: non-specific general prognosis. [pmid: 9699539].
151 Heinzelmann-Schwarz VA, Gardiner-Garden M, Henshall SM, et al. A distinct molecular profile associated with mucinous epithelial ovarian cancer. Br J Cancer. 2006;94(6):904-13. Exclude: no 2×2 table. [pmid: 16508639].
152 Hendrix ND, Wu R, Kuick R, et al. Fibroblast growth factor 9 has oncogenic activity and is a downstream target of Wnt signaling in ovarian endometrioid adenocarcinomas. Cancer Res. 2006;66(3):1354-62. Exclude: no 2×2 table. [pmid: 16452189].
153 Hengstler JG, Pilch H, Schmidt M, et al. Metallothionein expression in ovarian cancer in relation to histopathological parameters and molecular markers of prognosis. Int J Cancer. 2001;95(2):121-7. Exclude: non-specific general prognosis. [pmid: 11241323].
154 Hickey KP, Boyle KP, Jepps HM, et al. Molecular detection of tumour DNA in serum and peritoneal fluid from ovarian cancer patients. Br J Cancer. 1999;80(11):1803-8. Exclude: no 2×2 table. [pmid: 10468300].
155 Hiorns LR, Bradshaw TD, Skelton LA, et al. Variation in RNA expression and genomic DNA content acquired during cell culture. Br J Cancer. 2004;90(2):476-82. Exclude: cell line only. [pmid: 14735196].
156 Hoffman BR, Katsaros D, Scorilas A, et al. Immunofluorometric quantitation and histochemical localisation of kallikrein 6 protein in ovarian cancer tissue: a new independent unfavourable prognostic biomarker. Br J Cancer. 2002;87(7):763-71. Exclude: no 2×2 table. [pmid: 12232761].
157 Hogdall CK, Norgaard-Pedersen B, Mogensen O. The prognostic value of pre-operative serum tetranectin, CA-125 and a combined index in women with primary ovarian cancer. Anticancer Res. 2002;22(3):1765-8. Exclude: non-specific general prognosis. [pmid: 12168866].
158 Hogdall EV, Hogdall CK, Blaakaer J, et al. P53 autoantibodies in sera from Danish ovarian cancer patients and their correlation with clinical data and prognosis. APMIS. 2002;110(78):545-53. Exclude: no 2×2 table. [pmid: 12390412].
159 Hogdall EV, Hogdall CK, Tingulstad S, et al. Predictive values of serum tumour markers tetranectin, OVX1, CASA and CA125 in patients with a pelvic mass. Int J Cancer. 2000;89(6):519-23. Exclude: non-specific general prognosis. [pmid: 11102897].
160 Horak P, Pils D, Haller G, et al. Contribution of epigenetic silencing of tumor necrosis factor-related apoptosis inducing ligand receptor 1 (DR4) to TRAIL resistance and ovarian cancer. Mol Cancer Res. 2005;3(6):335-43. Exclude: no 2×2 table. [pmid: 15972852].
161 Horak P, Pils D, Kaider A, et al. Perturbation of the tumor necrosis factor—related apoptosis-inducing ligand cascade in ovarian cancer: overexpression of FLIPL and deregulation of the functional receptors DR4 and DR5. Clin Cancer Res. 2005;11(24 Pt 1):8585-91. Exclude: no 2×2 table. [pmid: 16361541].
162 Hornung R, Urs E, Serenella E, et al. Analysis of potential prognostic factors in 111 patients with ovarian cancer. Cancer Lett. 2004;206(1):97-106. Exclude: no 2×2 table. [pmid: 15019165].
163 Hough CD, Cho KR, Zonderman AB, et al. Coordinately up-regulated genes in ovarian cancer. Cancer Res. 2001;61(10):3869-76. Exclude: cell line only. [pmid: 11358798].
164 Howell D, Fitch MI, Deane KA. Impact of ovarian cancer perceived by women. Cancer Nurs. 2003;26(1):1-9. Exclude: no relevant data. [pmid: 12556707].
165 Hu Y, Rosen DG, Zhou Y, et al. Mitochondrial manganese-superoxide dismutase expression in ovarian cancer: role in cell proliferation and response to oxidative stress. J Biol Chem. 2005;280(47):39485-92. Exclude: no 2×2 table. [pmid: 16179351].
166 Huang KC, Rao PH, Lau CC, et al. Relationship of XIST expression and responses of ovarian cancer to chemotherapy. Mol Cancer Ther. 2002;1(10):769-76. Exclude: cell line only. [pmid: 12492109].
167 Huddleston HG, Wong KK, Welch WR, et al. Clinical applications of microarray technology: creatine kinase B is an up-regulated gene in epithelial ovarian cancer and shows promise as a serum marker. Gynecol Oncol. 2005;96(1):77-83. Exclude: no 2×2 table. [pmid: 15589584].
168 Huiart L, Eisinger F, Stoppa-Lyonnet D, et al. Effects of genetic consultation on perception of a family risk of breast/ovarian cancer and determinants of inaccurate perception after the consultation. J Clin Epidemiol. 2002;55(7):665-75. Exclude: BRCA-Q5. [pmid: 12160914].
169 Hurley KE, Miller SM, Costalas JW, et al. Anxiety/uncertainty reduction as a motivation for interest in prophylactic oophorectomy in women with a family history of ovarian cancer. J Womens Health Gend Based Med. 2001;10(2):189-99. Exclude: background Q5. [pmid: 11268302].
170 Ishikawa M, Hayashi H, Saitoh S, et al. [Clinical significance of manganese superoxide dismutase in ovarian carcinoma]. [Japanese]. Nippon Sanka Fujinka Gakkai Zasshi. 1991;43(5):509-15. Exclude: non-English article. [pmid: 2056226].
171 Ishikawa M, Yaginuma Y, Hayashi H, et al. Reactivity of a monoclonal antibody to manganese superoxide dismutase with human ovarian carcinoma. Cancer Res. 1990;50(8):2538-42. Exclude: no 2×2 table. [pmid: 2317833].
172 Ishioka S, Sagae S, Sugimura M, et al. Clinical factors and biomarkers which affect a new universal grading system for ovarian epithelial carcinoma. J Obstet Gynaecol Res. 2001;27(6):313-8. Exclude: grading study. [pmid: 11794816].
173 Ismail RS, Baldwin RL, Fang J, et al. Differential gene expression between normal and tumor-derived ovarian epithelial cells. Cancer Res. 2000;60(23):6744-9. Exclude: cell line only. [pmid: 11118061].
174 Israeli O, Goldring-Aviram A, Rienstein S, et al. In silico chromosomal clustering of genes displaying altered expression patterns in ovarian cancer. Cancer Genet Cytogenet. 2005;160(1):35-42. Exclude: relevant review. [pmid: 15949568].
175 Ivarsson K, Runesson E, Sundfeldt K, et al. The chemotactic cytokine interleukin-8—a cyst fluid marker for malignant epithelial ovarian cancer?. Gynecol Oncol. 1998;71(3):420-3. Exclude: no 2×2 table. [pmid: 9887242].
176 Jazaeri AA, Awtrey CS, Chandramouli GV, et al. Gene expression profiles associated with response to chemotherapy in epithelial ovarian cancers. Clin Cancer Res. 2005;11(17):6300-10. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 16144934].
177 Jazaeri AA, Lu K, Schmandt R, et al. Molecular determinants of tumor differentiation in papillary serous ovarian carcinoma. Mol Carcinog. 2003;36(2):53-9. Exclude: cell line only. [pmid: 12557260].
178 Jazaeri AA, Yee CJ, Sotiriou C, et al. Gene expression profiles of BRCA1-linked, BRCA2-linked, and sporadic ovarian cancers. J Natl Cancer Inst. 2002;94(13):990-1000. Exclude: BRCA-Q5. [pmid: 12096084].
179 Johann DJ Jr, McGuigan MD, Tomov S, et al. Novel approaches to visualization and data mining reveals diagnostic information in the low amplitude region of serum mass spectra from ovarian cancer patients. Dis Markers. 2003-2004;19(45):197-207. Exclude: Mass Spectro. [pmid: 15258334].
180 Jones MB, Krutzsch H, Shu H, et al. Proteomic analysis and identification of new biomarkers and therapeutic targets for invasive ovarian cancer. Proteomics. 2002;2(1):76-84. Exclude: stain study. [pmid: 11788994].
181 Jones MB, Michener CM, Blanchette JO, et al. The granulin-epithelin precursor/PC-cell-derived growth factor is a growth factor for epithelial ovarian cancer. Clin Cancer Res. 2003;9(1):44-51. Exclude: cell line only. [pmid: 12538450].
182 Kalir T, Wang BY, Goldfischer M, et al. Immunohistochemical staining of GLUT1 in benign, borderline, and malignant ovarian epithelia. Cancer. 2002;94(4):1078-82. Exclude: stain study. [pmid: 11920478].
183 Karppinen SM, Vuosku J, Heikkinen K, et al. No evidence of involvement of germline BACH1 mutations in Finnish breast and ovarian cancer families. Eur J Cancer. 2003;39(3):366-71. Exclude: not OVCA. [pmid: 12565990].
184 Katnik I, Jadach J, Kmieciak K, et al. Measurements of haptoglobin by the reaction with concanavalin A in sera of patients with ovarian tumours. Eur J Clin Chem Clin Biochem. 1995;33(10):727-32. Exclude: no 2×2 table. [pmid: 8608195].
185 Kauff ND, Hurley KE, Hensley ML, et al. Ovarian carcinoma screening in women at intermediate risk: impact on quality of life and need for invasive follow-up. Cancer. 2005;104(2):314-20. Exclude: no relevant data. [pmid: 15948173].
186 Keenan LA, Lesniak KT, Guarnaccia CA, et al. Family environments of women seeking BRCA1/BRCA2 genetic mutation testing: an exploratory analysis. J Genet Couns. 2004;13(2):157-76. Exclude: Q5 pre-10-2004. [pmid: 15604630].
187 Kenen R, Arden-Jones A, Eeles R. We are talking, but are they listening? Communication patterns in families with a history of breast/ovarian cancer (HBOC). Psychooncology. 2004;13(5):335-45. Exclude: non-specific general prognosis. [pmid: 15133774].
188 Khalifa MA, Abdoh AA, Mannel RS, et al. P-glycoprotein as a prognostic indicator in pre- and postchemotherapy ovarian adenocarcinoma. Int J Gynecol Pathol. 1997;16(1):69-75. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 8986535].
189 Kim H, Scorilas A, Katsaros D, et al. Human kallikrein gene 5 (KLK5) expression is an indicator of poor prognosis in ovarian cancer. Br J Cancer. 2001;84(5):643-50. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 11237385].
190 Kim JH, Skates SJ, Uede T, et al. Osteopontin as a potential diagnostic biomarker for ovarian cancer. JAMA. 2002;287(13):1671-9. Exclude: cell line only. [pmid: 11926891].
191 Kim JS, Baek SJ, Sali T, et al. The conventional nonsteroidal anti-inflammatory drug sulindac sulfide arrests ovarian cancer cell growth via the expression of NAG-1/MIC-1/GDF-15. Mol Cancer Ther. 2005;4(3):487-93. Exclude: Drug mech ab action. [pmid: 15767558].
192 Kohler M, Janz I, Wintzer HO, et al. The expression of EGF receptors, EGF-like factors and c-myc in ovarian and cervical carcinomas and their potential clinical significance. Anticancer Res. 1989;9(6):1537-47. Exclude: no 2×2 table. [pmid: 2697181].
193 Kohn EC, Reed E, Sarosy GA, et al. A phase I trial of carboxyamido-triazole and paclitaxel for relapsed solid tumors: potential efficacy of the combination and demonstration of pharmacokinetic interaction. Clin Cancer Res. 2001;7(6):1600-9. Exclude: cell line only. [pmid: 11410496].
194 Kohn EC, Sandeen MA, Liotta LA. In vivo efficacy of a novel inhibitor of selected signal transduction pathways including calcium, arachidonate, and inositol phosphates. Cancer Res. 1992;52(11):3208-12. Exclude: cell line only. [pmid: 1591730].
195 Kong F, Nicole White C, Xiao X, et al. Using proteomic approaches to identify new biomarkers for detection and monitoring of ovarian cancer. Gynecol Oncol. 2006;100(2):247-53. Exclude: no 2×2 table. [pmid: 16229881].
196 Koper NP, Thomas CM, Massuger LF, et al. Comparison of four ‘second generation’ immunoassay systems to determine CA 125 in serum by using a graphical approach to method comparison analysis. Eur J Clin Chem Clin Biochem. 1997;35(8):617-23. Exclude: background Q1. [pmid: 9298352].
197 Kozlowski P, Krzyzosiak WJ. Combined SSCP/duplex analysis by capillary electrophoresis for more efficient mutation detection. Nucleic Acids Res. 2001. 29(14):E71. Exclude: background Q1.
198 Krajewska M, Kim H, Shin E, et al. Tumor-associated alterations in caspase-14 expression in epithelial malignancies. Clin Cancer Res. 2005;11(15):5462-71. Exclude: no 2×2 table. [pmid: 16061862].
199 Kringen P, Bergamaschi A, Due EU, et al. Evaluation of arrayed primer extension for TP53 mutation detection in breast and ovarian carcinomas. Biotechniques. 2005;39(5):755-61. Exclude: no 2×2 table. [pmid: 16312222].
200 Krishna CM, Sockalingum GD, Venteo L, et al. Evaluation of the suitability of ex vivo handled ovarian tissues for optical diagnosis by Raman microspectroscopy. Biopolymers. 2005;79(5):269-76. Exclude: not genomic test. [pmid: 16078191].
201 Kristiansen G, Denkert C, Schluns K, et al. CD24 is expressed in ovarian cancer and is a new independent prognostic marker of patient survival. Am J Pathol. 2002;161(4):1215-21. Exclude: cell line only. [pmid: 12368195]. [pmcid: 1867310].
202 Kumar A, Soprano DR, Parekh HK. Cross-resistance to the synthetic retinoid CD437 in a paclitaxel-resistant human ovarian carcinoma cell line is independent of the overexpression of retinoic acid receptor-gamma. Cancer Res. 2001;61(20):7552-5. Exclude: cell line only. [pmid: 11606393].
203 Kumar P, Rehani MM, Kumar L, et al. Tumor marker CA-125 as an evaluator and response indicator in ovarian cancer: its quantitative correlation with tumor volume. Med Sci Monit. 2005;11(2):CR84-9. Exclude: no 2×2 table. [pmid: 15668638].
204 Lahti-Domenici J, Rapakko K, Paakkonen K, et al. Exclusion of large deletions and other rearrangements in BRCA1 and BRCA2 in Finnish breast and ovarian cancer families. Cancer Genet Cytogenet. 2001;129(2):120-3. Exclude: no 2×2 table. [pmid: 11566341].
205 Lambros MB, Fiegler H, Jones A, et al. Analysis of ovarian cancer cell lines using array-based comparative genomic hybridization. J Pathol. 2005;205(1):29-40. Exclude: cell line only. [pmid: 15586366].
206 Lancaster JM, Dressman HK, Whitaker RS, et al. Gene expression patterns that characterize advanced stage serous ovarian cancers. J Soc Gynecol Invest. 2004;11(1):51-9. Exclude: no 2×2 table.
207 Lapchenkov VI, Dudarev AL, Vinokurov VL, et al. [Comparative evaluation of diagnostic significance of carbohydrate antigen CA125 and cancer-embryonal antigen in ovarian cancer]. [Russian]. Vestn Rentgenol Radiol 1993;(5):30–1. Exclude: non-English article.
208 Lassus H, Sihto H, Leminen A, et al. Genetic alterations and protein expression of KIT and PDGFRA in serous ovarian carcinoma. Br J Cancer. 2004;91(12):2048-55. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 15583695].
209 Le Page C, Ouellet V, Madore J, et al. From gene profiling to diagnostic markers: IL-18 and FGF-2 complement CA125 as serum-based markers in epithelial ovarian cancer. Int J Cancer. 2006;118(7):1750-8. Exclude: no 2×2 table. [pmid: 16217764].
210 Lee BC, Cha K, Avraham S, et al. Microarray analysis of differentially expressed genes associated with human ovarian cancer. Int J Oncol. 2004;24(4):847-51. Exclude: denominator NOT patients. [pmid: 15010821].
211 Lee G, Ng HT. Clinical evaluations of a new ovarian cancer marker, COX-1. Int J Gynaecol Obstet. 1995;49(Suppl):S27-32. Exclude: no 2×2 table. [pmid: 7589737].
212 Lee SH, Zhang W, Choi JJ, et al. Overexpression of the thymosin beta-10 gene in human ovarian cancer cells disrupts F-actin stress fiber and leads to apoptosis [erratum appears in Oncogene 2002 Aug 22;31(27):5822 Note: Lee SH [corrected to Oh SH]]. Oncogene. 2001;20(46):6700-6. Exclude: cell line only. [pmid: 11709704].
213 Lee TV, Anderson BW, Peoples GE, et al. Identification of activated tumor antigen-reactive CD8+ cells in healthy individuals. Oncol Rep. 2000;7(3):455-66. Exclude: no 2×2 table. [pmid: 10767352].
214 Leeson S, Iredale R, Stansfield K, et al. Developing a cancer genetics service in Wales: opinions of gynaecologists on the management of women at risk of familial ovarian cancer. Eur J Cancer Care (Engl). 2001;10(3):172-8. Exclude: relevant review. [pmid: 11829379].
215 Lerman C, Biesecker B, Benkendorf JL, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. J Natl Cancer Inst. 1997;89(2):148-57. Exclude: background Q5 & Q6. [pmid: 8998184].
216 Levner I, et al. Feature selection and nearest centroid classification for protein mass spectrometry. BMC Bioinformatics. 2005;6(1):68. Exclude: no 2×2 table. [pmid: 15788095]. [pmcid: 1274262].
217 Li L, Umbach DM, Terry P, et al. Application of the GA/KNN method to SELDI proteomics data. Bioinformatics. 2004;20(10):1638-40. Exclude: no 2×2 table. [pmid: 14962943].
218 Lieberman G, Buscombe JR, Hilson AJ, et al. Preoperative diagnosis of ovarian carcinoma with a novel monoclonal antibody. Am J Obstet Gynecol. 2000;183(3):534-40. Exclude: not OVCA. [pmid: 10992170].
219 Liede A, Metcalfe K, Hanna D, et al. Evaluation of the needs of male carriers of mutations in BRCA1 or BRCA2 who have undergone genetic counseling. Am J Hum Genet. 2000;67(6):1494-504. Exclude: Q5 pre-10-2004. [pmid: 11063672]. [pmcid: 1287926].
220 Lilien RH, Farid H, Donald BR. Probabilistic disease classification of expression-dependent proteomic data from mass spectrometry of human serum. J Comput Biol. 2003;10(6):925-46. Exclude: mathematical model. [pmid: 14980018].
221 Lodder L, Frets PG, Trijsburg RW, et al. Men at risk of being a mutation carrier for hereditary breast/ovarian cancer: an exploration of attitudes and psychological functioning during genetic testing. Eur J Hum Genet. 2001;9(7):492-500. Exclude: Q5 pre-10-2004. [pmid: 11464240].
222 Lodder L, Frets PG, Trijsburg RW, et al. Psychological impact of receiving a BRCA1/BRCA2 test result. Am J Med Genet. 2001;98(1):15-24. Exclude: BRCA-Q5. [pmid: 11426450].
223 Lu KH, Patterson AP, Wang L, et al. Selection of potential markers for epithelial ovarian cancer with gene expression arrays and recursive descent partition analysis. Clin Cancer Res. 2004;10(10):3291-300. Exclude: cell line only. [pmid: 15161682].
224 Lukacsko I, Hernadi Z, Sapy T, et al. The prognostic value of CA-125 in epithelial ovarian cancer patients during and after chemotherapy. Acta Chir Hung. 1997;36(14):213-4. Exclude: no 2×2 table. [pmid: 9408350].
225 Lynch EL, Doherty RJ, Gaff CL, et al. “Cancer in the family” and genetic testing: implications for life insurance. Med J Aust. 2003;179(9):480-3. Exclude: Background only. [pmid: 14583079].
226 Lynch HT, Albano WA, Lynch JF, et al. Surveillance and management of patients at high genetic risk for ovarian carcinoma. Obstet Gynecol. 1982;59(5):589-96. Exclude: no 2×2 table. [pmid: 7070730].
227 Lynch HT, Lemon SJ, Durham C, et al. A descriptive study of BRCA1 testing and reactions to disclosure of test results. Cancer. 1997;79(11):2219-28. Exclude: background Q5. [pmid: 9179070].
228 Lynch HT, Snyder CL, Lynch JF, et al. Hereditary breast-ovarian cancer at the bedside: role of the medical oncologist. J Clin Oncol. 2003;21(4):740-53. Exclude: BRCA-Q5. [pmid: 12586815].
229 Macwhinnie N, Monaghan H. The use of P53, PTEN, and C-erbB-2 to differentiate uterine serous papillary carcinoma from endometrioid endometrial carcinoma. Int J Gynecol Cancer. 2004;14(5):938-46. Exclude: stain study. [pmid: 15361207].
230 Magklara A, Scorilas A, Katsaros D, et al. The human KLK8 (neuropsin/ovasin) gene: identification of two novel splice variants and its prognostic value in ovarian cancer. Clin Cancer Res. 2001;7(4):806-11. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 11309326].
231 Manderson EN, Mes-Masson AM, Novak J, et al. Expression profiles of 290 ESTs mapped to chromosome 3 in human epithelial ovarian cancer cell lines using DNA expression oligonucleotide microarrays. Genome Res. 2002;12(1):112-21. Exclude: cell line only. [pmid: 11779836]. [pmcid: 155251].
232 Marinov B, Tsachev K, Doganov N, et al. [The copper concentration in the blood serum of women with ovarian tumors (a preliminary report)]. [Bulgarian]. Akush Ginekol (Sofiia). 2000;39(2):36-7. Exclude: non-English article. [pmid: 10948620].
233 Marinov B, Tsachev K, Doganov N, et al. [The zinc concentration of the blood serum in women with ovarian tumors (preliminary report)]. [Bulgarian]. Akush Ginekol (Sofiia). 1998;37(4):16-8. Exclude: non-English article. [pmid: 10360044].
234 Markman M, Liu PY, Rothenberg ML, et al. Pretreatment CA-125 and risk of relapse in advanced ovarian cancer. J Clin Oncol. 2006;24(9):1454-8. Exclude: no 2×2 table. [pmid: 16549840].
235 Marquez RT, Baggerly KA, Patterson AP, et al. Patterns of gene expression in different histotypes of epithelial ovarian cancer correlate with those in normal fallopian tube, endometrium, and colon. Clin Cancer Res. 2005;11(17):6116-26. Exclude: no 2×2 table. [pmid: 16144910].
236 Martel P, Marty MH, Bonnet F, et al. [Value of imaging in the management of advanced stage ovarian cancer “experience of 72 computed tomographic examinations”]. [French]. Contracept Fertil Sex. 1997;25(11):865-71. Exclude: non-English article. [pmid: 9471291].
237 Martin MJ, Blockx PP. Comparison of one first-generation and three second-generation methods for the determination of CA 125. Int J Biol Markers. 1996;11(1):36-9. Exclude: no OVCA-specific data. [pmid: 8740640].
238 Martoglio AM, Miskin JW, Smith SK, et al. A decomposition model to track gene expression signatures: preview on observer-independent classification of ovarian cancer. Bioinformatics. 2002;18(12):1617-24. Exclude: mathematical model. [pmid: 12490446].
239 Martoglio AM, Tom BD, Starkey M, et al. Changes in tumorigenesis- and angiogenesis-related gene transcript abundance profiles in ovarian cancer detected by tailored high density cDNA arrays. Mol Med. 2000;6(9):750-65. Exclude: mathematical model. [pmid: 11071270]. [pmcid: 1949983].
240 Masciullo V, Scambia G, Marone M, et al. Altered expression of cyclin D1 and CDK4 genes in ovarian carcinomas. Int J Cancer. 1997;74(4):390-5. Exclude: denominator NOT patients. [pmid: 9291427].
241 Matei D, Chang DD, Jeng MH. Imatinib mesylate (Gleevec) inhibits ovarian cancer cell growth through a mechanism dependent on platelet-derived growth factor receptor alpha and Akt inactivation. Clin Cancer Res. 2004;10(2):681-90. Exclude: cell line only. [pmid: 14760091].
242 Matei D, Graeber TG, Baldwin RL, et al. Gene expression in epithelial ovarian carcinoma. Oncogene. 2002;21(41):6289-98. Exclude: cell line only. [pmid: 12214269].
243 Matsuzaki H, Kobayashi H, Yagyu T, et al. Plasma bikunin as a favorable prognostic factor in ovarian cancer. J Clin Oncol. 2005;23(7):1463-72. Exclude: no 2×2 table. [pmid: 15735122].
244 Mayerhofer K, Bodner K, Aktas C, et al. Knowledge of tumor markers and the psychological consequences of tumor marker sampling in patients with gynecologic cancers. Anticancer Res. 2000;20(2B):1281-4. Exclude: Q5 pre-10-2004. [pmid: 10810435].
245 McCluggage WG, Maxwell P, Veenstra H, et al. Monoclonal antibody SM047 as an immunohistochemical marker of ovarian adenocarcinoma. Histopathology. 2001;38(6):542-9. Exclude: stain study. [pmid: 11422498].
246 Medeiros R, Pereira D, Afonso N, et al. Platinum/paclitaxel-based chemotherapy in advanced ovarian carcinoma: glutathione S-transferase genetic polymorphisms as predictive biomarkers of disease outcome. Int J Clin Oncol. 2003;8(3):156-61. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 12851839].
247 Mehnert A, Bergelt C, Koch U. Knowledge and attitudes of gynecologists regarding genetic counseling for hereditary breast and ovarian cancer. Patient Educ Couns. 2003;49(2):183-8. Exclude: Background only. [pmid: 12566214].
248 Meisel M, Straube W, Weise J, et al. A study of serum CASA and CA 125 levels in patients with ovarian carcinoma. Arch Gynecol Obstet. 1995;256(1):9-15. Exclude: no 2×2 table. [pmid: 7726659].
249 Menzel C, Dobert N, Hamscho N, et al. The influence of CA 125 and CEA levels on the results of (18)F-deoxyglucose positron emission tomography in suspected recurrence of epithelial ovarian cancer. Strahlenther Onkol. 2004;180(8):497-501. Exclude: no 2×2 table. [pmid: 15292970].
250 Miliaras D. Volume-corrected mitotic index and p53 immunoreactivity in borderline and malignant epithelial ovarian tumors. Anal Quant Cytol Histol. 1999;21(5):425-9. Exclude: no 2×2 table. [pmid: 10560525].
251 Mogensen O, Mogensen B. IMx CA 125, an automated microparticle enzyme immunoassay: technical characteristics and clinical usefulness after recalibration. Scand J Clin Lab Invest. 1995;55(4):289-94. Exclude: background Q1. [pmid: 7569730].
252 Molina R, Agusti C, Filella X, et al. Study of a new tumor marker, CYFRA 21-1, in malignant and nonmalignant diseases. Tumour Biol. 1994;15(6):318-25. Exclude: no 2×2 table. [pmid: 7997803].
253 Mouchawar J, Valentine Goins K, Somkin C, et al. Guidelines for breast and ovarian cancer genetic counseling referral: adoption and implementation in HMOs. Genet Med. 2003;5(6):444-50. Exclude: background Q5. [pmid: 14614396].
254 Multhaupt HA, Arenas-Elliott CP, Warhol MJ. Comparison of glycoprotein expression between ovarian and colon adenocarcinomas. Arch Pathol Lab Med. 1999;123(10):909-16. Exclude: no 2×2 table. [pmid: 10506443].
255 Muramatsu T, Mukai M, Sato S, et al. Clinical usefulness of serum and immunohistochemical markers in patients with stage Ia and Ic ovarian cancer. Oncol Rep. 2005;14(4):861-5. Exclude: N=28. [pmid: 16142343].
256 Murta EF, da Silva CS, Gomes RA, et al. Ultrasonographic criteria and tumor marker assay are good procedures for the diagnosis of ovarian neoplasia in preselected outpatients. Eur J Gynaecol Oncol. 2004;25(6):707-12. Exclude: no OVCA-specific data. [pmid: 15597847].
257 Neungton N, Moongkarndi P, Neungton S, et al. Establishment of OVS1 and OVS2 monoclonal antibodies recognizing human ovarian mucinous cystadenocarcinoma. Asian Pac J Allergy Immunol. 1995;13(1):47-53. Exclude: no patient-level data. [pmid: 7488344].
258 Nguyen DV, Rocke DM. Tumor classification by partial least squares using microarray gene expression data. Bioinformatics. 2002;18(1):39-50. Exclude: no 2×2 table. [pmid: 11836210].
259 Nicholson S, Fox M, Epenetos A, et al. Immunoglobulin Inhibiting Reagent: evaluation of a new method for eliminating spurious elevations in CA125 caused by HAMA. Int J Biol Markers. 1996;11(1):46-9. Exclude: unrelated. [pmid: 8740642].
260 Nielsen JS, Jakobsen E, Holund B, et al. Prognostic significance of p53, Her-2, and EGFR overexpression in borderline and epithelial ovarian cancer. Int J Gynecol Cancer. 2004;14(6):1086-96. Exclude: non-specific general prognosis. [pmid: 15571614].
261 Nippert I, Schlegelberger B. Consortium ‘Hereditary Breast and Ovarian Cancer of The Deutsche Krebshilfe’. Women's experiences of undergoing BRCA1 and BRCA2 testing: organisation of the German Hereditary Breast and Ovarian Cancer Consortium Survey and Preliminary Data from Munster. Community Genet. 2003;6(4):249-58. Exclude: Q5 pre-10-2004. [pmid: 15331871].
262 Nishimura R, Kobayashi K, Katsuno M, et al. [Development of highly sensitive enzyme immunoassay to measure urinary beta-core fragment in patients with gynecological cancer]. [Japanese]. Nippon Sanka Fujinka Gakkai Zasshi. 1990;42(2):143-8. Exclude: non-English article. [pmid: 1690253].
263 Nishizuka S, Chen ST, Gwadry FG, et al. Diagnostic markers that distinguish colon and ovarian adenocarcinomas: identification by genomic, proteomic, and tissue array profiling. Cancer Res. 2003;63(17):5243-50. Exclude: no 2×2 table. [pmid: 14500354].
264 Nolan LP, Heatley MK. The value of immunocytochemistry in distinguishing between clear cell carcinoma of the kidney and ovary. Int J Gynecol Pathol. 2001;20(2):155-9. Exclude: pathology study. [pmid: 11293161].
265 Novakovic S, Fras PA, Jezersek-Novakovic B. Telomerase activity as a biological marker in some gynecological tumors: comparison with tissue and serum CA 125. In Vivo. 2001;15(4):327-32. Exclude: N=7. [pmid: 11695225].
266 Nowak-Markwitz E, Jankowska A, Andrusiewicz M, et al. Expression of beta-human chorionic gonadotropin in ovarian cancer tissue. Eur J Gynaecol Oncol. 2004;25(4):465-9. Exclude: no 2×2 table. [pmid: 15285305].
267 Nozawa S, Yajima M, Udagawa Y, et al. [The evaluation of CA54/61 in the diagnosis of ovarian cancer—with special reference to the cooperative results of 5 institutes]. [Japanese]. Nippon Sanka Fujinka Gakkai Zasshi. 1989;41(11):1823-9. Exclude: non-English article. [pmid: 2687409].
268 Nunez MI, Rosen DG, Ludes-Meyers JH, et al. WWOX protein expression varies among ovarian carcinoma histotypes and correlates with less favorable outcome. BMC Cancer. 2005;5(1):64. Exclude: no 2×2 table. [pmid: 15982416]. [pmcid: 1173095].
269 Nyvang GB, Mogensen O, Bichel P, et al. Combined prognostic importance of CA 125, histopathologic grade and DNA-index in advanced ovarian cancer. Eur J Gynaecol Oncol. 2000;21(6):569-72. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 11214611].
270 Oehler MK, Caffier H. Prognostic relevance of serum vascular endothelial growth factor in ovarian cancer. Anticancer Res. 2000;20(6D):5109-12. Exclude: non-specific general prognosis. [pmid: 11326678].
271 Oehler MK, Sutterlin M, Caffier H. CASA and Ca 125 in diagnosis and follow-up of advanced ovarian cancer. Anticancer Res. 1999;19(4A):2513-8. Exclude: no 2×2 table. [pmid: 10470185].
272 Okamoto A, Nikaido T, Ochiai K, et al. Indoleamine 2,3-dioxygenase serves as a marker of poor prognosis in gene expression profiles of serous ovarian cancer cells. Clin Cancer Res. 2005;11(16):6030-9. Exclude: no 2×2 table. [pmid: 16115948].
273 Okamoto S, Ito K, Sasano H, et al. Ber-EP4 and anti-calretinin antibodies: a useful combination for differential diagnosis of various histological types of ovarian cancer cells and mesothelial cells. Tohoku J Exp Med. 2005;206(1):31-40. Exclude: cell line only. [pmid: 15802873].
274 Oktem M, Dilek TU, Guner H, et al. The effect of recombinant GM-CSF on IL-6 and TNF-alpha levels in epithelial ovarian cancer patients who received paclitaxel and cisplatinum: preliminary results. Eur J Gynaecol Oncol. 2004;25(4):478-80. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 15285308].
275 Onsrud M, Shabana A, Austgulen R, et al. Comparison between soluble tumor necrosis factor receptors and CA125 in peritoneal fluids as a marker for epithelial ovarian cancer. Gynecol Oncol. 1995;57(2):183-7. Exclude: publication duplicate. [pmid: 7729731].
276 Ouellet V, Provencher DM, Maugard CM, et al. Discrimination between serous low malignant potential and invasive epithelial ovarian tumors using molecular profiling. Oncogene. 2005;24(29):4672-87. Exclude: no 2×2 table. [pmid: 15940270].
277 Owens OJ, Taggart C, Wilson R, et al. Interleukin-2 receptor and ovarian cancer. Br J Cancer. 1993;68(2):364-7. Exclude: no 2×2 table. [pmid: 8347492].
278 Padungsutt P, Thirapagawong C, Senapad S, et al. Accuracy of tissue polypeptide specific antigen (TPS) in the diagnosis of ovarian malignancy. Anticancer Res. 2000;20(2B):1291-5. Exclude: non-specific general prognosis. [pmid: 10810437].
279 Paolicchi A, Pompella A, Tonarelli P, et al. Gamma-glutamyltranspeptidase activity in human ovarian carcinoma. Anticancer Res. 1996;16(5B):3053-8. Exclude: no 2×2 table. [pmid: 8920766].
280 Paramasivam S, Tripcony L, Crandon A, et al. Prognostic importance of preoperative CA-125 in International Federation of Gynecology and Obstetrics stage I epithelial ovarian cancer: an Australian multicenter study. J Clin Oncol. 2005;23(25):5938-42. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 16087942].
281 Park IS, Lee YS, Kim JC, et al. Serum neopterin levels in ovarian tumors. Int J Gynaecol Obstet. 1995;51(3):229-34. Exclude: non-specific general prognosis. [pmid: 8745088].
282 Park J, Park K, Kim S, et al. Msx1 gene overexpression induces G1 phase cell arrest in human ovarian cancer cell line OVCAR3. Biochem Biophys Res Commun. 2001;281(5):1234-40. Exclude: cell line only. [pmid: 11243867].
283 Pasacreta JV. Psychosocial issues associated with genetic testing for breast and ovarian cancer risk: an integrative review. Cancer Invest. 2003;21(4):588-623. Exclude: relevant review. [pmid: 14533449].
284 Pegoraro RJ, Moodley M, Rom L, et al. P53 codon 72 polymorphism and BRCA 1 and 2 mutations in ovarian epithelial malignancies in black South Africans. Int J Gynecol Cancer. 2003;13(4):444-9. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 12911720].
285 Pepe MS, Longton G, Anderson GL, et al. Selecting differentially expressed genes from microarray experiments. Biometrics. 2003;59(1):133-42. Exclude: relevant review. [pmid: 12762450].
286 Peterson LA, Brown MR, Carlisle AJ, et al. An improved method for construction of directionally cloned cDNA libraries from microdissected cells. Cancer Res. 1998;58(23):5326-8. Exclude: no 2×2 table. [pmid: 9850058].
287 Petignat P, Joris F, Obrist R. How CA 125 is used in routine clinical practice. Eur J Cancer. 2000;36(15):1933-7. Exclude: no 2×2 table. [pmid: 11000573].
288 Piccioni MG, Fabiani C, Fattouche V, et al. Preoperative evaluation of ovarian masses: ultrasound and biochemical screening. Clin Exp Obstet Gynecol. 2003;30(4):217-9. Exclude: no 2×2 table. [pmid: 14664416].
289 Pinto D, Pereira D, Portela C, et al. The influence of HER2 genotypes as molecular markers in ovarian cancer outcome. Biochem Biophys Res Commun. 2005;335(4):1173-8. Exclude: no 2×2 table. [pmid: 16112085].
290 Pinto MM. CA-15.3 assay in effusions: comparison with carcinoembryonic antigen and CA-125 assay and cytologic diagnosis. Acta Cytol. 1996;40(3):437-42. Exclude: no 2×2 table. [pmid: 8669175].
291 Piver MS, Mettlin CJ, Tsukada Y, et al. Familial Ovarian Cancer Registry. Obstet Gynecol. 1984;64(2):195-9. Exclude: Background only. [pmid: 6738953].
292 Presneau N, Mes-Masson AM, Ge B, et al. Patterns of expression of chromosome 17 genes in primary cultures of normal ovarian surface epithelia and epithelial ovarian cancer cell lines. Oncogene. 2003;22(10):1568-79. Exclude: cell line only. [pmid: 12629520].
293 Protopapas A, Diakomanolis E, Bamias A, et al. The prognostic significance of the immunohistochemical expression of p53, bcl-2, c-erb B-2 and cathepsin-D in ovarian cancer patients receiving platinum with cyclophosphamide or paclitaxel chemotherapy. Eur J Gynaecol Oncol. 2004;25(2):225-9. Exclude: non-specific general prognosis. [pmid: 15032288].
294 Rakowicz-Szulczynska EM. Relevance of the viral RAK alpha gene in diagnosis of malignant versus nonmalignant tumors of the ovary and uterus. Clin Diagn Lab Immunol. 2000;7(3):360-5. Exclude: non-specific general prognosis. [pmid: 10799446]. [pmcid: 95879].
295 Rangel LB, Sherman-Baust CA, Wernyj RP, et al. Characterization of novel human ovarian cancer-specific transcripts (HOSTs) identified by serial analysis of gene expression. Oncogene. 2003;22(46):7225-32. Exclude: no 2×2 table. [pmid: 14562052].
296 Raspollini MR, Amunni G, Villanucci A, et al. COX-2 and preoperative CA-125 level are strongly correlated with survival and clinical responsiveness to chemotherapy in ovarian cancer. Acta Obstet Gynecol Scand. 2006;85(4):493-8. Exclude: no 2×2 table. [pmid: 16612714].
297 Raspollini MR, Amunni G, Villanucci A, et al. Prognostic value of P-glycoprotein and proliferative index in advanced low grade serous ovarian carcinomas. J Chemother. 2003;15(4):380-6. Exclude: non-specific general prognosis. [pmid: 12962367].
298 Raspollini MR, Amunni G, Villanucci A, et al. Utility of CDX-2 in distinguishing between primary and secondary (intestinal) mucinous ovarian carcinoma: an immunohistochemical comparison of 43 cases. Appl Immunohistochem Mol Morphol. 2004;12(2):127-31. Exclude: no 2×2 table. [pmid: 15354737].
299 Rathi A, Virmani AK, Schorge JO, et al. Methylation profiles of sporadic ovarian tumors and nonmalignant ovaries from high-risk women. Clin Cancer Res. 2002;8(11):3324-31. Exclude: no 2×2 table. [pmid: 12429618].
300 Reimer T, Gerber B, Kunkel S, et al. Estradiol, gonadotropins, and tumor markers in ovarian cyst fluid. Acta Obstet Gynecol Scand. 1997;76(5):478-83. Exclude: no OVCA-specific data. [pmid: 9197453].
301 Reimer T, Gerber B, Muller H, et al. Differential diagnosis of peri- and postmenopausal ovarian cysts. Maturitas. 1999;31(2):123-32. Exclude: no 2×2 table. [pmid: 10227005].
302 Reinsberg J, Schmolling J, Ackermann D. A simple and sensitive assay for determination of human anti-idiotypic anti-B72.3 antibodies, which is not affected by the presence of tumour-associated glycoprotein 72. Eur J Clin Chem Clin Biochem. 1996;34(3):237-44. Exclude: no relevant data. [pmid: 8721411].
303 Ricci R, Komminoth P, Bannwart F, et al. PTEN as a molecular marker to distinguish metastatic from primary synchronous endometrioid carcinomas of the ovary and uterus. Diagn Mol Pathol. 2003;12(2):71-8. Exclude: no 2×2 table. [pmid: 12766611].
304 Riener EK, Arnold N, Kommoss F, et al. The prognostic and predictive value of immunohistochemically detected HER-2/neu overexpression in 361 patients with ovarian cancer: a multicenter study [retraction in Gynecol Oncol. 2005 Mar;96(3):1021; PMID: 15810154]. Gynecol Oncol. 2004;95(1):89-94. Exclude: paper retracted. [pmid: 15385115].
305 Ritvo P, Irvine J, Robinson G, et al. Psychological adjustment to familial-genetic risk assessment for ovarian cancer: predictors of nonadherence to surveillance recommendations. Gynecol Oncol. 2002;84(1):72-80. Exclude: Q5 pre-10-2004. [pmid: 11748980].
306 Ritvo P, Robinson G, Irvine J, et al. Psychological adjustment to familial genetic risk assessment: differences in two longitudinal samples. Patient Educ Couns. 2000;40(2):163-72. Exclude: Q5 pre-10-2004. [pmid: 10771370].
307 Roberts D, Schick J, Conway S, et al. Identification of genes associated with platinum drug sensitivity and resistance in human ovarian cancer cells. Br J Cancer. 2005;92(6):1149-58. Exclude: cell line only. [pmid: 15726096].
308 Robertson DM, Cahir N, Burger HG, et al. Combined inhibin and CA125 assays in the detection of ovarian cancer. Clin Chem. 1999;45(5):651-8. Exclude: no 2×2 table. [pmid: 10222351].
309 Robertson DM, Stephenson T, Pruysers E, et al. Characterization of inhibin forms and their measurement by an inhibin alpha-subunit ELISA in serum from postmenopausal women with ovarian cancer. J Clin Endocrinol Metab. 2002;87(2):816-24. Exclude: no OVCA-specific data. [pmid: 11836327].
310 Rohlke P, Milde-Langosch K, Weyland C, et al. p53 is a persistent and predictive marker in advanced ovarian carcinomas: multivariate analysis including comparison with Ki67 immunoreactivity. J Cancer Res Clin Oncol. 1997;123(9):496-501. Exclude: non-specific general prognosis. [pmid: 9341899].
311 Rojo JV, Merino AM, Gonzalez LO, et al. Expression and clinical significance of pepsinogen C in epithelial ovarian carcinomas. Eur J Obstet Gynecol Reprod Biol. 2002;104(1):58-63. Exclude: non-specific general prognosis. [pmid: 12128264].
312 Roman LD, Muderspach LI, Burnett AF, et al. Carcinoembryonic antigen in women with isolated pelvic masses. Clinical utility?. J Reprod Med. 1998;43(5):403-7. Exclude: non-specific general prognosis. [pmid: 9610461].
313 Rossi AC, Di Vagno G, Cormio G, et al. A retrospective study of preoperative CA 125 levels in 82 patients with ovarian cancer. Arch Gynecol Obstet. 2004;269(4):263-5. Exclude: no 2×2 table. [pmid: 14745561].
314 Roupa Z, Faros E, Raftopoulos V, et al. Serum CA 125 combined with transvaginal ultrasonography for ovarian cancer screening. In Vivo. 2004;18(6):831-6. Exclude: CA125 for diagnosis. [pmid: 15646829].
315 Runnebaum IB, Bruning A. Glucocorticoids inhibit cell death in ovarian cancer and up-regulate caspase inhibitor cIAP2. Clin Cancer Res. 2005;11(17):6325-32. Exclude: no relevant data. [pmid: 16144937].
316 Rustin GJ, Nelstrop AE, Bentzen SM, et al. Selection of active drugs for ovarian cancer based on CA-125 and standard response rates in phase II trials. J Clin Oncol. 2000;18(8):1733-9. Exclude: no 2×2 table. [pmid: 10764434].
317 Rzymski P, Opala T, Wilczak M, et al. Serum tumor necrosis factor alpha receptors p55/p75 ratio and ovarian cancer detection. Int J Gynaecol Obstet. 2005;88(3):292-8. Exclude: no 2×2 table. [pmid: 15733884].
318 Sachs L, Taube A, Tishelman C. Risk in numbers—difficulties in the transformation of genetic knowledge from research to people—the case of hereditary cancer. Acta Oncol. 2001;40(4):445-53. Exclude: relevant review. [pmid: 11504302].
319 Sagarra RA, Andrade LA, Martinez EZ, et al. P53 and Bcl-2 as prognostic predictors in epithelial ovarian cancer. Int J Gynecol Cancer. 2002;12(6):720-7. Exclude: non-specific general prognosis. [pmid: 12445249].
320 Saip P, Tuzlali S, Demir K, et al. Value of glutathion-S transferase pi as a prognostic factor in epithelial ovarian carcinoma. Eur J Gynaecol Oncol. 2005;26(1):90-4. Exclude: no 2×2 table. [pmid: 15755010].
321 Saito M, Aoki D, Susumu N, et al. Efficient screening for ovarian cancers using a combination of tumor markers CA602 and CA546. Int J Gynecol Cancer. 2005;15(1):37-44. Exclude: no patient-level data. [pmid: 15670295].
322 Sakamoto M, Kondo A, Kawasaki K, et al. Analysis of gene expression profiles associated with cisplatin resistance in human ovarian cancer cell lines and tissues using cDNA microarray. Hum Cell. 2001;14(4):305-15. Exclude: not asymptomatic women. [pmid: 11925933].
323 Santala M, Risteli J, Kauppila A. Comparison of carboxyterminal telopeptide of type I collagen (ICTP) and CA 125 as predictors of prognosis in ovarian cancer. Anticancer Res. 2004;24(2C):1057-62. Exclude: non-specific general prognosis. [pmid: 15154623].
324 Santala M, Risteli L, Puistola U, et al. Elevated serum ICTP concentrations reflect poor prognosis in patients with ovarian carcinoma. Ann Med. 1995;27(1):57-61. Exclude: non-specific general prognosis. [pmid: 7742000].
325 Santala M, Simojoki M, Risteli J, et al. Type I and III collagen metabolites as predictors of clinical outcome in epithelial ovarian cancer. Clin Cancer Res. 1999;5(12):4091-6. Exclude: non-specific general prognosis. [pmid: 10632345].
326 Santin AD, Zhan F, Bellone S, et al. Discrimination between uterine serous papillary carcinomas and ovarian serous papillary tumours by gene expression profiling. Br J Cancer. 2004;90(9):1814-24. Exclude: no 2×2 table. [pmid: 15208622].
327 Santin AD, Zhan F, Bellone S, et al. Gene expression profiles in primary ovarian serous papillary tumors and normal ovarian epithelium: identification of candidate molecular markers for ovarian cancer diagnosis and therapy. Int J Cancer. 2004;112(1):14-25. Exclude: cell line only. [pmid: 15305371].
328 Santos AM, Sousa H, Portela C, et al. TP53 and P21 polymorphisms: response to cisplatinum/paclitaxel-based chemotherapy in ovarian cancer. Biochem Biophys Res Commun. 2006;340(1):256-62. Exclude: no 2×2 table. [pmid: 16364249].
329 Sarandakou A, Phocas I, Botsis D, et al. Tumour-associated antigens CEA, CA125, SCC and TPS in gynaecological cancer. Eur J Gynaecol Oncol. 1998;19(1):73-7. Exclude: no 2×2 table. [pmid: 9476065].
330 Sawiris GP, Sherman-Baust CA, Becker KG, et al. Development of a highly specialized cDNA array for the study and diagnosis of epithelial ovarian cancer. Cancer Res. 2002;62(10):2923-8. Exclude: no 2×2 table. [pmid: 12019173].
331 Saygan-Karamursel B, Dikmen G, Dogan P, et al. Quantitative telomerase activity in malignant, benign and normal gynecological tissues. Eur J Gynaecol Oncol. 2005;26(1):83-6. Exclude: no 2×2 table. [pmid: 15755008].
332 Scambia G, Benedetti P, Ferrandina G, et al. Cathepsin D assay in ovarian cancer: correlation with pathological features and receptors for oestrogen, progesterone and epidermal growth factor. Br J Cancer. 1991;64(1):182-4. Exclude: no 2×2 table. [pmid: 1854619].
333 Scambia G, Testa U, Benedetti Panici P, et al. Prognostic significance of interleukin 6 serum levels in patients with ovarian cancer. Br J Cancer. 1995;71(2):354-6. Exclude: no 2×2 table. [pmid: 7841052].
334 Schaner ME, Ross DT, Ciaravino G, et al. Gene expression patterns in ovarian carcinomas. Mol Biol Cell. 2003;14(11):4376-86. Exclude: no 2×2 table. [pmid: 12960427]. [pmcid: 266758].
335 Schauenstein E, Lahousen M, Weblacher M, et al. Selective decrease in serum immunoglobulin G1. A tissue nonspecific tumor marker detecting early stages of gynecologic malignant disease with high efficiency. Cancer. 1996;78(3):511-6. Exclude: no 2×2 table. [pmid: 8697398].
336 Schmider A, Gee C, Friedmann W, et al. p21 (WAF1/CIP1) protein expression is associated with prolonged survival but not with p53 expression in epithelial ovarian carcinoma. Gynecol Oncol. 2000;77(2):237-42. Exclude: non-specific general prognosis. [pmid: 10785471].
337 Schneider D, Halperin R, Langer R, et al. Peritoneal fluid lactate dehydrogenase in ovarian cancer. Gynecol Oncol. 1997;66(3):399-404. Exclude: not asymptomatic women. [pmid: 9299252].
338 Schorge JO, Drake RD, Lee H, et al. Osteopontin as an adjunct to CA125 in detecting recurrent ovarian cancer. Clin Cancer Res. 2004;10(10):3474-8. Exclude: no 2×2 table. [pmid: 15161704].
339 Schraml P, Schwerdtfeger G, Burkhalter F, et al. Combined array comparative genomic hybridization and tissue microarray analysis suggest PAK1 at 11q13.5-q14 as a critical oncogene target in ovarian carcinoma. Am J Pathol. 2003;163(3):985-92. Exclude: no 2×2 table. [pmid: 12937139]. [pmcid: 1868266].
340 Schummer M, Ng WV, Bumgarner RE, et al. Comparative hybridization of an array of 21,500 ovarian cDNAs for the discovery of genes overexpressed in ovarian carcinomas. Gene. 1999;238(2):375-85. Exclude: no 2×2 table. [pmid: 10570965].
341 Schwartz DR, Kardia SL, Shedden KA, et al. Gene expression in ovarian cancer reflects both morphology and biological behavior, distinguishing clear cell from other poor-prognosis ovarian carcinomas. Cancer Res. 2002;62(16):4722-9. Exclude: no 2×2 table. [pmid: 12183431].
342 Schwartz DR, Wu R, Kardia SL, et al. Novel candidate targets of beta-catenin/T-cell factor signaling identified by gene expression profiling of ovarian endometrioid adenocarcinomas. Cancer Res. 2003;63(11):2913-22. Exclude: no 2×2 table. [pmid: 12782598].
343 Scorilas A, Borgono CA, Harbeck N, et al. Human kallikrein 13 protein in ovarian cancer cytosols: a new favorable prognostic marker. J Clin Oncol. 2004;22(4):678-85. Exclude: non-specific general prognosis. [pmid: 14966091].
344 Seballos L, Zhang JZ, Sutphen R. Surface-enhanced Raman scattering detection of lysophosphatidic acid. Anal Bioanal Chem. 2005;383(5):763-7. Exclude: no 2×2 table. [pmid: 16261318].
345 Selvanayagam ZE, Cheung TH, Wei N, et al. Prediction of chemotherapeutic response in ovarian cancer with DNA microarray expression profiling. Cancer Genet Cytogenet. 2004;154(1):63-6. Exclude: no 2×2 table. [pmid: 15381375].
346 Semczuk A, Postawski K, Przadka D, et al. K-ras gene point mutations and p21ras immunostaining in human ovarian tumors. Eur J Gynaecol Oncol. 2004;25(4):484-8. Exclude: no relevant data. [pmid: 15285310].
347 Sengupta PS, McGown AT, Bajaj V, et al. p53 and related proteins in epithelial ovarian cancer. Eur J Cancer. 2000;36(18):2317-28. Exclude: non-specific general prognosis. [pmid: 11094305].
348 Shedden KA, Kshirsagar MP, Schwartz DR, et al. Histologic type, organ of origin, and Wnt pathway status: effect on gene expression in ovarian and uterine carcinomas. Clin Cancer Res. 2005;11(6):2123-31. Exclude: cell line only. [pmid: 15788657].
349 Shen GH, Ghazizadeh M, Kawanami O, et al. Prognostic significance of vascular endothelial growth factor expression in human ovarian carcinoma. Br J Cancer. 2000;83(2):196-203. Exclude: non-specific general prognosis. [pmid: 10901370].
350 Sheppard R, Fry A, Rush R, et al. Women at risk of ovarian cancer: attitudes towards and expectations of the familial ovarian cancer clinic. Fam Cancer. 2001;1(1):31-7. Exclude: relevant review. [pmid: 14574013].
351 Shiraishi Y, Yamamoto K, Soma H. Characteristic mucinous ovarian cancer antigen is expressed in malignantly transformed Bloom's syndrome cells. Cancer Res. 1993;53(14):3427-32. Exclude: cell line only. [pmid: 8391927].
352 Shridhar V, Lee J, Pandita A, et al. Genetic analysis of early- versus late-stage ovarian tumors. Cancer Res. 2001;61(15):5895-904. Exclude: no 2×2 table. [pmid: 11479231].
353 Shvartsman HS, Lu KH, Lee J, et al. Overexpression of kallikrein 10 in epithelial ovarian carcinomas. Gynecol Oncol. 2003;90(1):44-50. Exclude: no 2×2 table. [pmid: 12821340].
354 Sier CF, Sidenius N, Mariani A, et al. Presence of urokinase-type plasminogen activator receptor in urine of cancer patients and its possible clinical relevance. Lab Invest. 1999;79(6):717-22. Exclude: no 2×2 table. [pmid: 10378514].
355 Siervo-Sassi RR, Marrangoni AM, Feng X, et al. Physiological and molecular effects of Apo2L/TRAIL and cisplatin in ovarian carcinoma cell lines. Cancer Lett. 2003;190(1):61-72. Exclude: cell line only. [pmid: 12536078].
356 Simojoki M, Santala M, Risteli J, et al. Carboxyterminal telopeptide of type I collagen (ICTP) in predicting prognosis in epithelial ovarian cancer. Gynecol Oncol. 2001;82(1):110-5. Exclude: non-specific general prognosis. [pmid: 11426971].
357 Simojoki M, Santala M, Risteli J, et al. Serial determinations of aminoterminal propeptide of type III procollagen (PIIINP) and prognosis in ovarian cancer; comparison to CA125. Anticancer Res. 2000;20(6C):4655-60. Exclude: not asymptomatic women. [pmid: 11205196].
358 Simon I, Zhuo S, Corral L, et al. B7-h4 is a novel membrane-bound protein and a candidate serum and tissue biomarker for ovarian cancer. Cancer Res. 2006;66(3):1570-5. Exclude: no 2×2 table. [pmid: 16452214].
359 Singer G, Rebmann V, Chen YC, et al. HLA-G is a potential tumor marker in malignant ascites. Clin Cancer Res. 2003;9(12):4460-4. Exclude: not OVCA. [pmid: 14555519].
360 Skates SJ, Xu FJ, Yu YH, et al. Toward an optimal algorithm for ovarian cancer screening with longitudinal tumor markers. Cancer. 1995;76(10 Suppl):2004-10. Exclude: CA125 for diagnosis. [pmid: 8634992].
361 Skirnisdottir I, Seidal T, Karlsson MG, et al. Clinical and biological characteristics of clear cell carcinomas of the ovary in FIGO stages I–II. Int J Oncol. 2005;26(1):177-83. Exclude: no controls. [pmid: 15586238].
362 Skirnisdottir I, Seidal T, Sorbe B. A new prognostic model comprising p53, EGFR, and tumor grade in early stage epithelial ovarian carcinoma and avoiding the problem of inaccurate surgical staging. Int J Gynecol Cancer. 2004;14(2):259-70. Exclude: non-specific general prognosis. [pmid: 15086725].
363 Sliutz G, Tempfer C, Kainz C, et al. Tissue polypeptide specific antigen and cancer associated serum antigen in the follow-up of ovarian cancer. Anticancer Res. 1995;15(3):1127-9. Exclude: no 2×2 table. [pmid: 7645936].
364 Spentzos D, Levine DA, Kolia S, et al. Unique gene expression profile based on pathologic response in epithelial ovarian cancer. J Clin Oncol. 2005;23(31):7911-8. Exclude: no 2×2 table. [pmid: 16204010].
365 Spentzos D, Levine DA, Ramoni MF, et al. Gene expression signature with independent prognostic significance in epithelial ovarian cancer [erratum appears in J Clin Oncol. 2005 Jan 1;23(1):248]. J Clin Oncol. 2004;22(23):4700-10. Exclude: non-specific general prognosis. [pmid: 15505275].
366 Srivastava A, McKinnon W, Wood ME. Risk of breast and ovarian cancer in women with strong family histories. Oncology (Huntingt). 905;15(7):889-902. discussion 902. Exclude: relevant review. [pmid: 11499690].
367 Srokowski T, Pfeifer JD, Li J, et al. Expression and localization of GRP75 in human epithelial tumors and normal tissues. Appl Immunohistochem Mol Morphol. 2004;12(2):132-8. Exclude: no 2×2 table. [pmid: 15354738].
368 Stevens EV, Liotta LA, Kohn EC. Proteomic analysis for early detection of ovarian cancer: a realistic approach?. Int J Gynecol Cancer. 2003;13(Suppl 2):133-9. Exclude: relevant review. [pmid: 14656269].
369 Stone B, Schummer M, Paley PJ, et al. Serologic analysis of ovarian tumor antigens reveals a bias toward antigens encoded on 17q. Int J Cancer. 2003;104(1):73-84. Exclude: not OVCA. [pmid: 12532422].
370 Stratton JF, Thompson D, Bobrow L, et al. The genetic epidemiology of early-onset epithelial ovarian cancer: a population-based study. Am J Hum Genet. 1999;65(6):1725-32. Exclude: unrelated. [pmid: 10577927]. [pmcid: 1288384].
371 Sun XM, Dong WG, Yu BP, et al. Detection of type IV collagenase activity in malignant ascites. World J Gastroenterol. 2003;9(11):2592-5. Exclude: not OVCA. [pmid: 14606104].
372 Sun P, Sehouli J, Denkert C, et al. Expression of estrogen receptor-related receptors, a subfamily of orphan nuclear receptors, as new tumor biomarkers in ovarian cancer cells. J Mol Med. 2005;83(6):457-67. Exclude: no 2×2 table. [pmid: 15770498].
373 Sundfeldt K, Ivarsson K, Rask K, et al. Higher levels of soluble E-cadherin in cyst fluid from malignant ovarian tumours than in benign cysts. Anticancer Res. 2001;21(1A):65-70. Exclude: no 2×2 table. [pmid: 11299791].
374 Suzuki M, Ohwada M, Saga Y, et al. Micrometastatic p53-positive cells in the lymph nodes of early stage epithelial ovarian cancer: prognostic significance. Oncology. 2001;60(2):170-5. Exclude: no 2×2 table. [pmid: 11244333].
375 Suzuki M, Ohwada M, Sato I, et al. Serum level of macrophage colony-stimulating factor as a marker for gynecologic malignancies. Oncology. 1995;52(2):128-33. Exclude: non-specific general prognosis. [pmid: 7854772].
376 Suzuki M, Tamura N, Kobayashi H, et al. Clinical significance of combined use of macrophage colony-stimulating factor and squamous cell carcinoma antigen as a selective diagnostic marker for squamous cell carcinoma arising in mature cystic teratoma of the ovary. Gynecol Oncol. 2000;77(3):405-9. Exclude: only germ cell or stromal. [pmid: 10831350].
377 Swisher EM, Wollan M, Mahtani SM, et al. Tumor-specific p53 sequences in blood and peritoneal fluid of women with epithelial ovarian cancer. Am J Obstet Gynecol. 2005;193(3 Pt 1):662-7. Exclude: no 2×2 table. [pmid: 16150257].
378 Takai N, Miyazaki T, Nishida M, et al. c-Ets1 is a promising marker in epithelial ovarian cancer. Int J Mol Med. 2002;9(3):287-92. Exclude: non-specific general prognosis. [pmid: 11836635].
379 Tanner B, Kreutz E, Weikel W, et al. Prognostic significance of c-erB-2 mRNA in ovarian carcinoma. Gynecol Oncol. 1996;62(2):268-77. Exclude: no 2×2 table. [pmid: 8751560].
380 Tapper J, Kettunen E, El-Rifai W, et al. Changes in gene expression during progression of ovarian carcinoma. Cancer Genet Cytogenet. 2001;128(1):1-6. Exclude: no 2×2 table. [pmid: 11454421].
381 Tavares Murta BM, Cunha Fde Q, Miranda R, et al. Differential tumor microenvironment in human ovarian cystic tumors. Tumori. 2004;90(5):491-7. Exclude: no 2×2 tablet. [pmid: 15656335].
382 Tempfer C, Zeisler H, Sliutz G, et al. Serum evaluation of interleukin 6 in ovarian cancer patients. Gynecol Oncol. 1997;66(1):27-30. Exclude: no 2×2 table. [pmid: 9234916].
383 Tibshirani R, Hastie T, Narasimhan B, et al. Sample classification from protein mass spectrometry, by ‘peak probability contrasts’. Bioinformatics. 2004;20(17):3034-44. Exclude: no 2×2 table. [pmid: 15226172].
384 Tomic S, Ilic Forko J, Babic D, et al. c-erbB-2, p53, and nm23 proteins as prognostic factors in patients with epithelial ovarian carcinoma. Croat Med J. 2003;44(4):429-34. Exclude: no 2×2 table. [pmid: 12950146].
385 Tonin PN, Hudson TJ, Rodier F, et al. Microarray analysis of gene expression mirrors the biology of an ovarian cancer model. Oncogene. 2001;20(45):6617-26. Exclude: cell line only. [pmid: 11641787].
386 Tornillo L, Moch H, Diener PA, et al. CDX-2 immunostaining in primary and secondary ovarian carcinomas. J Clin Pathol. 2004;57(6):641-3. Exclude: pathology study. [pmid: 15166272]. [pmcid: 1770317].
387 Tsuda H, Hashiguchi Y, Nakata S, et al. The CA125 regression rate to predict overall survival differ between paclitaxel-containing regimen and nonpaclitaxel regimen in patients with advanced ovarian cancer. Int J Gynecol Cancer. 2002;12(5):435-7. Exclude: no 2×2 table. [pmid: 12366658].
388 Tsuda H, Ito YM, Ohashi Y, et al. Identification of overexpression and amplification of ABCF2 in clear cell ovarian adenocarcinomas by cDNA microarray analyses. Clin Cancer Res. 2005;11(19 Pt 1):6880-8. Exclude: no 2×2 table. [pmid: 16203778].
389 Tuxen MK, Soletormos G, Dombernowsky P. Serum tumor marker CA 125 for monitoring ovarian cancer during follow-up. Scand J Clin Lab Invest. 2002;62(3):177-88. Exclude: non-specific general prognosis. [pmid: 12088336].
390 Tuxen MK, Soletormos G, Petersen PH, et al. Assessment of biological variation and analytical imprecision of CA 125, CEA, and TPA in relation to monitoring of ovarian cancer. Gynecol Oncol. 1999;74(1):12-22. Exclude: publication duplicate. [pmid: 10385546].
391 Uslu R, Sanli UA, Dikmen Y, et al. Predictive value of serum interleukin-8 levels in ovarian cancer patients treated with paclitaxel-containing regimens. Int J Gynecol Cancer. 2005;15(2):240-5. Exclude: no 2×2 table. [pmid: 15823106].
392 Uttenreuther-Fischer MM, Feistel H, Wolf F, et al. Distribution of radiolabelled anti-CA125 monoclonal antibody OC125-F(ab)2-fragment following resection guided by antibodies (REGAJ) in ovarian cancer patients. J Clin Lab Anal. 1997;11(2):94-103. Exclude: no 2×2 table. [pmid: 9058243].
393 van Dalen A, Favier J, Baumgartner L, et al. Prognostic significance of CA 125 and TPS levels after chemotherapy in ovarian cancer patients. Anticancer Res. 1999;19(4A):2523-6. Exclude: non-specific general prognosis. [pmid: 10470187].
394 Van Dalen A, Favier J, Baumgartner L, et al. Serum levels of CA 125 and TPS during treatment of ovarian cancer. Anticancer Res. 2000;20(6D):5107-8. Exclude: no 2×2 table. [pmid: 11326677].
395 Verri E, Guglielmini P, Puntoni M, et al. HER2/neu oncoprotein overexpression in epithelial ovarian cancer: evaluation of its prevalence and prognostic significance. Clinical study. Oncology. 2005;68(23):154-61. Exclude: no 2×2 table. [pmid: 16020953].
396 Wabersich J, Fracas M, Mazzer S, et al. The value of the prognostic factors in ovarian granulosa cell tumors. Eur J Gynaecol Oncol. 1998;19(1):69-72. Exclude: only germ cell or stromal. [pmid: 9476064].
397 Walach N, Gur Y. Leukocyte alkaline phosphatase, CA15-3, CA125, and CEA in cancer patients. Tumori. 1998;84(3):360-3. Exclude: prognosis only, no link to mgmt or outcomes. [pmid: 9678617].
398 Wang E, Ngalame Y, Panelli MC, et al. Peritoneal and subperitoneal stroma may facilitate regional spread of ovarian cancer. Clin Cancer Res. 2005;11(1):113-22. Exclude: no 2×2 table. [pmid: 15671535].
399 Wang H, Huang H. SED, a normalization free method for DNA microarray data analysis. BMC Bioinformatics. 2004;5(1):121. Exclude: no 2×2 table. [pmid: 15345033]. [pmcid: 517708].
400 Wang K, Gan L, Jeffery E, et al. Monitoring gene expression profile changes in ovarian carcinomas using cDNA microarray. Gene. 1999;229(12):101-8. Exclude: no 2×2 table. [pmid: 10095109].
401 Wardle J. Women at risk of ovarian cancer. J Natl Cancer Inst Monogr 1995;(17):81–5. Exclude: BRCA-Q5.
402 Warrenfeltz S, Pavlik S, Datta S, et al. Gene expression profiling of epithelial ovarian tumours correlated with malignant potential. Mol Cancer. 2004;3(1):27. Exclude: not asymptomatic women. [pmid: 15471544]. [pmcid: 524500].
403 Watson P, Narod SA, Fodde R, et al. Carrier risk status changes resulting from mutation testing in hereditary non-polyposis colorectal cancer and hereditary breast-ovarian cancer. J Med Genet. 2003;40(8):591-6. Exclude: no 2×2 table. [pmid: 12920070]. [pmcid: 1735553].
404 Wei SH, Chen CM, Strathdee G, et al. Methylation microarray analysis of late-stage ovarian carcinomas distinguishes progression-free survival in patients and identifies candidate epigenetic markers. Clin Cancer Res. 2002;8(7):2246-52. Exclude: no 2×2 table. [pmid: 12114427].
405 Welsh JB, Zarrinkar PP, Sapinoso LM, et al. Analysis of gene expression profiles in normal and neoplastic ovarian tissue samples identifies candidate molecular markers of epithelial ovarian cancer. Proc Natl Acad Sci U S A. 2001;98(3):1176-81. Exclude: no 2×2 table. [pmid: 11158614]. [pmcid: 14728].
406 Wenham RM, Calingaert B, Ali S, et al. Matrix metalloproteinase-1 gene promoter polymorphism and risk of ovarian cancer. J Soc Gynecol Invest. 2003;10(6):381-7. Exclude: prognosis only, no link to mgmt or outcomes.
407 Wiechen K, Diatchenko L, Agoulnik A, et al. Caveolin-1 is down-regulated in human ovarian carcinoma and acts as a candidate tumor suppressor gene. Am J Pathol. 2001;159(5):1635-43. Exclude: no 2×2 table. [pmid: 11696424]. [pmcid: 1867061].
408 Wilder JL, Pavlik E, Straughn JM, et al. Clinical implications of a rising serum CA-125 within the normal range in patients with epithelial ovarian cancer: a preliminary investigation. Gynecol Oncol. 2003;89(2):233-5. Exclude: no 2×2 table. [pmid: 12713985].
409 Wojciechowska-Lacka A, Markowska J, Skasko E, et al. Frequent disease progression and early recurrence in patients with familial ovarian cancer primarily treated with paclitaxel and cis- or carboplatin (preliminary report). Eur J Gynaecol Oncol. 2003;24(1):21-4. Exclude: Drug mech ab action. [pmid: 12691311].
410 Wong KK, Cheng RS, Mok SC. Identification of differentially expressed genes from ovarian cancer cells by MICROMAX cDNA microarray system. Biotechniques. 2001;30(3):670-5. Exclude: no 2×2 table. [pmid: 11252802].
411 Woong-Shick A, Sung-Pil P, Su-Mi B, et al. Identification of hemoglobin-alpha and -beta subunits as potential serum biomarkers for the diagnosis and prognosis of ovarian cancer. Cancer Sci. 2005;96(3):197-201. Exclude: non-specific general prognosis. [pmid: 15771624].
412 Wrigley E, Verspaget HW, Jayson GC, et al. Metallothionein expression in epithelial ovarian cancer: effect of chemotherapy and prognostic significance. J Cancer Res Clin Oncol. 2000;126(12):717-21. Exclude: non-specific general prognosis. [pmid: 11153145].
413 Wu JT, Astill ME, Gagon SD, et al. Measurement of c-erbB-2 proteins in sera from patients with carcinomas and in breast tumor tissue cytosols: correlation with serum tumor markers and membrane-bound oncoprotein. J Clin Lab Anal. 1995;9(3):151-65. Exclude: no 2×2 table. [pmid: 7541455].
414 Wu JT, Erickson AJ, Tsao KC, et al. Elevated serum chromogranin A is detectable in patients with carcinomas at advanced disease stages. Ann Clin Lab Sci. 2000;30(2):175-8. Exclude: no 2×2 table. [pmid: 10807161].
415 Wu TL, Zhang D, Chia JH, et al. Cell-free DNA: measurement in various carcinomas and establishment of normal reference range. Clin Chim Acta. 2002;321(12):77-87. Exclude: no 2×2 table. [pmid: 12031596].
416 Xiao Y, Chen Y, Kennedy AW, et al. Evaluation of plasma lysophospholipids for diagnostic significance using electrospray ionization mass spectrometry (ESI-MS) analyses. Ann N Y Acad Sci. 2000;905:242-59. Exclude: no 2×2 table. [pmid: 10818458].
417 Xie D, Lau SH, Sham JS, et al. Up-regulated expression of cytoplasmic clusterin in human ovarian carcinoma. Cancer. 2005;103(2):277-83. Exclude: no relevant data. [pmid: 15578711].
418 Xu S, Mou H, Lu G, et al. Gene expression profile differences in high and low metastatic human ovarian cancer cell lines by gene chip. Chin Med J (Engl). 2002;115(1):36-41. Exclude: cell line only. [pmid: 11930655].
419 Xu Y, Shen Z, Wiper DW, et al. Lysophosphatidic acid as a potential biomarker for ovarian and other gynecologic cancers. JAMA. 1998;280(8):719-23. Exclude: no 2×2 table. [pmid: 9728644].
420 Yacyshyn MB, Poppema S, Berg A, et al. CD69+ and HLA-DR+ activation antigens on peripheral blood lymphocyte populations in metastatic breast and ovarian cancer patients: correlations with survival following active specific immunotherapy. Int J Cancer. 1995;61(4):470-4. Exclude: no 2×2 table. [pmid: 7538976].
421 Yamashita K, Aitio ML, Dawson JR. Characterization of the carcinoembryonic antigen activity associated with cyst fluids of mucinous ovarian cystadenocarcinoma. Cancer Res. 1979;39(5):1760-5. Exclude: no 2×2 table. [pmid: 85489].
422 Yang SH, Kim JS, Oh TJ, et al. Genome-scale analysis of resveratrol-induced gene expression profile in human ovarian cancer cells using a cDNA microarray. Int J Oncol. 2003;22(4):741-50. Exclude: cell line only. [pmid: 12632063].
423 Ye B, Cramer DW, Skates SJ, et al. Haptoglobin-alpha subunit as potential serum biomarker in ovarian cancer: identification and characterization using proteomic profiling and mass spectrometry. Clin Cancer Res. 2003;9(8):2904-11. Exclude: no 2×2 table. [pmid: 12912935].
424 Yedema KA, Kenemans P, Wobbes T, et al. Carcinoma-associated mucin serum markers CA M26 and CA M29: efficacy in detecting and monitoring patients with cancer of the breast, colon, ovary, endometrium and cervix. Int J Cancer. 1991;47(2):170-9. Exclude: non-specific general prognosis. [pmid: 1988362].
425 Yeh LS, Hung YC, Kao A, et al. Tissue polypeptide specific antigen (TPS) and carbohydrate antigen 125 (CA-125) in the early prediction of recurrent ovarian cancer. Anticancer Res. 2002;22(6B):3669-71. Exclude: no 2×2 table. [pmid: 12552974].
426 Yen RF, Sun SS, Shen YY, et al. Whole body positron emission tomography with 18F-fluoro-2-deoxyglucose for the detection of recurrent ovarian cancer. Anticancer Res. 2001;21(5):3691-4. Exclude: not asymptomatic women. [pmid: 11848544].
427 Yokoyama Y, Charnock-Jones DS, Licence D, et al. Vascular endothelial growth factor-D is an independent prognostic factor in epithelial ovarian carcinoma. Br J Cancer. 2003;88(2):237-44. Exclude: non-specific general prognosis. [pmid: 12610509].
428 Young RH, Hart WR. Metastatic intestinal carcinomas simulating primary ovarian clear cell carcinoma and secretory endometrioid carcinoma: a clinicopathologic and immunohistochemical study of five cases. Am J Surg Pathol. 1998;22(7):805-15. Exclude: no 2×2 table. [pmid: 9669343].
429 Yousef GM, Polymeris ME, Grass L, et al. Human kallikrein 5: a potential novel serum biomarker for breast and ovarian cancer [erratum appears in Cancer Res. 2003 Sep 1;63(17):5647]. Cancer Res. 2003;63(14):3958-65. Exclude: no 2×2 table. [pmid: 12873991].
430 Zagorianakou N, Stefanou D, Makrydimas G, et al. Clinicopathological study of metallothionein immunohistochemical expression, in benign, borderline and malignant ovarian epithelial tumors. Histol Histopathol. 2006;21(4):341-7. Exclude: no 2×2 table. [pmid: 16437378].
431 Zeimet AG, Widschwendter M, Knabbe C, et al. Ascitic interleukin-12 is an independent prognostic factor in ovarian cancer. J Clin Oncol. 1998;16(5):1861-8. Exclude: non-specific general prognosis. [pmid: 9586902].
432 Zhang X, Feng J, Cheng Y, et al. Characterization of differentially expressed genes in ovarian cancer by cDNA microarrays. Int J Gynecol Cancer. 2005;15(1):50-7. Exclude: N=4. [pmid: 15670297].
433 Zhang X, Li P, Bao J, et al. Suppression of death receptor-mediated apoptosis by 1,25-dihydroxyvitamin D3 revealed by microarray analysis. J Biol Chem. 2005;280(42):35458-68. Exclude: cell line only. [pmid: 16093247].
434 Zorn KK, Bonome T, Gangi L, et al. Gene expression profiles of serous, endometrioid, and clear cell subtypes of ovarian and endometrial cancer. Clin Cancer Res. 2005;11(18):6422-30. Exclude: no 2×2 table. [pmid: 16166416].
435 Zorn KK, Jazaeri AA, Awtrey CS, et al. Choice of normal ovarian control influences determination of differentially expressed genes in ovarian cancer expression profiling studies. Clin Cancer Res. 2003;9(13):4811-8. Exclude: no 2×2 table. [pmid: 14581352].
436 Zygmunt A, Madry R, Markowska J, et al. Estimation of the usefulness of neoplastic markers TPS and CA 125 in diagnosis and monitoring of ovarian cancer. Eur J Gynaecol Oncol. 1999;20(4):298-301. Exclude: no 2×2 table. [pmid: 10475127].