# Appendix A: Exact Search String

Database: Ovid MEDLINE^®^ <1966 to May Week 2 2006>

Search Strategy:

1 liotta l$.au.
2 Ovarian Neoplasms/
3 1 and 2
4 exp Ovarian Neoplasms/
5 exp Genomics/
6 exp Genetic Phenomena/
7 ovacheck.mp.
8 myriad.mp.
9 Chorionic Gonadotropin, beta Subunit, Human/
10 GENES, BRCA1/ or BRCA1 PROTEIN/
11 GENES, BRCA2/ or BRCA2 PROTEIN/
12 CA-125 Antigen/
13 Antigens, Tumor-Associated, Carbohydrate/
14 Carcinoembryonic Antigen/
15 Receptor, erbB-2/
16 Tumor Markers, Biological/
17 Antigens, Neoplasm/
18 4 and (or/5–17)
19 correlogic.mp.
20 4 and (or/5,7–17)
21 18 not 20
22 limit 20 to (humans and english language and abstracts)
23 exp Diagnosis/
24 exp “Sensitivity and Specificity”/
25 di.fs.
26 22 and (or/24–25)
27 3 and 26
28 3 and 22
29 3 not 28
30 28 not 27
31 *“Proteome”/
32 oligonucleotide array sequence analysis/ or protein array analysis/
33 4 and (or/5,7–17,32)
34 33 not 20
35 3 and 34
36 2 and (or/5,7–17,32)
37 *ovarian neoplasms/
38 37 and (or/5,7–17,32)
39 2 and (or/7–8,19,32)
40 3 and 39
41 39 not 26
42 3 not 26
43 41 or 42
44 limit 43 to (humans and english language)
45 limit 44 to abstracts
46 from 45 keep 1–10
47 from 45 keep 1–167
48 “Reproducibility of Results”/
49 reference standards/
50 quality control/
51 reference values/
52 or/48–51
53 52 and (or/5,7–17,19,32) and 4
54 52 and (or/5,7–17,19,32) and 4
55 52 and (or/5,7–17,19,32)
56 Genetic Screening/
57 Genetic Counseling/
58 4 and (or/56–57)
59 limit 58 to (humans and english language and abstracts)
60 59 not (26 or 45)
61 54 not (26 or 45)
62 limit 61 to (humans and abstracts)
63 genes, brca1/ or genes, brca2/
64 60 not 63
65 60 not 64
66 from 64 keep 1–155
67 from 62 keep 1–76