# List of Acronyms/Abbreviations

AAA | Abdominal Aortic Aneurysm
ACE | AnEVARysme de l'aorte abdominal: Chirurgie versus Endoprothese
ADAM | Aneurysm Detection and Management
AHIP | America's Health Insurance Plans
AHQR | Agency for Healthcare Research and Policy
ARR | Absolute Risk Reduction
CAESAR | Comparison of surveillance versus Aortic Endografting for Small Aneurysm Repair
CI | Confidence Interval
CM | Conservative Management
COPD | Chronic Obstructive Pulmonary Disease
CT | Computed Tomography
CTA | Thin-Cut Helical/Spiral CT Arteriography
DREAM | Dutch Randomized Endovascular Aneurysm Management
DRG | Diagnosis Related Group
EGS | Endovascular Aortoiliac Grafting System
EPC | Evidence-based Practice Center
EVAR | Endovascular Repair
FDA | Food and Drug Administration
FEV_1_ | Forced Expiratory Volume in 1 second
HR | Hazard Ratio
ICD-9-CM | International Classification of Diseases, 9^th^ Revision, Clinical Modification
ICER | Incremental Cost Effectiveness Ratio
ICU | Intensive Care Unit
IDE | Investigational Device Exemption
IQR | Interquartile Range
LOS | Length of Stay
NHS | National Health Service
NICE | National Institute of Clinical Excellence
NRCTs | Nonrandomized Controlled Trials
OSR | Open Surgical Repair
OVER | Open Versus Endovascular Repair
PIVOTAL | Positive Impact of endovascular Options for Treating Aneurysms
PSA | Probabilistic Sensitivity Analysis
QALY | Quality Adjusted Life Years
QOL | Quality of Life
RCT | Randomized Controlled Trials
RD | Risk Difference
RR | Relative Risk
SF-36 | Short Form-36
TEP | Technical Expert Panel
UKSAT | United Kingdom Small Aneurysm Trial
USPSTF | U.S. Preventive Services Task Force
VA | Veterans Administration