# References for Evidence Tables

1 Lederle FA, Johnson GR, Wilson SE, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. Mar 15. 1997;126(6):441-9. [pmid: 9072929].
2 Anonymous. Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. The UK participants. Lancet 1998;352(9141):1649–55.
3 Prinssen M, Buskens E, Nolthenius RP, et al. Sexual dysfunction after conventional and endovascular AAA repair: Results of the DREAM trial. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11(6):613-20.
4 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb 1. 1995;273(5):408-12. [pmid: 7823387].
5 EVAR trial participants. Endovascular aneurysm repair versus open repair in patients with abdominal aortic aneurysm (EVAR trial 1): randomised controlled trial. Lancet. Jun 25–Jul 1. 2005;365(9478):2179-86. [pmid: 15978925].
6 Cuypers PW, Gardien M, Buth J, et al. Randomized study comparing cardiac response in endovascular and open abdominal aortic aneurysm repair. Br J Surg. Aug. 2001;88(8):1059-65. [pmid: 11488790].
7 EVAR trial participants. Endovascular aneurysm repair and outcome in patients unfit for open repair of abdominal aortic aneurysm (EVAR trial 2): randomised controlled trial. Lancet. Jun 25–Jul 1. 2005;365(9478):2187-92. [pmid: 15978926].
8 Anderson PL, Arons RR, Moskowitz AJ, et al. A statewide experience with endovascular abdominal aortic aneurysm repair: Rapid diffusion with excellent early results. J Vasc Surg. Jan. 2004;39(1):10-9. [pmid: 14718804].
9 Becquemin J, Bourriez A, D'Audiffret A, et al. Mid-term results of endovascular versus open repair for abdominal aortic aneurysm in patients anatomically suitable for endovascular repair. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):656-61. [pmid: 10875781].
10 Bertrand M, Godet G, Koskas F, et al. Endovascular treatment of abdominal aortic aneurysms: is there a benefit regarding postoperative outcome?. Eur J Anaesthesiol. Apr. 2001;18(4):245-50. [pmid: 11350462].
11 Bolke E, Jehle PM, Storck M, et al. Endovascular stent-graft placement versus conventional open surgery in infrarenal aortic aneurysm: a prospective study on acute phase response and clinical outcome. Clin Chim Acta. Dec. 2001;314(12):203-7. [pmid: 11718696].
12 Criado FJ, Fairman RM, Becker GJ. Talent LPS AAA stent graft: results of a pivotal clinical trial. J Vasc Surg. Apr. 2003;37(4):709-15. [pmid: 12663967].
13 Elkouri S, Gloviczki P, McKusick MA, et al. Perioperative complications and early outcome after endovascular and open surgical repair of abdominal aortic aneurysms. J Vasc Surg. Mar. 2004;39(3):497-505. [pmid: 14981437].
14 Garcia-Madrid C, Josa M, Riambau V, et al. Endovascular versus open surgical repair of abdominal aortic aneurysm: a comparison of early and intermediate results in patients suitable for both techniques. Eur J Vasc Endovasc Surg. Oct. 2004;28(4):365-72. [pmid: 15350557].
15 Greenberg RK, Chuter TA, Sternbergh WC 3rd, et al. Zenith AAA endovascular graft: intermediate-term results of the US multicenter trial. J Vasc Surg. Jun. 2004;39(6):1209-18. [pmid: 15192559].
16 Hansman MF, Neuzil D, Quigley TM, et al. A comparison of 50 initial endoluminal endograft repairs for abdominal aortic aneurysm with 50 concurrent open repairs. Am J Surg. May. 2003;185(5):441-4. [pmid: 12727564].
17 Jordan WD, Alcocer F, Wirthlin DJ, et al. Abdominal aortic aneurysms in “high-risk” surgical patients: comparison of open and endovascular repair. Ann Surg. May. 2003;237(5):623-9. discussion 9–30. [pmid: 12724628]. [pmcid: 1514512].
18 Lee WA, Carter JW, Upchurch G, et al. Perioperative outcomes after open and endovascular repair of intact abdominal aortic aneurysms in the United States during 2001. J Vasc Surg. Mar. 2004;39(3):491-6. [pmid: 14981436].
19 Lifeline Registry of EVAR Publications Committee. Lifeline registry of endovascular aneurysm repair: long-term primary outcome measures. J Vasc Surg. Jul. 2005;42(1):1-10. [pmid: 16012445].
20 Teufelsbauer H, Prusa AM, Wolff K, et al. The impact of endovascular stent grafting on reducing mortality rates after surgical treatment of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Nov. 2003;26(5):494-500. [pmid: 14532876].
21 Zeebregts CJ, Geelkerken RH, van der Palen J, et al. Outcome of abdominal aortic aneurysm repair in the era of endovascular treatment. Br J Surg. May. 2004;91(5):563-8. [pmid: 15122606].
22 Carpenter JP, Endologix Investigators. Midterm results of the multicenter trial of the powerlink bifurcated system for endovascular aortic aneurysm repair. 40 2004;5(849–59).
23 Matsumura JS, Brewster DC, Makaroun MS, et al. A multicenter controlled clinical trial of open versus endovascular treatment of abdominal aortic aneurysm. J Vasc Surg. Feb. 2003;37(2):262-71. [pmid: 12563194].
24 Moore WS, Matsumura JS, Makaroun MS, et al. Five-year interim comparison of the Guidant bifurcated endograft with open repair of abdominal aortic aneurysm. J Vasc Surg. Jul. 2003;38(1):46-55. [pmid: 12844088].
25 Resch T, Malina M, Lindblad B, et al. The evolution of Z stent-based stent-grafts for endovascular aneurysm repair: a life-table analysis of 7.5-year followup. J Am Coll Surg. Jan. 2002;194(1 Suppl):S74-8. [pmid: 11800358].
26 Haulon S, Devos P, Willoteaux S, et al. Risk factors of early and late complications in patients undergoing endovascular aneurysm repair. Eur J Vasc Endovasc Surg. Feb. 2003;25(2):118-24. [pmid: 12552471].
27 Burks JA Jr, Faries PL, Gravereaux EC, et al. Endovascular repair of abdominal aortic aneurysms: stent-graft fixation across the visceral arteries. J Vasc Surg. Jan. 2002;35(1):109-13. [pmid: 11802140].
28 Cartes-Zumelzu F, Lammer J, Hoelzenbein T, et al. Endovascular placement of a nitinol-ePTFE stent-graft for abdominal aortic aneurysms: initial and midterm results. J Vasc Interv Radiol. May. 2002;13(5):465-73. [pmid: 11997354].
29 Alric P, Hinchliffe RJ, MacSweeney ST, et al. The Zenith aortic stent-graft: a 5-year single-center experience. J Endovasc Ther. Dec. 2002;9(6):719-28. [pmid: 12546570].
30 Flora HS, Chaloner EJ, Sweeney A, et al. Secondary intervention following endovascular repair of abdominal aortic aneurysm: a single centre experience. Eur J Vasc Endovasc Surg. Sep. 2003;26(3):287-92. [pmid: 14509892].
31 Gilling-Smith GL, Martin J, Sudhindran S, et al. Freedom from endoleak after endovascular aneurysm repair does not equal treatment success. Eur J Vasc Endovasc Surg. Apr. 2000;19(4):421-5. [pmid: 10801377].
32 Ohki T, Veith FJ, Shaw P, et al. Increasing incidence of midterm and long-term complications after endovascular graft repair of abdominal aortic aneurysms: a note of caution based on a 9-year experience. Ann Surg. Sep. 2001;234(3):323-34. discussion 34–5. [pmid: 11524585]. [pmcid: 1422023].
33 Parlani G, Zannetti S, Verzini F, et al. Does the presence of an iliac aneurysm affect outcome of endoluminal AAA repair? An analysis of 336 cases. Eur J Vasc Endovasc Surg. Aug. 2002;24(2):134-8. [pmid: 12389235].
34 Faries PL, Briggs VL, Rhee JY, et al. Failure of endovascular aortoaortic tube grafts: a plea for preferential use of bifurcated grafts. J Vasc Surg. May. 2002;35(5):868-73. [pmid: 12021700].
35 Tutein Nolthenius RP, van Herwaarden JA, van den Berg JC, et al. Three year single centre experience with the AneuRx aortic stent graft. Eur J Vasc Endovasc Surg. Sep. 2001;22(3):257-64. [pmid: 11506520].
36 Ricco JB, Goeau-Brissonniere O, Rodde-Dunet MH, et al. Use of abdominal aortic endovascular prostheses in France from 1999 to 2001. J Vasc Surg. Dec. 2003;38(6):1273-81. discussion 82. [pmid: 14681627].
37 May J, White GH, Waugh R, et al. Life-table analysis of primary and assisted success following endoluminal repair of abdominal aortic aneurysms: the role of supplementary endovascular intervention in improving outcome. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):648-55. [pmid: 10873735].
38 Blum U, Hauer M, Pfammatter T, et al. Percutaneous endoprosthesis for treatment of aortic aneurysms. World J Surg. Mar. 2001;25(3):347-52. discussion 53–4. [pmid: 11343191].
39 Albertini JN, Branchereau A, Hopkinson B, et al. Mortality and morbidity following endovascular repair of abdominal aortic aneurysms: analysis of two single centre experiences. Eur J Vasc Endovasc Surg. Nov. 2001;22(5):429-35. [pmid: 11735181].
40 Ouriel K, Greenberg RK, Clair DG, et al. Endovascular aneurysm repair: gender-specific results. J Vasc Surg. Jul. 2003;38(1):93-8. [pmid: 12844096].
41 Thomas SM, Beard JD, Ireland M, et al. Results from the prospective registry of endovascular treatment of abdominal aortic aneurysms (RETA): mid term results to five years. Eur J Vasc Endovasc Surg. Jun. 2005;29(6):563-70. [pmid: 15878530].
42 Zarins CK. The US AneuRx Clinical Trial: 6-year clinical update 2002. J Vasc Surg. Apr. 2003;37(4):904-8. [pmid: 12664000].
43 Fransen GA, Desgranges P, Laheij RJ, et al. Frequency, predictive factors, and consequences of stent-graft kink following endovascular AAA repair. J Endovasc Ther. Oct. 2003;10(5):913-8. [pmid: 14656182].
44 Laheij RJ, van Marrewijk CJ, Buth J, et al. The influence of team experience on outcomes of endovascular stenting of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Aug. 2002;24(2):128-33. [pmid: 12389234].
45 Criado FJ, Wilson EP, Fairman RM, et al. Update on the Talent aortic stent-graft: a preliminary report from United States phase I and II trials. J Vasc Surg. Feb. 2001;33(2 Suppl):S146-9. [pmid: 11174826].
46 Carpenter JP, Anderson WN, Brewster DC, et al. Multicenter pivotal trial results of the Lifepath System for endovascular aortic aneurysm repair. J Vasc Surg. Jan. 2004;39(1):34-43. [pmid: 14718809].
47 Elkouri S, Gloviczki P, McKusick MA, et al. Endovascular repair of abdominal aortic aneurysms: initial experience with 100 consecutive patients. Mayo Clin Proc. Oct. 2003;78(10):1234-42. [pmid: 14531482].
48 Zannetti S, De Rango P, Parlani G, et al. Endovascular abdominal aortic aneurysm repair in high-risk patients: a single centre experience. Eur J Vasc Endovasc Surg. Apr. 2001;21(4):334-8. [pmid: 11359334].
49 Vallabhaneni SR, Harris PL. Lessons learnt from the EUROSTAR registry on endovascular repair of abdominal aortic aneurysm repair. Eur J Radiol. Jul. 2001;39(1):34-41. [pmid: 11439229].
50 Resch T, Malina M, Lindblad B, et al. The impact of stent-graft development on outcome of AAA repair—a 7-year experience. Eur J Vasc Endovasc Surg. Jul. 2001;22(1):57-61. [pmid: 11461105].
51 Lifeline Registry of EVAR Publications Committee. Lifeline Registry of Endovascular Aneurysm Repair: Registry data report. J Vasc Surg. 2002;35(3):616-20. [pmid: 11877719].
52 Howell MH, Zaqqa M, Villareal RP, et al. Endovascular exclusion of abdominal aortic aneurysms: initial experience with stent-grafts in cardiology practice. Tex Heart Inst J. 2000;27(2):136-45. [pmid: 10928501]. [pmcid: 101048].
53 Lee WA, Wolf YG, Hill BB, et al. The first 150 endovascular AAA repairs at a single institution: how steep is the learning curve?. 2002;9(3):269-76.
54 Wolf YG, Arko FR, Hill BB, et al. Gender differences in endovascular abdominal aortic aneurysm repair with the AneuRx stent graft. J Vasc Surg. May. 2002;35(5):882-6. [pmid: 12021702].
55 Arko FR, Filis KA, Hill BB, et al. Morphologic changes and outcome following endovascular abdominal aortic aneurysm repair as a function of aneurysm size. Arch Surg. Jun. 2003;138(6):651-5. discussion 5–6. [pmid: 12799337].
56 Shames ML, Sanchez LA, Rubin BG, et al. Delayed complications after endovascular AAA repair in women. J Endovasc Ther. Feb. 2003;10(1):10-5. [pmid: 12751923].
57 Zarins CK, Wolf YG, Lee WA, et al. Will endovascular repair replace open surgery for abdominal aortic aneurysm repair?. Ann Surg. Oct. 2000;232(4):501-7. [pmid: 10998648]. [pmcid: 1421182].
58 Ayerdi J, McLafferty RB, Markwell SJ, et al. Indications and outcomes of AneuRx Phase III trial versus use of commercial AneuRx stent graft. J Vasc Surg. Apr. 2003;37(4):739-43. [pmid: 12663971].