# References and Included Studies

1 Gillum RF. Epidemiology of aortic aneurysm in the United States. J Clin Epidemiol. Nov. 1995;48(11):1289-98. [pmid: 7490591].
2 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): executive summary a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines. J Am Coll Cardiol. 2006;47(6):1239-312. [pmid: 16545667].
3 Lucas FL, Stukel TA, Morris AM, et al. Race and surgical mortality in the United States. Annals of Surgery. 2006;243(2):281-6. [pmid: 16432363]. [pmcid: 1448914].
4 Huber TS, Wang JG, Derrow AE, et al. Experience in the United States with intact abdominal aortic aneurysm repair. J Vasc Surg. Feb. 2001;33(2):304-10. discussion 10–11. [pmid: 11174782].
5 Lawrence PF, Gazak C, Bhirangi L, et al. The epidemiology of surgically repaired aneurysms in the United States. J Vasc Surg. Oct. 1999;30(4):632-40. [pmid: 10514202].
6 Drury D, Michaels JA, Jones L, et al. Systematic review of recent evidence for the safety and efficacy of elective endovascular repair in the management of infrarenal abdominal aortic aneurysm. Br J Surg. Aug. 2005;92(8):937-46. [pmid: 16034817].
7 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb 1. 1995;273(5):408-12. [pmid: 7823387].
8 Chaikof EL, Fillinger MF, Matsumura JS, et al. Identifying and grading factors that modify the outcome of endovascular aortic aneurysm repair. J Vasc Surg. May. 2002;35(5):1061-6. [pmid: 12021728].
9 Lederle FA, Wilson SE, Johnson GR, et al. Immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. May 9. 2002;346(19):1437-44. [pmid: 12000813].
10 Anonymous. Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. The UK participants. Lancet 1998;352(9141):1649–55.
11 Cuypers PW, Gardien M, Buth J, et al. Randomized study comparing cardiac response in endovascular and open abdominal aortic aneurysm repair. Br J Surg. Aug. 2001;88(8):1059-65. [pmid: 11488790].
12 Prinssen M, Verhoeven EL, Buth J, et al. A randomized trial comparing conventional and endovascular repair of abdominal aortic aneurysms. N Engl J Med. Oct 14. 2004;351(16):1607-18. [pmid: 15483279].
13 EVAR trial participants. Endovascular aneurysm repair versus open repair in patients with abdominal aortic aneurysm (EVAR trial 1): randomised controlled trial. Lancet. Jun 25–Jul 1. 2005;365(9478):2179-86. [pmid: 15978925].
14 Sicard GA, Zwolak RM, Sidawy AN, et al. Endovascular abdominal aortic aneurysm repair: Long-term outcome measures in patients at high risk for open surgery. Journal of Vascular Surgery. 2006;45:229-36.
15 Goodney PP, Lucas FL, Birkmeyer JD. Should volume standards for cardiovascular surgery focus only on high-risk patients?. Circulation. Jan 28. 2003;107(3):384-7. [pmid: 12551859].
16 Dimick JB, Stanley JC, Axelrod DA, et al. Variation in death rate after abdominal aortic aneurysmectomy in the United States: Impact of hospital volume, gender, and age. Ann Surg. Apr. 2002;235(4):579-85. [pmid: 11923615]. [pmcid: 1422474].
17 Michaels JA, Drury D, Thomas SM. Cost-effectiveness of endovascular abdominal aortic aneurysm repair. Br J Surg. Aug. 2005;92(8):960-7. [pmid: 16034841].
18 Fleming C, Whitlock EP, Beil TL, et al. Screening for abdominal aortic aneurysm: a best-evidence systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. Feb 1. 2005;142(3):203-11. [pmid: 15684209].
19 Lederle FA, Johnson GR, Wilson SE, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. Mar 15. 1997;126(6):441-9. [pmid: 9072929].
20 Sakalihasan N, Limet R, Defawe OD. Abdominal aortic aneurysm. Lancet. Apr 30–May 6. 2005;365(9470):1577-89. [pmid: 15866312].
21 USPSTF. Screening for abdominal aortic aneurysm: recommendation statement. Ann Intern Med. Feb 1. 2005;142(3):198-202. [pmid: 15684208].
22 Meenan RT, Fleming C, Whitlock EP, et al. Cost-effectiveness analyses of population-based screening for abdominal aortic Aneurysm. Agency for Healthcare Research and Quality, Rockville, MD. 2005 Feb. Available at: http://www.ahrq.gov/clinic/uspstf05/aaascr/aaacost.htm. Accessed Dec, 2005.
23 Wolff KS, Prusa AM, Polterauer P, et al. Endografting increases total volume of AAA repairs but not at the expense of open surgery: experience in more than 1000 patients. J Endovasc Ther. Jun. 2005;12(3):274-9. [pmid: 15943501].
24 Bush RL, Najibi S, Lin PH, et al. Conservatism and new technology: the impact on abdominal aortic aneurysm repair. Am Surg. Jan. 2002;68(1):57-60. discussion -1. [pmid: 12467319].
25 Shackley P, Slack R, Booth A, et al. Is there a positive volume-outcome relationship in peripheral vascular surgery? Results of a systematic review. Eur J Vasc Endovasc Surg. Oct. 2000;20(4):326-35. [pmid: 11035964].
26 Halm EA, Lee C, Chassin MR. How is volume related to quality in health care? A systematic review of the research literature. In: Hewitt M, ed. Interpreting the Volume-Outcome Relationship in the Context of Health Care Quality: Workshop Summary. Washington, D.C.: National Academy of Sciences, Institute of Medicine; 2000:Appendix C.
27 Halm EA, Lee C, Chassin MR. Is volume related to outcome in health care? A systematic review and methodologic critique of the literature. Ann Intern Med. Sep 17. 2002;137(6):511-20. [pmid: 12230353].
28 Katz DJ, Stanley JC, Zelenock GB. Operative mortality rates for intact and ruptured abdominal aortic aneurysms in Michigan: An eleven-year statewide experience. J Vasc Surg. May. 1994;19(5):804-15. discussion 16–7. [pmid: 8170034].
29 Manheim LM, Sohn MW, Feinglass J, et al. Hospital vascular surgery volume and procedure mortality rates in California, 1982-1994. J Vasc Surg. Jul. 1998;28(1):45-56. discussion -8. [pmid: 9685130].
30 Luft HS, Bunker JP, Enthoven AC. Should operations be regionalized? The empirical relation between surgical volume and mortality. N Engl J Med. Dec 20. 1979;301(25):1364-9. [pmid: 503167].
31 Shahian DM, Normand SL. The volumeoutcome relationship: from Luft to Leapfrog. Ann Thorac Surg. Mar. 2003;75(3):1048-58. [pmid: 12645752].
32 Adriaensen ME, Bosch JL, Halpern EF, et al. Elective endovascular versus open surgical repair of abdominal aortic aneurysms: systematic review of short-term results. Radiology. Sep. 2002;224(3):739-47. [pmid: 12202708].
33 Maher MM, McNamara AM, MacEneaney PM, et al. Abdominal aortic aneurysms: elective endovascular repair versus conventional surgery—evaluation with evidence-based medicine techniques. Radiology. Sep. 2003;228(3):647-58. [pmid: 12869684].
34 Goodney PP, Siewers AE, Stukel TA, et al. Is surgery getting safer? National trends in operative mortality. J Am Coll Surg. Aug. 2002;195(2):219-27. [pmid: 12168969].
35 Birkmeyer JD, Finlayson EV, Birkmeyer CM. Volume standards for high-risk surgical procedures: potential benefits of the Leapfrog initiative. Surgery. Sep. 2001;130(3):415-22. [pmid: 11562662].
36 Lederle FA, Johnson GR, Wilson SE, et al. Rupture rate of large abdominal aortic aneurysms in patients refusing or unfit for elective repair. JAMA. Jun 12. 2002;287(22):2968-72. [pmid: 12052126].
37 Parodi JC, Palmaz JC, Barone HD. Transfemoral intraluminal graft implantation for abdominal aortic aneurysms. Ann Vasc Surg. Nov. 1991;5(6):491-9. [pmid: 1837729].
38 Wieslander CK, Huang CC, Omura MC, et al. Endovascular workforce for peripheral vascular disease: current and future needs. J Vasc Surg. Jun. 2002;35(6):1218-25. [pmid: 12042734].
39 Arko FR, Filis KA, Seidel SA, et al. How many patients with infrarenal aneurysms are candidates for endovascular repair? The Northern California experience. J Endovasc Ther. Feb. 2004;11(1):33-40. [pmid: 14748631].
40 Wolf YG, Fogarty TJ, Olcott CI, et al. Endovascular repair of abdominal aortic aneurysms: eligibility rate and impact on the rate of open repair. J Vasc Surg. Sep. 2000;32(3):519-23. [pmid: 10957658].
41 Rutherford RB. Structural failures in abdominal aortic aneurysm stentgrafts: Threat to durability and challenge to technology. Semin Vasc Surg. Dec. 2004;17(4):294-7. [pmid: 15614754].
42 Geller SC. Imaging guidelines for abdominal aortic aneurysm repair with endovascular stent grafts. J Vasc Interv Radiol. 2003;14:S263-4. [pmid: 14514830].
43 Chaikof EL, Blankensteijn JD, Harris PL, et al. Reporting standards for endovascular aortic aneurysm repair. J Vasc Surg. May. 2002;35(5):1048-60. [pmid: 12021727].
44 Luft HS, Hunt SS, Maerki SC. The volume-outcome relationship: practice-makes-perfect or selective-referral patterns?. Health Serv Res. Jun. 1987;22(2):157-82. [pmid: 3112042]. [pmcid: 1065430].
45 Hannan EL, Kilburn H Jr, O'Donnell JF, et al. A longitudinal analysis of the relationship between in-hospital mortality in New York State and the volume of abdominal aortic aneurysm surgeries performed. Health Serv Res. Oct. 1992;27(4):517-42. [pmid: 1399655]. [pmcid: 1069892].
46 Milstein A, Galvin RS, Delbanco SF, et al. Improving the safety of health care: the leapfrog initiative. Eff Clin Pract. Nov–Dec. 2000;3(6):313-6. [pmid: 11151534].
47 Dudley RA, Johansen KL, Brand R, et al. Selective referral to high-volume hospitals: estimating potentially avoidable deaths. JAMA. Mar 1. 2000;283(9):1159-66. [pmid: 10703778].
48 Kazmers A, Jacobs L, Perkins A, et al. Abdominal aortic aneurysm repair in Veterans Affairs medical centers. J Vasc Surg. Feb. 1996;23(2):191-200. [pmid: 8637096].
49 Birkmeyer JD, Dimick JB, Staiger DO. Operative mortality and procedure volume as predictors of subsequent hospital performance. Ann Surg. 2006;243:411-7. [pmid: 16495708]. [pmcid: 1448928].
50 LEAPFROG. Evidence-based hospital referral fact sheet. The LEAPFROG Group. Available at: https://leapfrog.medstat.com/pdf/Final.doc. Accessed 20 October, 2005.
51 Lee WA, Carter JW, Upchurch G, et al. Perioperative outcomes after open and endovascular repair of intact abdominal aortic aneurysms in the United States during 2001. J Vasc Surg. Mar. 2004;39(3):491-6. [pmid: 14981436].
52 Brewster DC, Cronenwett JL, Hallett JW Jr, et al. Guidelines for the treatment of abdominal aortic aneurysms. Report of a subcommittee of the Joint Council of the American Association for Vascular Surgery and Society for Vascular Surgery. J Vasc Surg. May. 2003;37(5):1106-17. [pmid: 12756363].
53 Leon LR, Labropoulos N, Laredo J, et al. To what extent has endovascular aneurysm repair influenced abdominal aortic aneurysm management in the state of Illinois?. J Vasc Surg. 2005;41:568-74. [pmid: 15874918].
54 Anderson PL, Arons RR, Moskowitz AJ, et al. A statewide experience with endovascular abdominal aortic aneurysm repair: Rapid diffusion with excellent early results. J Vasc Surg. Jan. 2004;39(1):10-9. [pmid: 14718804].
55 Lobato AC, Rodriguez-Lopez J, Diethrich EB. Learning curve for endovascular abdominal aortic aneurysm repair: Evaluation of a 277-patient single-center experience. J Endovasc Ther. Jun. 2002;9(3):262-8. [pmid: 12096938].
56 Ramaiah VG, Westerband A, Thompson C, et al. The AneuRx stent-graft since FDA approval: single-center experience of 230 cases. J Endovasc Ther. Aug. 2002;9(4):464-9. [pmid: 12223007].
57 Laheij RJ, van Marrewijk CJ, Buth J, et al. The influence of team experience on outcomes of endovascular stenting of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Aug. 2002;24(2):128-33. [pmid: 12389234].
58 Torella F. on behalf of the EUROSTAR Collaborators. Effect of improved endograft design on outcome of endovascular aneurysm repair. J Vasc Surg 2004;40:216–21.
59 Brown LC, Epstein D, Manca A, et al. The UK Endovascular Aneurysm Repair (EVAR) trials: design, methodology and progress. Eur J Vasc Endovasc Surg. Apr. 2004;27(4):372-81. [pmid: 15015186].
60 Lederle FA. The VA Open versus Endovascular Repair (OVER) Trial for AAA; 2005 (in press).
61 Panageas KS, Schrag D, Riedel E, et al. The effect of clustering of outcomes on the association of procedure volume and surgical outcomes. Ann Intern Med. Oct 21. 2003;139(8):658-65. [pmid: 14568854].
62 Hallin A, Bergqvist D, Holmberg L. Literature review of surgical management of abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. Sep. 2001;22(3):197-204. [pmid: 11506510].
63 NICE. A systematic review of the recent evidence for the safety and efficacy of elective endovascular repair in the management of infrarenal abdominal aortic aneurysms. National Institute for Health and Clinical Excellence, National Health Service, U.K. 2004 Jun. Available at: http://www.nice.org.uk/pdf/ip/AAA%20stent%20review%20body%20report%20for%20web.pdf. Accessed Dec, 2005.
64 Sternbergh WC 3rd, Money SR. Hospital cost of endovascular versus open repair of abdominal aortic aneurysms: A multicenter study. J Vasc Surg. 2000;31(2):237-44. [pmid: 10664492].
65 Zierler BK, Gray DT. The principles of cost-effectiveness analysis and their application. Journal of Vascular Surgery. 2003;37(1):226-34. [pmid: 12514610].
66 Aquino RV, Jones MA, Zullo TG, et al. Quality of life assessment in patients undergoing endovascular or conventional AAA repair. J Endovasc Ther. Oct. 2001;8(5):521-8. [pmid: 11718412].
67 Berman SS, Gentile AT, Berens ES, et al. Institutional economic losses associated with AAA repair are independent of technique. J Endovasc Ther. Jun. 2002;9(3):282-8. [pmid: 12096941].
68 Birch SE, Stary DR, Scott AR. Cost of endovascular versus open surgical repair of abdominal aortic aneurysms. Aust N Z J Surg. Sep. 2000;70(9):660-6. [pmid: 10976896].
69 Forbes TL, DeRose G, Kribs S, et al. A cost-effectiveness analysis of standard versus endovascular abdominal aortic aneurysm repair. Can J Surg. Dec. 2002;45(6):420-4. [pmid: 12500916].
70 Lottman PE, Laheij RJ, Cuypers PW, et al. Health-related quality of life outcomes following elective open or endovascular AAA repair: a randomized controlled trial. J Endovasc Ther. Jun. 2004;11(3):323-9. [pmid: 15174920].
71 Rosenberg BL, Comstock MC, Butz DA, et al. Endovascular abdominal aortic aneurysm repair is more profitable than open repair based on contribution margin per day. Surgery. Mar. 2005;137(3):285-92. [pmid: 15746778].
72 Nevitt MP, Ballard DJ, Hallett JW Jr. Prognosis of abdominal aortic aneurysms. A population-based study. N Engl J Med. Oct 12. 1989;321(15):1009-14. [pmid: 2674715].
73 Scott RA, Tisi PV, Ashton HA, et al. Abdominal aortic aneurysm rupture rates: a 7-year follow-up of the entire abdominal aortic aneurysm population detected by screening. J Vasc Surg. Jul. 1998;28(1):124-8. [pmid: 9685138].
74 Scott RA, Kim LG, Ashton HA. Assessment of the criteria for elective surgery in screen-detected abdominal aortic aneurysms. J Med Screen. 2005;12(3):150-4. [pmid: 16156946].
75 Brown LC, Powell JT. Risk factors for aneurysm rupture in patients kept under ultrasound surveillance. UK Small Aneurysm Trial Participants. Ann Surg. Sep. 1999;230(3):289-96. discussion 96–97. [pmid: 10493476]. [pmcid: 1420874].
76 Santilli SM, Littooy FN, Cambria RA, et al. Expansion rates and outcomes for the 3.0-cm to the 3.9-cm infrarenal abdominal aortic aneurysm. J Vasc Surg. Apr. 2002;35(4):666-71. [pmid: 11932660].
77 Jones A, Cahill D, Gardham R. Outcome in patients with a large abdominal aortic aneurysm considered unfit for surgery. Br J Surg. Oct. 1998;85(10):1382-4. [pmid: 9782019].
78 Medtronic. Medtronic and The Cleveland Clinic launch clinical trial evaluating early treatment of small aneurysms. Available at: http://wwwp.medtronic.com/Newsroom/NewsReleaseDetails.do?itemId=1120751150202&lang=en_US. Accessed Dec, 2005.
79 Cao P. Comparison of surveillance vs Aortic Endografting for Small Aneurysm Repair (CAESAR) trial: study design and progress. Eur J Vasc Endovasc Surg. Sep. 2005;30(3):245-51. [pmid: 16130206].
80 Prinssen M, Buskens E, Blankensteijn JD, et al. Quality of life endovascular and open AAA repair. Results of a randomised trial. European Journal of Vascular & Endovascular Surgery. 2004;27(2):121-7. [pmid: 14718892].
81 Prinssen M, Buskens E, Nolthenius RP, et al. Sexual dysfunction after conventional and endovascular AAA repair: Results of the DREAM trial. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11(6):613-20.
82 United Kingdom Small Aneurysm Trial Participants. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. N Engl J Med. 2002;346(19):1445-52. [pmid: 12000814].
83 Arko FR, Hill BB, Olcott C, et al. Endovascular repair reduces early and late morbidity compared to open surgery for abdominal aortic aneurysm. J Endovasc Ther. Dec. 2002;9(6):711-8. [pmid: 12546569].
84 Becquemin J, Bourriez A, D'Audiffret A, et al. Mid-term results of endovascular versus open repair for abdominal aortic aneurysm in patients anatomically suitable for endovascular repair. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):656-61. [pmid: 10875781].
85 Bertrand M, Godet G, Koskas F, et al. Endovascular treatment of abdominal aortic aneurysms: is there a benefit regarding postoperative outcome?. Eur J Anaesthesiol. Apr. 2001;18(4):245-50. [pmid: 11350462].
86 Bolke E, Jehle PM, Storck M, et al. Endovascular stent-graft placement versus conventional open surgery in infrarenal aortic aneurysm: a prospective study on acute phase response and clinical outcome. Clin Chim Acta. Dec. 2001;314(12):203-7. [pmid: 11718696].
87 Criado FJ, Fairman RM, Becker GJ. Talent LPS AAA stent graft: results of a pivotal clinical trial. J Vasc Surg. Apr. 2003;37(4):709-15. [pmid: 12663967].
88 Hansman MF, Neuzil D, Quigley TM, et al. A comparison of 50 initial endoluminal endograft repairs for abdominal aortic aneurysm with 50 concurrent open repairs. Am J Surg. May. 2003;185(5):441-4. [pmid: 12727564].
89 Moore WS, Matsumura JS, Makaroun MS, et al. Five-year interim comparison of the Guidant bifurcated endograft with open repair of abdominal aortic aneurysm. J Vasc Surg. Jul. 2003;38(1):46-55. [pmid: 12844088].
90 Teufelsbauer H, Prusa AM, Wolff K, et al. The impact of endovascular stent grafting on reducing mortality rates after surgical treatment of abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. Nov. 2003;26(5):494-500. [pmid: 14532876].
91 Albertini JN, Branchereau A, Hopkinson B, et al. Mortality and morbidity following endovascular repair of abdominal aortic aneurysms: analysis of two single centre experiences. Eur J Vasc Endovasc Surg. Nov. 2001;22(5):429-35. [pmid: 11735181].
92 Blum U, Hauer M, Pfammatter T, et al. Percutaneous endoprosthesis for treatment of aortic aneurysms. World J Surg. Mar. 2001;25(3):347-52. discussion 53–4. [pmid: 11343191].
93 Flora HS, Chaloner EJ, Sweeney A, et al. Secondary intervention following endovascular repair of abdominal aortic aneurysm: a single centre experience. Eur J Vasc Endovasc Surg. Sep. 2003;26(3):287-92. [pmid: 14509892].
94 Ouriel K, Srivastava SD, Sarac TP, et al. Disparate outcome after endovascular treatment of small versus large abdominal aortic aneurysm. J Vasc Surg. Jun. 2003;37(6):1206-12. [pmid: 12764266].
95 Ouriel K, Greenberg RK, Clair DG, et al. Endovascular aneurysm repair: gender-specific results. J Vasc Surg. Jul. 2003;38(1):93-8. [pmid: 12844096].
96 Parlani G, Zannetti S, Verzini F, et al. Does the presence of an iliac aneurysm affect outcome of endoluminal AAA repair? An analysis of 336 cases. Eur J Vasc Endovasc Surg. Aug. 2002;24(2):134-8. [pmid: 12389235].
97 Zannetti S, De Rango P, Parlani G, et al. Endovascular abdominal aortic aneurysm repair in high-risk patients: a single centre experience. Eur J Vasc Endovasc Surg. Apr. 2001;21(4):334-8. [pmid: 11359334].
98 Resch T, Malina M, Lindblad B, et al. The impact of stent-graft development on outcome of AAA repair—a 7-year experience. Eur J Vasc Endovasc Surg. Jul. 2001;22(1):57-61. [pmid: 11461105].
99 Criado FJ, Wilson EP, Fairman RM, et al. Update on the Talent aortic stent-graft: a preliminary report from United States phase I and II trials. J Vasc Surg. Feb. 2001;33(2 Suppl):S146-9. [pmid: 11174826].
100 Arko FR, Filis KA, Hill BB, et al. Morphologic changes and outcome following endovascular abdominal aortic aneurysm repair as a function of aneurysm size. Arch Surg. Jun. 2003;138(6):651-5. discussion 5–6. [pmid: 12799337].
101 Ayerdi J, McLafferty RB, Markwell SJ, et al. Indications and outcomes of AneuRx Phase III trial versus use of commercial AneuRx stent graft. J Vasc Surg. Apr. 2003;37(4):739-43. [pmid: 12663971].
102 Howell MH, Zaqqa M, Villareal RP, et al. Endovascular exclusion of abdominal aortic aneurysms: initial experience with stentgrafts in cardiology practice. Tex Heart Inst J. 2000;27(2):136-45. [pmid: 10928501]. [pmcid: 101048].
103 Lee WA, Wolf YG, Hill BB, et al. The first 150 endovascular AAA repairs at a single institution: how steep is the learning curve?. J Endovasc Ther. Jun. 2002;9(3):269-76. [pmid: 12096939].
104 Shames ML, Sanchez LA, Rubin BG, et al. Delayed complications after endovascular AAA repair in women. J Endovasc Ther. Feb. 2003;10(1):10-5. [pmid: 12751923].
105 Wolf YG, Arko FR, Hill BB, et al. Gender differences in endovascular abdominal aortic aneurysm repair with the AneuRx stent graft. J Vasc Surg. May. 2002;35(5):882-6. [pmid: 12021702].
106 Alric P, Hinchliffe RJ, MacSweeney ST, et al. The Zenith aortic stent-graft: a 5-year single-center experience. J Endovasc Ther. Dec. 2002;9(6):719-28. [pmid: 12546570].
107 Burks JA Jr, Faries PL, Gravereaux EC, et al. Endovascular repair of abdominal aortic aneurysms: stent-graft fixation across the visceral arteries. J Vasc Surg. Jan. 2002;35(1):109-13. [pmid: 11802140].
108 Carpenter JP, Anderson WN, Brewster DC, et al. Multicenter pivotal trial results of the Lifepath System for endovascular aortic aneurysm repair. J Vasc Surg. Jan. 2004;39(1):34-43. [pmid: 14718809].
109 Cartes-Zumelzu F, Lammer J, Hoelzenbein T, et al. Endovascular placement of a nitinol-ePTFE stent-graft for abdominal aortic aneurysms: initial and midterm results. J Vasc Interv Radiol. May. 2002;13(5):465-73. [pmid: 11997354].
110 Elkouri S, Gloviczki P, McKusick MA, et al. Endovascular repair of abdominal aortic aneurysms: initial experience with 100 consecutive patients. Mayo Clin Proc. Oct. 2003;78(10):1234-42. [pmid: 14531482].
111 Faries PL, Briggs VL, Rhee JY, et al. Failure of endovascular aortoaortic tube grafts: a plea for preferential use of bifurcated grafts. J Vasc Surg. May. 2002;35(5):868-73. [pmid: 12021700].
112 Gilling-Smith GL, Martin J, Sudhindran S, et al. Freedom from endoleak after endovascular aneurysm repair does not equal treatment success. Eur J Vasc Endovasc Surg. Apr. 2000;19(4):421-5. [pmid: 10801377].
113 Haulon S, Devos P, Willoteaux S, et al. Risk factors of early and late complications in patients undergoing endovascular aneurysm repair. Eur J Vasc Endovasc Surg. Feb. 2003;25(2):118-24. [pmid: 12552471].
114 May J, White GH, Waugh R, et al. Lifetable analysis of primary and assisted success following endoluminal repair of abdominal aortic aneurysms: the role of supplementary endovascular intervention in improving outcome. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):648-55. [pmid: 10873735].
115 Tutein Nolthenius RP, van Herwaarden JA, van den Berg JC, et al. Three year single centre experience with the AneuRx aortic stent graft. Eur J Vasc Endovasc Surg. Sep. 2001;22(3):257-64. [pmid: 11506520].
116 Ohki T, Veith FJ, Shaw P, et al. Increasing incidence of midterm and long-term complications after endovascular graft repair of abdominal aortic aneurysms: a note of caution based on a 9-year experience. Ann Surg. Sep. 2001;234(3):323-34. discussion 34–5. [pmid: 11524585]. [pmcid: 1422023].
117 Resch T, Malina M, Lindblad B, et al. The evolution of Z stent-based stent-grafts for endovascular aneurysm repair: a life-table analysis of 7.5-year followup. J Am Coll Surg. Jan. 2002;194(1 Suppl):S74-8. [pmid: 11800358].
118 Ricco JB, Goeau-Brissonniere O, Rodde-Dunet MH, et al. Use of abdominal aortic endovascular prostheses in France from 1999 to 2001. J Vasc Surg. Dec. 2003;38(6):1273-81. discussion 82. [pmid: 14681627].
119 Fransen GA, Desgranges P, Laheij RJ, et al. Frequency, predictive factors, and consequences of stent-graft kink following endovascular AAA repair. J Endovasc Ther. Oct. 2003;10(5):913-8. [pmid: 14656182].
120 Vallabhaneni SR, Harris PL. Lessons learnt from the EUROSTAR registry on endovascular repair of abdominal aortic aneurysm repair. Eur J Radiol. Jul. 2001;39(1):34-41. [pmid: 11439229].
121 Howell MH, Strickman N, Mortazavi A, et al. Preliminary results of endovascular abdominal aortic aneurysm exclusion with the AneuRx stent-graft. J Am Coll Cardiol. Oct. 2001;38(4):1040-6. [pmid: 11583879].
122 Lee WA, Wolf YG, Fogarty TJ, et al. Does complete aneurysm exclusion ensure long-term success after endovascular repair?. J Endovasc Ther. Dec. 2000;7(6):494-500. [pmid: 11194821].
123 Zarins CK, Bloch DA, Crabtree T, et al. Aneurysm enlargement following endovascular aneurysm repair: AneuRx clinical trial. J Vasc Surg. Jan. 2004;39(1):109-17. [pmid: 14718827].
124 Zarins CK. The US AneuRx Clinical Trial: 6-year clinical update 2002. J Vasc Surg. Apr. 2003;37(4):904-8. [pmid: 12664000].
125 Zarins CK, Wolf YG, Lee WA, et al. Will endovascular repair replace open surgery for abdominal aortic aneurysm repair?. Ann Surg. Oct. 2000;232(4):501-7. [pmid: 10998648]. [pmcid: 1421182].
126 Lifeline Registry of EVAR Publications Committee. Lifeline registry of endovascular aneurysm repair: long-term primary outcome measures. J Vasc Surg. Jul. 2005;42(1):1-10. [pmid: 16012445].
127 Thomas SM, Beard JD, Ireland M, et al. Results from the prospective registry of endovascular treatment of abdominal aortic aneurysms (RETA): mid term results to five years. Eur J Vasc Endovasc Surg. Jun. 2005;29(6):563-70. [pmid: 15878530].
128 Elkouri S, Gloviczki P, McKusick MA, et al. Perioperative complications and early outcome after endovascular and open surgical repair of abdominal aortic aneurysms. J Vasc Surg. Mar. 2004;39(3):497-505. [pmid: 14981437].
129 Jordan WD, Alcocer F, Wirthlin DJ, et al. Abdominal aortic aneurysms in “high-risk” surgical patients: comparison of open and endovascular repair. Ann Surg. May. 2003;237(5):623-9. discussion 9–30. [pmid: 12724628]. [pmcid: 1514512].
130 Garcia-Madrid C, Josa M, Riambau V, et al. Endovascular versus open surgical repair of abdominal aortic aneurysm: a comparison of early and intermediate results in patients suitable for both techniques. Eur J Vasc Endovasc Surg. Oct. 2004;28(4):365-72. [pmid: 15350557].
131 Greenberg RK, Chuter TA, Sternbergh WC 3rd, et al. Zenith AAA endovascular graft: intermediate-term results of the US multicenter trial. J Vasc Surg. Jun. 2004;39(6):1209-18. [pmid: 15192559].
132 Zeebregts CJ, Geelkerken RH, van der Palen J, et al. Outcome of abdominal aortic aneurysm repair in the era of endovascular treatment. Br J Surg. May. 2004;91(5):563-8. [pmid: 15122606].
133 Matsumura JS, Brewster DC, Makaroun MS, et al. A multicenter controlled clinical trial of open versus endovascular treatment of abdominal aortic aneurysm. J Vasc Surg. Feb. 2003;37(2):262-71. [pmid: 12563194].
134 Carpenter JP, Endologix Investigators. Midterm results of the multicenter trial of the powerlink bifurcated system for endovascular aortic aneurysm repair. 40 2004;5(849–59).
135 Faries PL, Cadot H, Agarwal G, et al. Management of endoleak after endovascular aneurysm repair: cuffs, coils, and conversion. J Vasc Surg. Jun. 2003;37(6):1155-61. [pmid: 12764258].
136 Birkmeyer JD, Siewers AE, Finlayson EV, et al. Hospital volume and surgical mortality in the United States. N Engl J Med. Apr 11. 2002;346(15):1128-37. [pmid: 11948273].
137 Birkmeyer JD, Stukel TA, Siewers AE, et al. Surgeon volume and operative mortality in the United States. N Engl J Med. Nov 27. 2003;349(22):2117-27. [pmid: 14645640].
138 Dimick JB, Cowan JA Jr, Stanley JC, et al. Surgeon specialty and provider volumes are related to outcome of intact abdominal aortic aneurysm repair in the United States. J Vasc Surg. Oct. 2003;38(4):739-44. [pmid: 14560223].
139 Khuri SF, Daley J, Henderson W, et al. Relation of surgical volume to outcome in eight common operations: results from the VA National Surgical Quality Improvement Program. Ann Surg. Sep. 1999;230(3):414-29. discussion 29–32. [pmid: 10493488]. [pmcid: 1420886].
140 Dardik A, Lin JW, Gordon TA, et al. Results of elective abdominal aortic aneurysm repair in the 1990s: A population-based analysis of 2335 cases. J Vasc Surg. Dec. 1999;30(6):985-95. [pmid: 10587382].
141 Sollano JA, Gelijns AC, Moskowitz AJ, et al. Volume-outcome relationships in cardiovascular operations: New York State, 1990-1995. J Thorac Cardiovasc Surg. Mar. 1999;117(3):419-28. discussion 28–30. [pmid: 10047643].
142 Pearce WH, Parker MA, Feinglass J, et al. The importance of surgeon volume and training in outcomes for vascular surgical procedures. J Vasc Surg. May. 1999;29(5):768-76. discussion 77–78. [pmid: 10231626].
143 Jencks SF, Williams DK, Kay TL. Assessing hospital-associated deaths from discharge data. The role of length of stay and comorbidities. JAMA. Oct 21. 1988;260(15):2240-6. [pmid: 3050163].
144 Trivedi AN, Sequist TD, Ayanian JZ. Impact of hospital volume on racial disparities in cardiovascular procedure mortality. J Am Coll Cardiol. 2006;47:417-24. [pmid: 16412871].
145 EVAR trial participants. Endovascular aneurysm repair and outcome in patients unfit for open repair of abdominal aortic aneurysm (EVAR trial 2): randomised controlled trial. Lancet. Jun 25–Jul 1. 2005;365(9478):2187-92. [pmid: 15978926].
146 Peppelenbosch N, Buth J, Harris PL, et al. Diameter of abdominal aortic aneurysm and outcome of endovascular aneurysm repair: does size matter? A report from EUROSTAR. J Vasc Surg. Feb. 2004;39(2):288-97. [pmid: 14743127].
147 Anonymous. Health service costs and quality of life for early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. UK Small Aneurysm Trial Participants. Lancet Nov 21 1998;352(9141): 1656–60.
148 Schermerhorn ML, Birkmeyer JD, Gould DA, et al. Cost-effectiveness of surgery for small abdominal aortic aneurysms on the basis of data from the United Kingdom small aneurysm trial. J Vasc Surg. Feb. 2000;31(2):217-26. [pmid: 10664490].
149 Bosch JL, Kaufman JA, Beinfeld MT, et al. Abdominal aortic aneurysms: cost-effectiveness of elective endovascular and open surgical repair. Radiology. Nov. 2002;225(2):337-44. [pmid: 12409564].
150 Patel ST, Haser PB, Bush HL Jr, et al. The cost-effectiveness of endovascular repair versus open surgical repair of abdominal aortic aneurysms: A decision analysis model. J Vasc Surg. Jun. 1999;29(6):958-72. [pmid: 10359930].
151 Angle N, Dorafshar AH, Moore WS, et al. Open versus endovascular repair of abdominal aortic aneurysms: what does each really cost?. Ann Vasc Surg. Sep. 2004;18(5):612-8. [pmid: 15534745].
152 Clair DG, Gray B, O'Hara P J, et al. An evaluation of the costs to health care institutions of endovascular aortic aneurysm repair. J Vasc Surg. Jul. 2000;32(1):148-52. [pmid: 10876217].
153 Bertges DJ, Zwolak RM, Deaton DH, et al. Current hospital costs and Medicare reimbursement for endovascular abdominal aortic aneurysm repair. J Vasc Surg. Feb. 2003;37(2):272-9. [pmid: 12563195].
154 Bosch JL, Lester JS, McMahon PM, et al. Hospital costs for elective endovascular and surgical repairs of infrarenal abdominal aortic aneurysms. Radiology. Aug. 2001;220(2):492-7. [pmid: 11477259].
155 Brox AC, Filion KB, Zhang X, et al. In-hospital cost of abdominal aortic aneurysm repair in Canada and the United States. Arch Intern Med. Nov 10. 2003;163(20):2500-4. [pmid: 14609787].
156 Dryjski M, O'Brien-Irr MS, Hassett J. Hospital costs for endovascular and open repair of abdominal aortic aneurysm. J Am Coll Surg. Jul. 2003;197(1):64-70. [pmid: 12831926].
157 Hayter CL, Bradshaw SR, Allen RJ, et al. Follow-up costs increase the cost disparity between endovascular and open abdominal aortic aneurysm repair. J Vasc Surg. Nov. 2005;42(5):912-8. [pmid: 16275447].
158 Lester JS, Bosch JL, Kaufman JA, et al. Inpatient costs of routine endovascular repair of abdominal aortic aneurysm. Acad Radiol. Jul. 2001;8(7):639-46. [pmid: 11450965].
159 Prinssen M, Wixon CL, Buskens E, et al. Surveillance after endovascular aneurysm repair: diagnostics, complications, and associated costs. Ann Vasc Surg. Jul. 2004;18(4):421-7. [pmid: 15108054].
160 Gold MR, Siegel JE, Russell LB, et al., eds. Cost-effectiveness in Health and Medicine. New York: Oxford University Press; 1996.
161 Weinstein MC, Siegel JE, Gold MR, et al. Recommendations of the panel on cost-effectiveness in health and medicine. JAMA. 1996;276(15):1253-8. [pmid: 8849754].
162 Drummond MF, Sculpher M. Common methodological flaws in economic evaluations. Medical Care. 2005;43(7 Suppl):5-14. [pmid: 16056003].
163 Patel ST, Korn P, Haser PB, et al. The cost-effectiveness of repairing ruptured abdominal aortic aneurysms. J Vasc Surg. Aug. 2000;32(2):247-57. [pmid: 10917983].
164 Reed SD, Anstrom KJ, Bakhai A, et al. Conducting economic evaluations alongside multinational clinical trials: toward a research consensus. Am Heart J. Mar. 2005;149(3):434-43. [pmid: 15864231].