# Executive Summary

## Introduction

An abnormal bulging of the abdominal aorta, called an abdominal aortic aneurysm (AAA) is a potentially serious condition that can lead to death if it ruptures. An AAA is considered present when the maximum diameter of the aorta below the renal arteries (infrarenal AAA) expands to exceed 3.0 cm. In the United States, rupture of AAA accounts for approximately 9,000 deaths annually.^1^ Another 30,000–40,000 patients undergo elective surgical repair of asymptomatic AAA to prevent rupture, with perioperative mortality ranging from 2–8 percent.^2,^ ^3^ Death due to AAA rupture or repair is the thirteenth leading cause of death in the United States and tenth among older men.^4,^ ^5^

The majority of AAAs remain asymptomatic for years, though the risk of rupture increases with AAA size. Immediate death can result, and mortality remains between 40 and 60 percent, even when emergency care and repair are undertaken. Management options are primarily based on patient's life expectancy and AAA size and include no treatment, active surveillance and delayed repair, immediate open surgical repair (OSR), and endovascular aneurysm repair (EVAR).

Recent recommendations for AAA screening in high-risk populations along with emerging endovascular methods for repair have led to increased interest in evaluating the effectiveness and adverse effects of treatment options for patients with AAA.

### Objectives and Key Questions

The Minnesota Evidence-based Practice Center (EPC) was asked to answer the following questions related to elective treatment of nonruptured AAA that were nominated by America's Health Insurance Plans (AHIP).

1 What are the comparative effectiveness and adverse effects of treatment options of AAA including active surveillance, open repair, and endovascular repair?
2 What is the relationship of volume, both hospital and physician, to the benefits and harms of endovascular procedures to repair AAA?
3 How do the characteristics of the aneurysm (size/location/shape) and the patient (age/gender) affect the benefits and harms of endovascular and open-surgical repair?
4 What are the costs-benefits for each of the procedures?

## Methods

### Literature Search

For questions 1 and 3 we searched PubMed®, Cochrane Library, Food and Drug Administration (FDA), and other electronic websites from 1990 to October 2005. The following terms were included: abdominal aortic aneurysm, endovascular repair, surveillance, and surgery. Titles and abstracts of identified references were reviewed. For question 2, MEDLINE® was searched for publications about volume-outcome relationships for procedures to repair AAA published after 1990. Key words included abdominal aortic aneurysm, volume, outcome, and process assessment of health care. For question 4 we used the terms abdominal aortic aneurysm combined with economics, nursing economics, pharmaceutical economics, cost, pharmacoeconomics, cost analysis, cost allocation, cost-benefit analysis, cost control, cost savings, cost of illness, cost sharing, “deductibles and coinsurance,” medical savings accounts, health care costs, direct service costs, drug costs, employer health costs, hospital costs, health expenditures, capital expenditures, hospital economics, hospital charges, hospital costs, medical economics, or medical fees. Reference lists and contacts with content experts were used to identify additional reports.

### Study Selection Extract Data

For questions 1 and 3, studies were eligible if they were randomized controlled trials or multivariate natural history studies involving AAA, open repair, endovascular repair, or active surveillance and reported clinical outcomes. We included and updated a systematic review of EVAR vs. open repair published by the U.K. National Institute of Clinical Excellence (NICE) as well as nonrandomized U.S. trials or national registries.^6^ To assess volume-outcome relations (question 2), articles that met the following criteria were reviewed. The report had to be an original analysis of U.S. data representing repair of unruptured AAA beginning in 1990; the sample had to represent variation between hospitals or surgeons in a community or larger geographic area and present sample statistics representing the relationship between a measure of hospital or physician volume and a beneficial or harmful outcome of AAA repair; the analysis had to attempt to make adjustments for other known risk factors. For question 4, studies had to include at least 50 AAA procedures in each arm, provide data on costs, charges, or reimbursement rates, or be a cost-effectiveness analysis.

### Quality Assessment and Strength of Evidence

The methods of Schulz et al. were used to assess the quality of randomized controlled trials (RCT).^7^ We determined whether intention-to-treat analysis was utilized and whether published RCT used EVAR devices similar to those available in the United States. We evaluated whether effectiveness of interventions varied according to patient, aneurysm, or device characteristics including: age, race, gender, EVAR device manufacturer, or aneurysm size (small [<5.5 cm] vs. large aneurysm). Data from nonrandomized studies were included to assess relevance and consistency to practice in the United States. Analyses of administrative databases to examine relationships between provider volume and outcomes were evaluated by their ability to represent current practices in the United States, the reliability and validity of ‘volume’ and outcome measures, and the thoroughness of the regression analyses, including control of key risk factors. Quality of cost studies were based on whether they included relevant costs, used appropriate time frame, and evidence of effectiveness and adverse effects from randomized controlled trials.

### Data Extraction

Data regarding study, patient, and device characteristics as well as outcomes were extracted. Outcomes were described as effectiveness (initial clinical success ≤30 days or during initial hospitalization; short-term (30 days to 6 months), midterm (6 months to 5 years), and long-term >5 years) and adverse effects based on recommendations for reporting of outcomes for open and EVAR by the Society for Vascular Surgery.^8^ The primary outcome was midterm all-cause mortality. Additional outcomes included initial all-cause mortality, AAA mortality, AAA rupture, quality of life, and technical measures of EVAR and OSR success. Adverse events and complications included treatment-related mortality and morbidity such as endoleaks, graft rupture, migration, kinking, and need for additional interventions, including OSR.

For question 2 the main outcome that has been studied in relation to provider volume is short-term mortality. All published analyses used regression models of this outcome on retrospectively defined volume measures. Information was abstracted to characterize (1) the study population, (2) volume measures, (3) outcome measures, (4) regression model including covariates used for risk adjustment and handling of clustering of patients within hospitals or surgeons, and (5) adjusted and unadjusted estimates of volume effects. For question 4 we assessed charges, costs, reimbursement rates, hospital and intensive care unit length of stay, incremental cost effectiveness ratios, and quality adjusted life years.

### Data Analysis

Descriptive characteristics of patient populations were presented. For results from RCTs we calculated odds ratios (ORs) for categorical variables and weighted risk differences for continuous variables with the corresponding 95 percent confidence intervals. Because of the paucity of RCT, results from each study were evaluated and described and the corresponding statistical parameters for effect size and significance were described. We reported on tests of interaction for predefined subgroups. The preponderance of evidence for relationships between the volume of procedures performed by hospitals and physicians to repair AAA and outcomes has been obtained by secondary regression analysis of administrative databases. Methodological differences, including the definition of volume and outcomes measures, make it difficult to compare results from the different studies. Use of variables to control for pre-procedure risk (case-mix), physician training, and health care system attributes varied. Analytical methods varied as well. Therefore, we did not attempt to do a meta-analysis to combine estimates from different retrospective observational studies. The summary of studies of the volume-outcome relationship was limited to tabulation of individual study characteristics and results. Cost analysis was limited to a review of published findings and discussion of study limitations and strengths.

## Results

### Comparative Effectiveness of Treatment Options

The strongest known predictor of rupture is AAA diameter. AAA enlargement rate is not consistently independently associated with rupture rate. The annual rate of rupture for AAA <5.5 cm is 1 percent or less. Among individuals refusing or medically unfit for surgical intervention, the 1 year rupture risk may exceed 10 percent in AAA >6 cm and for AAA of >8 cm, the risk may exceed 25 percent at 6 months.

For patients with small AAA (<5.5 cm), two high-quality RCT (n=2,226), the Aneurysm Detection and Management study (ADAM)^9^ and the United Kingdom Small Aneurysm Trial (UKSAT)^10^ demonstrated that early/immediate OSR of AAA did not reduce all-cause mortality compared with active surveillance and delayed OSR. After a mean followup of approximately 5 years, the overall relative risk (RR) and hazard ratio (HR) for all-cause mortality for ADAM and UKSAT were 1.21 [95 percent confidence interval (CI) 0.95 to 1.54] and 0.94 [95 percent CI 0.75 to 1.17, p=0.56], respectively. Outcomes did not differ between treatment groups according to age, gender, or AAA diameter at baseline. After a mean followup of 8 years in the UKSAT study, no significant difference in mean survival was found between groups (6.5 years for surveillance versus 6.7 for early surgery, p=0.29) although total mortality was lower in the early/immediate OSR (adjusted HR was 0.83 [95 percent CI 0.69 to 1.00, p=0.05]). AAA related mortality was not reduced by early/immediate OSR in the ADAM study (3.3 percent vs. 3.4 percent). In the UKSAT trial, AAA-related deaths (combined ruptured AAA, secondary AAA rupture, and AAA repair deaths) accounted for 19 percent of all deaths in the surveillance group compared to 15 percent for the early OSR group at a mean followup of 8 years. Differences in quality of life measures, when they existed, were small.

Three high-quality multicenter trials compared the outcomes of EVAR with OSR of large AAA (≥5.5 cm) (n = 1,489) in patients judged medically fit for OSR.^11^–^13^ Two trials provided data at 2 years or longer (n = 1,413).^12,^ ^13^ None of the studies were conducted in the United States. All began recruitment prior to 2000 and some EVAR devices used may not be currently available in the United States EVAR reduced postoperative 30-day mortality compared to OSR (EVAR = 1.6 percent vs. OSR = 4.7 percent RR = 0.34 [95 percent CI 0.17 to 0.65]) and hospital length of stay. Reduction in all-cause mortality seen with EVAR disappeared by 2 years. There was a persistent 3 percent reduction in AAA-related mortality. Outcomes did not differ significantly by treatment for either all-cause or AAA mortality according to age, gender, aneurysm diameter, or renal function though few women were enrolled. In EVAR-1, postoperative complications, included primarily EVAR graft related ruptures, infections, endoleaks, thrombosis, or other surgery required and re-exploration of OSR. These were five times more common with EVAR as with OSR (17.6 vs. 3.3 per 100 person years). The Dutch Randomized Endovascular Aneurysm Management (DREAM) trial reported nearly identical rates of severe (systemic, local-vascular/graft complications or local nonvascular complications) adverse event-free survival in the two groups (16.9 percent [EVAR] versus 19.4 percent [OSR] at year 2). The rate of survival free of moderate or severe complications was similar at two years (65.6 percent for EVAR and 65.9 percent for OSR). In EVAR-1, reinterventions occurred three times as often in the EVAR group, exceeding 20 percent at 4 years. DREAM showed a similar pattern in the first 9 months but then reintervention rates were roughly parallel.

DREAM study data on quality of life and sexual functioning favored EVAR in the early postoperative period, but by 6 months, scores in the OSR group equaled or surpassed those in the EVAR group. In EVAR-1, physical component summary scores in the Short Form-36 (SF-36) were lower with OSR to 3 months, with no differences thereafter. There were no differences at any point in the mental component summary scores. Differences at 3 months did not achieve a level previously determined detectable by patients. EVAR costs were higher than OSR.

The British EVAR-2 study was a methodologically high-quality study and the only RCT that evaluated EVAR versus no intervention for patients with large AAA (≥5.5 cm) and deemed medically unfit for OSR (n = 338). There was a 6 percent higher all-cause mortality in patients receiving EVAR compared with no intervention that did not achieve statistical significance (45 percent vs. 39 percent; HR = 1.21; [95 percent CI 0.87 to 1.69]). AAA rupture occurred in 4 percent of EVAR patients and 12 percent of individuals in the no intervention group (rupture rate in the no intervention group = 9 per 100 person years.) There was no difference in AAA related mortality (12 vs. 13 percent) (HR = 1.01 [0.55 to 1.84]), although nine ruptures and six AAA deaths occurred in the EVAR group prior to elective repair (median time from randomization to EVAR = 57 days). There were no significant differences in mortality for EVAR compared with no intervention according to age, sex, aneurysm diameter, or renal function. The 30-day EVAR mortality was higher in the sicker EVAR-2 patients than those receiving EVAR who were judged medically fit for surgery in EVAR-1 (9 percent versus 2 percent; p <0.0001). If only elective EVAR cases were considered in EVAR-2 the 30-day EVAR mortality was 7 percent. Compared to EVAR-1 patients, there was a greater need for internal iliac artery embolization, blood products, renal dialysis, and longer hospital stay.

Approximately 55 percent of individuals with large AAA screened for trial enrollment in EVAR-1 and 2 were judged to be anatomically suitable for EVAR. The most commonly used EVAR devices in these two trials were Zenith (33–59 percent of devices) and Talent (21 to 33 percent). Over 90 percent of EVAR devices used in these trials were aortobiiliac device systems commercially available in the U.K. at the time of the RCT. Aorto-aortic (tube) grafts were used in the majority of OSR. Selection for EVAR and OSR grafts was based on the discretion of the surgical team. There are no data to determine whether outcomes varied according to device type. The exact make and model of EVAR devices used is not known, and some may not be approved for use or currently available in the United States. Refinements in device, delivery systems, and provider experience may be associated with different outcomes in the United States than reported in these RCTs.

Forty-eight reports of lower methodologic quality than RCT (case series, nonrandomized controlled studies, national registries, and U.S. FDA reports) assessed clinical outcomes of EVAR. While it is not possible to make direct comparisons with RCT, most reports explicitly stated patients were candidates for OSR. Baseline patient characteristics, AAA diameter, 30 day and 2 year overall, and AAA mortality as well as EVAR conversion rates and secondary interventions for included patients were similar to those from EVAR-1 and DREAM. None of these reports assessed EVAR in patients with AAA ≥5.5 cm and considered “medically unfit for OSR” and direct comparisons cannot be made with EVAR-2. One report evaluated outcomes of EVAR and OSR in a “high surgical risk” subgroup of patients entered into any of five nonrandomized multicenter Investigational Device Exemption (IDE) studies leading to U.S. FDA approval of EVAR devices. Patients with AAA ≥5.5 cm were retrospectively categorized as “high surgical risk” based on age >60 years and having at least one cardiac, pulmonary, or renal comorbidity. Inclusion criteria for the IDE studies required that patients were candidates for OSR, though in one study patients were prospectively defined as being poor candidates for OSR or at high risk due to pathophysiologic conditions including creatinine >2.0 mg/dL, disabling COPD, ejection fraction <25 percent, stroke with residual deficit, or myocardial infarction within the past 6 months. Three-quarters of “high-risk” patients had only one comorbid category and less than one percent had all three categories.^14^ After 4 years, deaths categorized as due to AAA were similar between EVAR and OSR patients (4.2 percent and 5.1 percent respectively (p = 0.58). Overall-survival in EVAR treated patients was 10 percent lower compared to OSR (56 percent vs. 66 percent) though this difference was not statistically significant (p = 0.23).

Patient treatment preference according to AAA size and medical fitness for surgical intervention is difficult to ascertain. How the results from published RCTs influence future patient and provider treatment preferences in the United States is not known.

### Volume Outcomes

Our search did not find any adequate published studies of the relationship between hospital or physician volume and any outcome of EVAR.

There were several historical studies of the relationship between the volume of OSR done by hospitals and physicians to repair AAA and short-term mortality. Many of these studies represented practices in the 1990s when endovascular repair procedures were being developed and later tested in randomized controlled trials. Studies of the volume-outcome relationship for OSR have not been reported since the widespread adoption of EVAR in the United States. Nevertheless, historical studies of OSR of AAA can serve to inform the design of future studies of EVAR. Studies of OSR have not determined why hospital volume appears to be related to short-term mortality. Surgeon volume and surgeon specialty may explain a large portion of the commonly observed inverse relationship between the volume of OSR done by hospitals and short-term mortality. Very low-volume hospitals often appear to have higher mortality; however, data from low-volume providers is highly variable and statistically imprecise. No previous study carefully controlled all the key risk factors that might confound these observational studies, especially the characteristics of the aneurysms that will be important in studies of EVAR. The type of endograft might be another important factor in studies of EVAR outcomes. The one study of OSR that was able to control for preoperative clinical measures did not find a significant association between hospital volume and mortality. Very low-volume hospitals often appear to have higher mortality; however, data from low-volume providers is highly variable and statistically imprecise. Thus, future studies of EVAR volume in relation to outcomes must strive to take all important covariates into account, and consider the imprecision of outcome data for low-volume providers. Two studies suggested that the volume effect for OSR was relatively consistent in subgroups of patients with different preoperative risks of death.^15,^ ^16^ However, studies of EVAR should not assume that any volume-outcome relationship will be constant across subgroups of patients. Arbitrary cutpoints for hospital volume that were associated with lower adjusted mortality ranged from 17 to 100 AAA repairs per year in studies of OSR. Investigators used a variety of measures of volume and mortality and did not attempt to analyze their data to find a threshold(s) for the volume effect. If studies of volume-outcome relationships for EVAR are going to be used by payers or policymakers to define volume thresholds for preferential referral, studies should be designed with standardized measures of volume and outcomes, and the nature of relationships between hospital and physician volume and outcomes needs to be characterized more completely.

### Costs

Case series focusing on hospital costs generally found that EVAR costs more to perform than OSR, primarily due to the cost of the prosthesis. The high cost of the EVAR prosthesis is partially offset by reduced hospital and intensive care unit length of stay, operating time, and necessity for blood transfusion relative to open surgery. More comprehensive cost analyses noted the higher follow-up costs for EVAR.

None of the Markov cost effectiveness models had accurate data on the complication and reintervention rates associated with EVAR. Although the Michaels et al. study is based on the literature published through September 2004, several case series have come out since then, and data from midterm results of RCTs were not included.^17^ Results from ongoing RCTs, comparing EVAR and OSR for large AAA and EVAR versus surveillance for small AAA conducted in the United States have not yet been published.

Data from RCTs demonstrate that for small AAA (<5.5 cm) immediate OSR costs more and does not improve survival compared to active surveillance and delayed elective intervention. For large AAA (≥5.5 cm) among patients unfit for OSR, EVAR has both greater short- and long-term costs, does not improve overall survival or quality of life beyond 1 year, and is associated with complications, need for reintervention, and long-term monitoring compared to OSR or no intervention. EVAR is associated with shorter hospital and intensive care unit length of stay, reduced AAA mortality, and lower 30-day morbidity and mortality, compared to OSR.

The cost effectiveness of EVAR relative to OSR varies by whether an institutional or societal perspective was taken. Third party payers and hospitals each formulate their own institutional perspective on costs and effectiveness that depends on the extent and duration of their responsibility for the financing and/or provision of the patient's health care needs. For third party payers such as Medicare, hospital reimbursement levels are determined by a DRG that does not vary by the type of inpatient procedure (EVAR or OSR) or the cost of the prosthesis.

## Conclusions

AAA are associated with considerable morbidity, mortality, and health-care costs. Patients with AAA <5.5 cm have an annual risk of rupture of approximately 1 percent. For AAA <5.5 cm in diameter high-quality RCT results demonstrate that active surveillance with ultrasound and delayed OSR (if AAA attains a diameter of ≥5.5 cm or the patient develops aneurysm related symptoms) results in equivalent mortality but lesser morbidity and operative costs due to fewer interventions compared to immediate OSR. There are no RCTs evaluating EVAR in these patients.

Among individuals refusing or medically unfit for OSR the 1-year rupture risk may exceed 10 percent in AAA >6 cm and for AAA of >8 cm, the risk may exceed 25 percent at 6 months. For AAA ≥5.5 cm and suitable for EVAR, high-quality RCTs have been conducted outside the United States and may have used some EVAR devices that are not approved for use in the United States. Their results demonstrate that, compared to OSR, EVAR is associated with lower perioperative morbidity and mortality and persistent reduction in AAA-defined mortality to 4 years, though the latter may be due, at least in part, to ascertainment bias for later term cause of death. EVAR did not improve longer term overall survival or health status and was associated with greater complications, need for reintervention, long-term monitoring, and costs.

For the minority of patients with AAA ≥5.5 cm and judged medically unfit for OSR, one high-quality RCT conducted in the U.K. and with EVAR devices that may not be approved for use in the United States demonstrated that EVAR did not improve survival or health status and costs more than no intervention.

There are no data adequate to estimate the effect of hospital or physician volume on EVAR outcomes and identify a volume threshold for policymakers. A volume outcome relationship for OSR has been shown for surgery prior to the introduction of EVAR, but none since.

The long-term cost effectiveness of EVAR relative to OSR is difficult to determine because there are no long term (>4 year) outcome data from RCT of EVAR versus OSR conducted in the United States using devices approved by the FDA.

## Future Research

- Results from nonrandomized trials, case-series, or FDA reports are inadequate to accurately assess the relative effectiveness and safety of treatments for AAA. The highest priority for future research to guide clinical care is to conduct long-term RCTs in the United States to assess whether RCT results of EVAR conducted in Europe apply to U.S. settings. These include EVAR vs. OSR for AAA ≥5.5 cm, EVAR versus active surveillance for AAA <5.5 cm, and EVAR versus no intervention for AAA ≥5.5 cm in patients medically unfit for OSR.
- Effective strategies are required to disseminate and implement the findings from published high-quality RCTs to patients, providers, health-care organizations, and payers.
- Additional information on the benefits and risks of treatments in women is needed.
- Refinements in EVAR devices, technique, and interventionist team are required to reduce complications and need for long-term followup.
- Consistent/validated definitions of outcomes including AAA mortality, complications, and need for reintervention are required to assist clinicians, investigators, policymakers, and patients to evaluate relative safety and effectiveness of treatment options. In particular, cause of death ascertainment beyond 30 days or the initial hospitalization is problematic. Reducing ascertainment bias likely requires rigorous adjudication of all death, including use of autopsy and/or post-mortem imaging.
- Conduct RCTs to determine whether medical therapy slows AAA enlargement or rupture.
- Improve data submission, followup, and cause of death ascertainment in registries.
- Improved medical management is needed for patients with large AAA considered as unacceptable surgical risks.
- Specific studies of EVAR are needed to characterize the hospital and physician volume-outcome relationship, if any. The validity of methods used to identify and count EVAR procedures should be examined and reported. Studies should measure volume in a consistent manner and focus on outcomes defined in reporting standards including clinical success, continuing success, complications, and return to preprocedure activity levels. Risk adjustment should include patient demographics, comorbidity, morphology of the aneurysm and access vessels, device characteristics, and any other variables that could have a substantial influence on the outcomes under investigation. Rigorously developed and tested regression models and examination of the sensitivity of results to the method of analysis would be useful. Most likely, representative prospective registries will be needed to perform a proper indepth analysis to determine whether and how the volume of endovascular procedures done by hospitals or physicians to repair AAA relate to beneficial or adverse outcomes. Ideally, future studies would strive to characterize the functional form of volume-outcome relationships and explain why they exist. The volume-mortality relationship for OSR of AAA needs to be reexamined in the EVAR era.
- Future cost analyses studies should include short- and long-term followup data, either collected prospectively on all patients or incorporated from RCTs into Markov models.
- A standardized approach to analyzing costs and effectiveness associated with the two procedures is recommended. Studies should explicitly describe the methods used to calculate costs and should include the following categories: direct medical care costs, institutional overhead costs, patient travel costs, and patients' time and/or lost earnings. The collection of these costs should be carefully itemized and described.
- Studies conducting prospective data collection in the United States taking a societal perspective are needed. Where appropriate, data on the patient's time taken off work or other activities to travel and attend medical appointments, whether on an inpatient or outpatient basis, and to obtain prescriptions are needed.
- Data on United States patient's Quality of Life (QOL), where the treatment of the QOL associated with lost earnings and death is explicitly stated, should also be collected.