# Acknowledgments

We would like to thank Andrea Cutting, Heidi O'Connor, and James Tacklind for their assistance with data extraction and table preparation; Indulus Rutks for literature search and retrieval; and Marilyn Eells for editing and formatting this report.