# Results

Question 1: What are the comparative effectiveness and adverse effects of treatment options of AAA including active surveillance, open repair, and endovascular repair?

## Natural History of AAA

Observational studies have assessed the rupture rate of AAA according to diameter and other risk factors among patients followed by surveillance. The results of seven recent studies that assessed the average rate of enlargement and risk of rupture of AAA according to initial or attained size are summarized. Studies were selected, in part, because they represent patients with AAA size or medical conditions where the decision for early intervention is controversial (e.g., small AAA (<5.5 cm) or patients with large AAA (≥5.5) but considered medically unfit for OSR). For individuals with large AAA that are considered OSR candidates, the more relevant question is not based on rupture rate in the absence of intervention but rather on the comparative effectiveness of EVAR vs. OSR. Estimates for AAA rupture or enlargement in an individual may be more variable than the average estimates obtained from these studies.

A population-based study of residents of Rochester, Minnesota, with AAA documented by ultrasound reported on enlargement rate and risk of rupture. Of 181 patients, 103 had more than one ultrasound. The diameter of the AAA increased by a median of 0.21 cm/year. The risk of rupture over 5 years was 0 percent for the 130 patients with an initial AAA <5 cm in diameter and 25 percent for the 46 patients with AAA ≥5 cm.^72^ Among variables examined, including age and sex, only the size of the AAA at initial ultrasound was associated with subsequent rupture. A 1 cm larger initial diameter was associated with an approximately 50 percent increase in the adjusted rupture risk. There was no significant association with risk of rupture in relation to the rate of change in size, though the confidence intervals were wide.

An evaluation of 166 patients with small AAA detected by screening reported an annual rupture rate of 0.7 percent for AAA of 3.0 to 4.4 cm and 1.7 percent for AAA 4.5 to 4.9 cm. ^73^ When patients who underwent elective OSR due to growth rate or attained size were included, the risk of rupture or elective OSR was 2.1 percent and 10.2 percent respectively. An additional report demonstrated that the risk of rupture was very low (2 of 256 patients per year) for AAA <5 cm, even if they grew 1.0 cm or greater per year.^74^

Three studies^9,^ ^75,^ ^76^ used results from patients recruited for RCTs of immediate OSR versus active surveillance and delayed OSR of small AAA to determine the rate of, and risk factors for, rupture of AAA under surveillance. A cohort of 2,257 adults was comprised of patients enrolled in the UKSAT and the associated study for patients ineligible or refusing randomization. After 3 years the annual rate of AAA rupture was 2.2 percent. The risk of rupture was associated with female gender, larger AAA diameter, mean blood pressure, and current smoking. Additional analyses assessed the risk of rupture and last known or estimated AAA diameter categorized as ≤3.9 cm, 4.0 to 4.9 cm, 5.0 to 5.9 cm and ≥6.0 cm. The number of ruptures per 100 patient-years increased from 0.3 for AAA <3.9 cm to 1.5 for AAA 4.0 to 4.9 cm and 6.5 for AAA 5.0 to 5.9 cm. Individuals with AAA ≥6.0 had few person-years of followup because most underwent OSR. The mean diameter preceding rupture was smaller in women (5.0 ± 0.8 cm) than men (6.0 ± 1.4 cm; p = 0.001). In the surveillance group of UKSAT, the median aneurysm growth rate was 0.33 cm per year (Inter Quartile Range of 0.20–0.53).

In the surveillance arm of the ADAM trial, the rate of rupture was 0.7 percent per year. Of these ruptures, two were incidental findings at the time of elective repair. Median rate of increase in diameter according to first and last Computed Tomography (CT) readings was 0.32 cm per year (interquartile range = 0.16 to 0.42 cm). The only significant predictor of increased rate of enlargement was a larger initial diameter and the absence of diabetes.^9^

The expansion rates and outcomes for men with very small AAA (3.0 cm to 3.9 cm) found by ultrasound scanning were assessed at five VA Medical Centers participating in the ADAM trial.^76^ More than 90 days after the initial screening 790 men had AAA meeting the eligibility diameter and had at least one repeat ultrasound scan. The average followup period was 3.9 years, mean AAA size = 3.3 cm and the median expansion rate = 0.11 cm/year. No expansion was observed in 25 percent of patients and moderate expansion (defined as >0.4 cm/year) was noted in 8.9 percent of the overall group. There were no reported AAA ruptures during the study period. However, the cause of death was available in only 43 percent of patients. Therefore, misclassification or lack of assessment could lead to underreporting of AAA rupture and death. In patients with initial AAA of 3.0 to 3.4 cm, only 23 of 578 (4 percent) had expansion to ≥5 cm and 1.2 percent had OSR. Among 212 men with an AAA of 3.5 to 3.9 cm, 14 percent had expansion to ≥5 cm and 6.6 percent had OSR.

The risk of rupture of large AAA has been poorly understood because most patients with AAA ≥5.5 cm undergo early elective repair. Three studies provided information on patients with large AAA who were considered unfit for OSR or refused OSR. In 1998 Jones reported on rupture rates in a cohort of patients with a large AAA considered unfit for OSR.^77^ The annual rupture rate was 12 percent for AAA of 5.0 to 5.9 cm and 14 percent for AAA ≥6 cm.

Lederle and colleagues reported on the rupture rate of large AAA (mean = 6.6 cm) in a cohort of 198 veterans who refused or were considered unfit for elective OSR.^36^ Outcome ascertainment was complete for all patients (almost all men) with a 46 percent autopsy rate among the 112 patients who died; 40.2 percent had a probable AAA rupture. The 1-year incidence of probable rupture by initial AAA diameter was 9.4 percent for AAA of 5.5 to 5.9 cm, 10.2 percent for AAA of 6.0 to 6.9 cm, and 32.5 percent for AAA ≥7.0 cm. Among patients who attained an AAA diameter exceeding 8.0 cm, 25.7 percent ruptured within 6 months. In multivariate analysis diameter of the AAA was the strongest predictor of rupture (RR = 1.39 per 1 cm). The median rate of change in AAA diameter was 0.43 cm per year. In multivariate models the rate of change was a nearly significant predictor of probable rupture when last measurement of AAA diameter was also included (RR per 0.1 cm per year = 1.07; 95 percent CI, 0.99–1.15).

The EVAR-2 study was a RCT comparing EVAR to no intervention in 338 patients ≥60 years of age with AAA >5.5 cm and considered medically unfit for OSR. Patients enrolled in the no intervention arm (n=172, though 27 percent underwent intervention to exclude the AAA, including 12 cases of OSR) provide information regarding rupture rates in medically unfit patients at a median followup of 2.4 years. Mean AAA diameter was 6.3 cm. Crude rupture rate in the no intervention group was 9.0 per 100 person years (95 percent CI 6.0–13.5) with a median time to rupture of 98 days. The rupture rate was lower than in the report by Lederle.^36^ Overall, 33 percent of patients died, with mortality attributed to AAA rupture occurring in 12 percent.

In summary, the strongest known predictor of rupture is initial or attained AAA diameter. The rate of enlargement has not been consistently independently associated with rupture rates. Evaluating rupture rates based on size or enlargement is complicated by the fact that many patients with larger or more rapidly enlarging AAA receive elective intervention in the absence of symptoms due to concern of rupture and subsequent poor outcomes.

The annual risk of rupture is 1 percent or lower for AAA less than 5.5 cm. These individuals are very unlikely to benefit from elective interventions even if there is low operative morbidity. The 1-year risk of rupture increases with AAA size and may exceed 10 percent in individuals with AAA >6 cm who are judged medically unfit for OSR. AAA of this diameter comprise fewer than 1 percent of AAA detected in screening programs. For AAA that attain a size of >8.0 cm, the risk may exceed 25 percent at 6 months. Based on estimates of rupture risk in the absence of intervention, the potential risks and benefits of early OSR or EVAR can be weighed.

## Elective Immediate OSR Versus Active Surveillance for Small Aneurysms (4.0 to 5.5 cm)

Two randomized trials (n=2,226), one in the United States and the other in the United Kingdom, assessed whether immediate elective OSR decreases AAA and overall mortality for patients with small AAA (4.0–5.5 cm), compared to active surveillance with OSR delayed for prespecified AAA conditions: ADAM^9^ and the UKSAT.^10^ Both studies had similar eligibility requirements and criteria for intervention in the active surveillance group. An RCT conducted in Canada was ended prematurely due to inadequate recruitment and reported no outcomes.

Two trials evaluating early EVAR compared with surveillance have begun recruitment. The Positive Impact of endo Vascular Options for Treating Aneurysms earLy (PIVOTAL), a multi-center randomized trial, is scheduled to enroll 1,700 patients with AAA 5.0 cm or less in diameter.^78^ The Comparison of surveillance versus Aortic Endografting for Small Aneurysm Repair (CAESAR) trial has a target enrollment of 740 patients with AAA between 4.1 and 5.4 cm.^79^

### Baseline Characteristics (Appendix E * * Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/aaareptp.htm , Table E1)

Baseline characteristics and a description of the study protocol are shown in Appendix E, Table E1. ADAM randomized 1,136 patients fit for elective OSR with an AAA between 4.0 to 5.4 cm in diameter out of a total of 5,038 patients screened and referred for recruitment. The majority of patients excluded had AAA outside the eligible parameters, severe comorbid conditions, or were judged to be unlikely to adhere to the study protocol. Patients were randomized to immediate OSR (n=569) or to undergo surveillance (n=567) by ultrasonography or computed tomography (CT) every 6 months. Patients in the surveillance group were followed without repair until: 1) AAA reached 5.5 cm in diameter; 2) enlargement of AAA by at least 0.7 cm in six months or 1.0 cm in 1 year; or 3) the development of symptoms attributable to the AAA by the attending vascular surgeon.

Enrolled patients were ages 50 to 79 years with a mean age of 68 and a baseline mean AAA diameter by CT scan of 4.7 cm. Comorbid conditions included hypertension (56 percent), coronary artery disease (42 percent), and diabetes (10 percent). Past or current smoking status was greater than 90 percent. Patients were overwhelmingly male and white race.

UKSAT randomized 1,090 out of 1,276 eligible patients with non-tender infrarenal AAA between 4.0 to 5.5 cm. Patients fit for elective OSR were randomly assigned to early OSR (n=563) or ultrasonographic surveillance (n=527). OSR in the surveillance group was recommended if patients met the following criteria: (1) AAA exceeded 5.5 cm in diameter; (2) enlargement of AAA >1.0 cm per year; (3) AAA became tender; or (4) iliac or thoracic repair of an aneurysm was needed. Patients had a mean age of 69 years (range 60 to 76) and a mean AAA diameter of 4.6 cm. The majority of patients were male (83 percent) and 37 percent were current smokers. Hypertension was prevalent in 38 percent, ischemic heart disease in 40 percent. Over 90 percent of patients had a history of tobacco use with 37 percent still smoking.

### Followup and Treatment

The mean duration of followup was 4.9 years for ADAM and 4.6 years for the initial report of the UKSAT. Additional analysis of the UKSAT provided results at a mean followup duration of 8 years (range 6–10). In both trials approximately 60 percent of patients randomized to active surveillance underwent OSR sometime during the trial. The vast majority of delayed OSR were because AAA achieved predetermined criteria; typically AAA size >5.5 cm. In ADAM, AAA repair was performed in 93 percent of patients in the immediate OSR group, 72 percent within 6 weeks after randomization. In the active surveillance group, 62 percent of patients in the surveillance group had undergone AAA OSR by the end of the trial, and 9 percent were performed despite the fact that participants did not meet study criteria for OSR. Rate of repair in the surveillance group increased with the size of the aneurysm at baseline. Four years after randomization, 27 percent of AAA that had measured 4.0 to 4.4 cm at baseline had OSR as compared with 81 percent of those with baseline AAA 5.0 to 5.4 cm.

In UKSAT, 92 percent assigned to early repair had undergone OSR by the end of the trial and 87 percent within 5 months of randomization. Within the surveillance group, 62 percent had undergone repair, (82 percent of all delayed OSR were done according to protocol). The median time to surgery was 2.9 years. At the 8 year mean followup period, an additional 1 percent in the early repair group and 12 percent in the surveillance group had AAA repair. Treatment between the initial and longer followup report did not necessarily adhere to protocol. Approximately one of five patients in the surveillance group (105 of 527) died without undergoing AAA repair.

## Results

### Mortality (Tables 2 and 3 on pages 42 and 43 and Appendix E *, Table E2)

All-cause mortality. Early/immediate OSR of AAA did not significantly reduce all-cause mortality compared with surveillance in either trial. After a mean followup of approximately 5 years, 27 percent of patients randomized to early OSR had died compared with 25 percent of the surveillance and delayed OSR group. Comparing immediate OSR to surveillance, the RR of death in the ADAM trial was 1.21 [95 percent CI 0.95 to 1.54] and the HR for the UKSAT was 0.94 [95 percent CI 0.75 to 1.17, p=0.56]. After a mean followup of 8 years, the adjusted hazard ratio was 0.83 [95 percent CI 0.69 to 1.00; p <0.05] with an estimated 7.1 and 8.3 deaths per 100 patient years for the early repair and surveillance groups, respectively.

Table 2 Subgroup mortality for early/immediate elective repair versus surveillance of AAA randomized controlled trials

Outcome, Trials | Early/Immediate Repair, n / N (%) | Surveillance Events, n / N (%) | Death Rate per 100 Patient-Year | Relative Risk (RR) or Hazard Ratio (HR) [95%CI]
Mortality according to baseline aneurysm diameter: Tertile Group 1 (diameter 4.0 to 4.4 cm)
ADAM,^9^ mean followup 4.9 years | 37 / 174 (21.5) | 32 / 197 (16.2) | NR | RR 1.48 [0.92 to 2.38]
UKSAT,^82^ mean followup 4.6 years | 63 / 214 (29.4) | 53 / 213 (24.9) | 7.4 ER; 6.5 S | HR 1.14 [CI NR]
UKSAT,^82^ mean followup 8 years | 91 / 214 (42.5) | 93 / 213 (43.7) | 7.1 ER; 7.4 S | HR 0.95 [CI NR]
Mortality according to baseline aneurysm diameter: Tertile Group 2 (diameter 4.5 to 4.8 cm (UKSAT) / 4.9 cm (ADAM))
ADAM,^9^ mean followup 4.9 years | 46 / 205 (22.4) | 33 / 188 (17.6) | NR | RR 1.27 [0.81 to 1.99]
UKSAT,^82^ mean followup 4.6 years | 45 / 175 (25.7) | 45 / 169 (26.6) | 6.3 ER; 6.8 S | HR 0.88 [CI NR]
UKSAT,^82^ mean followup 8 years | 73 / 175 (41.7) | 78 / 169 (46.2) | 6.7 ER; 7.9 S | HR 0.84 [CI NR]
Mortality according to baseline aneurysm diameter: Tertile Group 3 (diameter 4.9 cm (UKSAT) / 5.0 cm (ADAM) to 5.4 cm (ADAM) / 5.5 cm (UKSAT))
ADAM,^9^ mean followup 4.9 years | 60 / 190 (31.6) | 57 / 182 (31.3) | NR | HR 1.02 [0.71 to 1.47]
UKSAT,^82^ mean followup 4.6 years | 51 / 174 (29.3) | 52 / 145 (35.9) | 7.4 ER; 9.5 S | HR 0.79 [CI NR]
UKSAT,^82^ mean followup 8 years | 78/174 (44.8) | 83/145 (57.2) | 7.5 ER; 10.4 S | HR 0.70 [CI NR]
Mortality according to gender
UKSAT,^82^ Men, mean followup 8 years | 201 / 468 (42.9) | 210 / 434 (48.4) | 7.1 ER; 8.3 S | HR 0.80 [CI NR]
UKSAT,^82^ Women, mean follow up 8 years | 41 / 95 (43.1) | 44 / 93 (47.3) | 7.3 ER; 8.4 S | HR 0.99 [CI NR]
Mortality according to age subgroups, ADAM
Age 50 to 59 years, mean followup 4.9 years | 8 / 47 (17.0) | 8 / 51 (15.7) | NR | 1.02 [0.38 to 2.73]
Age 60 to 69 years, mean followup 4.9 years | 61 / 251 (24.3) | 55 / 279 (19.7) | NR | 1.34 [0.93 to 1.93]
Age 70 to 79 years, mean followup 4.9 years | 74 / 271 (27.3) | 59 / 237 (24.9) | NR | 1.10 [0.78 to 1.55]
Mortality according to age subgroups, UKSAT
Age 60 to 66 years, mean followup 8 years | 56 / 183 (30.6) | 68 / 181 (37.6) | 4.7 ER; 6.1 S | 0.72 [CI NR]
Age 67 to 71 years, mean followup 8 years | 76 / 183 (41.5) | 94 / 180 (52.2) | 6.7 ER; 9.5 S | 0.74 [CI NR]
Age 72 to 76 years, mean followup 8 years | 110 / 197 (55.8) | 92 / 166 (55.4) | 10.0 ER; 9.8 S | 1.00 [CI NR]

NR = Not reported

Table 3 All-cause and aneurysm-related mortality for early/immediate elective repair versus surveillance of AAA randomized controlled trials

Outcome, Trials, Followup Period | Early/Immediate Repair (ER) Events, n / N (%) | Surveillance Events, n / N (%) | Death Rate per 100 Patient-Year | Relative Risk (RR) or Hazard Ratio (HR) [95% CI]
All-cause mortality
ADAM,^9^ mean followup 4.9 years | 143 / 569 (25.1) | 122 / 567 (21.5) | NR | RR 1.21 [0.95 to 1.54]
UKSAT,^10^ mean followup 4.6 years | 159 / 563 (28.2) | 150 / 527 (28.5) | 7.0 ER; 7.4 S | HR 0.94 [0.75 to 1.17]
UKSAT,^82^ mean followup 8 years | 242 / 563 (43.0) | 254 / 527 (48.2) | 7.1 ER; 8.3 S | HR 0.83 [0.69 to 1.00]
Aneurysm-related mortality, ADAM
AAA-related | 19 / 569 (3.3) | 19 / 567 (3.4) | NR | NR
Thoracic aneurysm-related | 2 / 569 (<1) | 0
Aneurysm-related mortality, UKSAT (combined ruptured AAA, secondary AAA rupture, and AAA repair considered underlying cause of death occurring within 14 days after AAA surgery)
Mean follow up 8 years | 37 / 242 deaths (15.3) | 49 / 254 deaths (19.3) | NR | NR
Mortality according to time period, UKSAT
Months 0 to 6 | 31 / 563 (5.5) | 12 / 527 (2.3) | 11.4 ER; 4.6 S | HR 2.52 [1.20 to 5.33]
Months >6, mean follow up 8 years | 211 / 532 (39.7) | 242 / 515 (47.0) | 6.4 ER; 7.8 S | HR 0.77 [0.63 to 0.93]

* Repair considered underlying cause of death

NR = Not reported

In UKSAT (but not ADAM) mortality within the first 6 months of randomization was significantly higher in the early repair group compared with patients in the surveillance group (HR of 2.52 [95 percent CI 1.20 to 5.33] and absolute risk difference of 3 percent) (Appendix E *, Table E2). The 30-day mortality rate was approximately 6 percent for patients who underwent elective OSR and did not vary by time of repair. After 3 years, mortality was higher in the surveillance group in UKSAT but not ADAM. At the 8 year followup period, the mean duration of survival in the early OSR group was 6.7 years compared to 6.5 years for the surveillance group. Despite a mortality of 2.7 percent within 30 days of surgery or during hospitalization, the immediate OSR group of ADAM had lower cumulative survival compared to the surveillance and delayed OSR throughout the followup period. Independent predictors of death included higher serum creatinine level, lower weight, diagnosis of Chronic Obstructive Pulmonary Disease (COPD) or diabetes, larger AAA diameter, lower forced expiratory volume in one second, and nonuse of a beta-blocker.

Aneurysm-related mortality and rupture. (Table 2 on page 42) Aneurysm-related mortality was not reduced by early/immediate repair in the ADAM study (3.3 percent vs. 3.4 percent) but as defined differently in UKSAT was lower in the long-term followup report (7.5 percent vs. 11.4 percent.

In ADAM, 0.4 percent in the immediate OSR group and 1.9 percent in the surveillance group had AAA rupture. UKSAT assessed AAA rupture and death from OSR. The latter was defined as occurring within 14 days of OSR. The total rupture rate was 1.6 percent per year in the first 5 years of followup and 3.2 percent per year in the subsequent 3 years. Four percent of patients (8 percent of all deaths) in the surveillance group study died due to ruptured AAA compared to 1.8 percent (4 percent of all deaths) in the early OSR group after 8 years of followup.

Aneurysm related mortality in UKSAT, defined as deaths due to ruptured AAA, secondary AAA rupture, or AAA repair accounted for 19.3 percent vs. 15.3 percent of all deaths in the surveillance and early OSR groups respectively. Death associated with aneurysm-related disorders following OSR occurred in 19 patients, 15 in the surveillance group compared to four in the early repair group (p <0.001). Of these 19 deaths, three resulted from secondary AAA rupture, four from aortoduodenal fistula, and 12 from a ruptured thoracic aortic aneurysm. The risk of rupture was four times as high among women as among men. Additionally, fatal ruptures were more common in women than men; resulting in 14 percent of deaths for women versus 5 percent of deaths for men (p = 0.001). However, deaths for women from any cause were similar in the two treatment groups (8.4 percent versus 7.3 percent respectively; p = 0.99).

All-cause mortality according to diameter of aneurysm, age, gender, and smoking status. (Table 3 on page 43) Both trials reported no benefit from early OSR of AAA <5.5 cm in diameter or in any subgroup of patients defined by aneurysm diameter at entry. In UKSAT the reported test of interaction was not significant (p = 0.28) across AAA size or age (p = 0.18) or gender (p = 0.40). Calculated risk differences, reported relative risks and tests for interaction from ADAM were not significant and had point estimates favoring surveillance. In UKSAT, the overall death rate for patients who continued to smoke was 12.0 per 100 patient-years compared to 3.8 per 100 patient-years for patients who no longer smoked. However, these results were not reported according to randomized treatment assignment.

Operative and in-hospital mortality. The age and sex adjusted 30-day and in-hospital operative mortality did not differ in either the UKSAT or ADAM trial between patients receiving immediate OSR or those initially managed with surveillance but receiving delayed OSR. In UKSAT the 30 day operative mortality was 5.8 percent in the early repair group versus 7.1 percent in the group initially managed with surveillance (p = 0.30). In-hospital mortality was 5.8 percent and 7.2 percent respectively. Direct comparisons of these percents should be done cautiously because of differences between groups at the time of surgery in terms of age, aneurysm size, and number of tender or ruptured AAA at the time of OSR. In the ADAM study both the 30-day and in-hospital mortality were below 3 percent in the immediate OSR group and the surveillance group. Thus the finding in ADAM of no survival benefit with early OSR was found despite a low total operate mortality in the immediate repair group.

### Complications of OSR (Appendix E *, Table E3)

AAA-related hospitalizations (besides those for the elective OSR) occurred more than twice as often for patients undergoing immediate OSR (44.8 percent) versus those randomized to surveillance (22.7 percent). Major complications of OSR with no operative death of unruptured AAA occurred in 4.5 percent of immediate repair patients and 7.6 percent of patients in surveillance who underwent delayed OSR. More than 50 percent of patients in either group who underwent OSR experienced “any complication.” Rehospitalizations for complications were slightly higher for early OSR versus surveillance (20.5 percent versus 16.5 percent). Late graft failure occurred in less than 0.5 percent of patients in either arm.

### Rupture and Enlargement of Small Aneurysms in Patients Kept Under Ultrasound Surveillance

After nearly 5 years of followup, there were 25 and 14 total ruptures in UKSAT and ADAM, respectively. In ADAM, there were 12 ruptures in the surveillance group, resulting in eight deaths, yielding a rupture rate of 0.7 percent per year of followup of unrepaired aneurysms. The mean risk of rupture in the UKSAT study was 1.0 percent per year. The rate of aneurysm enlargement was 0.32 cm (interquartile range (IQR) 0.16 to 0.42) and 0.33 cm (IQR 0.20 to 0.53) per year for the ADAM and UKSAT surveillance groups, respectively. After 8 years of followup, UKSAT assessed total rupture rates (including AAA ≥5.5 cm and non-fatal ruptures) for two time periods. The total rupture up to the end of the trial was 1.6 percent per year and during the final 3 years of followup the rate was 3.2 percent per year (p = 0.008).

UKSAT investigators assessed risk factors associated with AAA rupture in 2,257 patients enrolled in the UKSAT or an associated study who were kept under ultrasound surveillance (data not shown in tables).^75^ In addition to UKSAT participants, eligible patients analyzed had aortic diameter <4.0 cm (n=507), or ≥5.5 cm (n=100), refused randomization (n=122), were considered unfit for surgery (n=340), or other reasons (n=98). Ninety-eight percent of patients had initial aneurysm diameters between 3–6 cm. Three-quarters of the ruptures occurred in patients with AAA ≥5 cm in diameter. After 3 years of followup, the annual rate of AAA rupture was 2.2 percent (95 percent CI = 1.7 to 2.8). The risk of rupture was associated with female sex, larger initial aneurysm diameter, current smoking, and higher mean blood pressure. Women had a threefold higher risk of aneurysm rupture than men. Crude rupture rate in women was 4.6 per 100 person years vs. 2.0 per 1,000 person years in men.

### Quality of Life (Appendix E *, Figures E1–E3 and Appendix E, Table E4)

Any differences in quality of life between treatment groups were small. ADAM utilized the Short Form-36 (SF-36) health status questionnaire in addition to measuring impotence and maximal activity level. The SF-36 scores for the physical and mental subscales are shown in Appendix E, Figure E1. There were no significant differences in any of the subscales between the immediate OSR and surveillance group with the exception of general health. All subscales showed a significant decrease throughout the followup period regardless of treatment group. The general health score was higher (p <0.001) at individual time points from 6 months to 2 years for the immediate OSR group. There were sporadic time point comparisons in other subscales that were significant, mental health at 6 months favoring immediate OSR and physical function at 5 years and role-physical at 6.5 years favoring the surveillance group. These should be interpreted cautiously due to the large number of comparisons. The baseline value for physical functioning was determined to be an independent predictor of mortality during the study duration.

The prevalence of impotence by treatment arm over the study duration is shown in Appendix E, Figure E2. Approximately 40 percent of all patients were impotent before OSR. Following randomization, impotence increased in the immediate OSR group between 18 months to 4 years (p <0.03), with the exception of 12 months. Maximum activity level did not significantly differ between the study groups. A significant interaction between treatment and followup (p <0.02) indicated a greater decline in maximum activity level over time in the immediate repair group.

Health-related quality of life status for UKSAT was assessed by the Medical Outcomes Study short-form 20-item questionnaire. There were no significant differences between groups in the mean change in scores from baseline at 12 months after randomization with the exception in current health perceptions subscale which favored the early repair group. The weighted mean difference in the mean change of scores from baseline between early repair and surveillance was 6.70 [95 percent CI 3.45 to 9.95] (Appendix E, Table E4, Appendix E, Figure E3). Within the surveillance group, mean score changes between baseline and 12 months after randomization for physical functioning, role functioning, social functioning, and bodily pain subscales decreased. In the early OSR group only physical functioning decreased significantly, but the health perceptions subscale improved significantly.

### Large Aneurysm (≥5.5 cm) Randomized Controlled Trials

Three RCTs that enrolled patients with AAA ≥5.5 cm and considered medically fit for OSR have been completed.^11^–^13^ None were conducted in the United States. EVAR devices used may not have been approved for, or are currently in use, in the U.S. Two of the trials, British Endovascular Aneurysm Repair-1 (EVAR-1) and DREAM, recently published midterm (2–4 year) results. EVAR-1 and DREAM report on procedures performed from 1999-2003. The Cuyper's trial objective was to compare cardiac response after EVAR and OSR. Cardiac complications in both groups were assessed up to 1 month postoperatively, and no long-term outcomes were reported. Two additional trials are undergoing recruitment, the Open Versus Endovascular Repair (OVER) in the U.S. and the AnEVARysme de l'aorte abdominal: Chirurgie versus Endoprothese (ACE) project in France. OVER has a recruitment goal of 900 and ACE is planning on enrolling 600 patients. The VA OVER trial will compare procedures done from 2002 to 2007. OVER is unique in that the specific device the patient will receive if randomized to EVAR will be recorded before randomization, thus allowing for subgroup analysis by EVAR compared with randomized controls for that graft. OVER will include a cost-effectiveness analysis of U.S. utilization and costs.

### EVAR Versus OSR Patients Who Are Medically Fit for OSR

Study and patient characteristics. (Appendix E *, Table E5). Three trials comparing EVAR with OSR randomized a total of 1,489 patients^11^–^13^ In the largest of the three trials, EVAR-1, 2,068 patients were anatomically eligible for EVAR, of which 52 percent gave consent and were randomized. Reasons for exclusion included: 1) refusal of further assessment following initial screen (n=327); 2) deemed unfit for OSR after local fitness assessment and offered EVAR-2 (n=399); and 3) refusal to participate (n=260).

Eligible patients had to be candidates for either OSR or EVAR based on aneurysm size (at least 5.0 cm) and anatomy as well as surgical risk. Over 90 percent of enrollees were male with an average age of approximately 70 years. Mean AAA diameter ranged from 5.4 cm in the small study by Cuypers to 6.5 cm in EVAR-1. More than 40 percent had a history of cardiac disease, 10–16 percent had diabetes, and the majority a history of tobacco use. All studies reported analyses comparing groups by intention-to-treat. EVAR-1 reported “per protocol” results.

### Short-Term Mortality and Morbidity (Table 4 on page 44, Figure 5 on page 49, and Appendix E, Table E6)

EVAR resulted in a lower postoperative 30-day mortality compared to OSR. Pooled 30-day mortality was 1.6 percent for EVAR compared with 4.7 percent for OSR (Risk Difference [RD] = -3, 95 percent CI -5 to -1; RR = 0.34, 95 percent CI 0.17 to 0.65) (Table 4 and Figure 5). In-hospital mortality was similar, 1.9 percent for EVAR vs. 5.8 percent for OSR (RR = 0.32 [0.17 to 0.59]). Of the nine deaths within 30 days in the EVAR group reported in EVAR-1, one occurred after emergency OSR for AAA rupture and one after from rupture following elective OSR. In the OSR group, there was one death after AAA rupture and emergency repair within 30 days.

Table 4 Mortality for EVAR versus OSR of AAA randomized controlled trials

Outcome, Trials | EVAR Events, n / N (%) | OSR Events, n / N (%) | Risk Difference, % [95% CI] | Relative Risk [95% CI]
Postoperative 30-day mortality Patient denominators exclude subject deaths, refusals or postponements prior to surgery. DREAM, 6 patients not included in intention-to-treat populations (OSR - 1 death (prior to surgery), 3 refusals; EVAR - 1 death, 1 refusal). EVAR Trial 1, 35 patients not included in intention-to-treat populations (OSR - 14 deaths, 7 refusals, 2 postponed; EVAR - 1 death, 1 refusal, 1 postponed)
Cuypers^11^ | 1 / 57 (1.8) | 1 / 19 (5.3) | -4 [-14 to 7] | 0.33 [0.02 to 5.07]
DREAM^81^ | 2 / 171 (1.2) | 8 / 174 (4.6) | -3 [-7 to 0] | 0.25 [0.05 to 1.18]
EVAR-1^13^ | 9 / 531 (1.7) | 24 / 516 (4.7) | -3 [-5 to -1] | 0.36 [0.17 to 0.78]
Totals | 12 / 759 (1.6) | 33 / 709 (4.7) | -3 [-5 to -1] | 0.34 [0.17 to 0.65]
In-hospital mortality
DREAM^81^ | 2 / 171 (1.2) | 8 / 174 (4.6) | -3 [-7 to 0] | 0.25 [0.05 to 1.18]
EVAR-1^13^ | 11 / 531 (2.1) | 32 / 516 (6.2) | -4 [-7 to -2] | 0.33 [0.17 to 0.66]
Totals | 13 / 702 (1.9) | 40 / 690 (5.8) | -4 [-6 to -2] | 0.32 [0.17 to 0.59]
Mortality <30 days after primary operation, AAA procedure-related (elective)
EVAR-1^13^ | 7 / 532 (1.3) | 23 / 518 (4.2) | -3 [-5 to -1] | 0.30 [0.13 to 0.68]
Mid term (2-year) all-cause mortality
DREAM^81^ | 20 / 173 (11.6) | 18 / 178 (10.1) | 1 [-5 to 8] | 1.14 [0.63 to 2.09]
EVAR-1^13^ | 71 / 543 (13.1) | 77 / 539 (14.2) | -1 [-5 to 3] | 0.92 [0.68 to 1.24]
Totals | 91 / 716 (12.7) | 95 / 717 (13.2) | -1 [-4 to 3] | 0.96 [0.73 to 1.25]
Mid term (4-year) all-cause mortality
EVAR-1^13^ | 100 / 543 (18.4) | 109 / 539 (20.2) | -2 [-7 to 3] | 0.91 [0.71 to 1.16]
Mid term (2-year) aneurysm-related mortality
DREAM^81^ | 2 / 173 (1.2) | 8 / 178 (4.5) | -3 [-7 to 0] | 0.26 [0.06 to 1.19]
EVAR-1^13^ | 16 / 543 (2.9) | 32 / 539 (5.9) | -3 [-5 to -1] | 0.50 [0.28 to 0.89]
Totals | 18 / 716 (2.5) | 40 / 717 (5.6) | -3 [-5 to -1] | 0.45 [0.26 to 0.78]
Mid term (4-year) aneurysm-related mortality
EVAR-1^13^ | 19 / 543 (3.5) | 34 / 539 (6.3) | -3 [-5 to 0] | 0.55 [0.32 to 0.96]
Mid term (2-year) mortality after discharge
DREAM^81^ | 17 / 169 (10.1) | 9 / 166 (5.4) | 5 [-1 to 10] | 1.86 [0.85 to 4.04]
Mid term (4-year) mortality >30 days after primary operation
EVAR-1^13^ | 81 / 523 (15.5) | 71 / 493 (14.4) | 1 [-3 to 5] | 1.08 [0.80 to 1.44]

Figure 5. Endovascular Repair Versus Open Repair: 30-day Mortality

DREAM reported more severe or moderate systemic operative complications for the OSR group, 26.4 percent versus 11.7 percent for EVAR, an absolute risk reduction of 15 percent [95 percent CI -23 to -7]. A higher rate of pulmonary complications in the OSR group accounted for the majority of this difference. There were significantly more local vascular or implant related complications in the EVAR group, 16.4 percent compared with 8.6 percent for the OSR group (RR = 1.90, 95 percent CI 1.05 to 3.43). In addition, there were three conversions to OSR.

### Endoleaks and Secondary Interventions (Table 5 on pages 45–46 and Appendix E *, Table E6)

Secondary intervention occurred in 9.8 percent of the EVAR group during primary admission in EVAR-1, including ten conversions to OSR and 18 endoleak corrections. The OSR group had 5.8 percent secondary interventions during initial admission, half for re-exploration of OSR.

Table 5 Complications and endoleaks for EVAR versus OSR of AAA randomized controlled trials

Outcome, Trials | EVAR Events, n / N (%) | OSR Events, n / N (%) | Risk Difference, % [95% CI] | Relative Risk [95% CI]
Number of patients with postoperative 30-day mortality and severe complications (based on standards of the Society of Vascular Surgery/International Society for Cardiovascular Surgery)
DREAM^81^ | 8 / 171 (4.7) | 17 / 174 (9.8) | -5 [-11 to 0] | 0.48 [0.21 to 1.08]
Number of patients with postoperative 30-day mortality and moderate or severe complications
DREAM^81^ | 31 / 171 (18.1) | 41 / 174 (23.6) | -5 [-14 to 3] | 0.77 [0.51 to 1.17]
Systemic complications, moderate/severe | 20 / 171 (11.7) | 46 / 174 (26.4) | -15 [-23 to -7] | 0.44 [0.27 to 0.72]
Systemic complications, severe | 6 / 171 (3.5) | 19 / 174 (10.9) | -7 [-13 to -2] | 0.32 [0.13 to 0.79]
Vascular/implant-related complications, moderate/severe | 28 / 171 (16.4) | 15 / 174 (8.6) | 8 [1 to 15] | 1.90 [1.05 to 3.43]
Vascular/implant-related complications, severe | 7 / 171 (4.1) | 9 / 174 (5.2) | -1 [-6 to 3] | 0.79 [0.30 to 2.08]
Correction of endoleak | 2 / 171 (1.2) | 0 / 174
Arterial/graft obstruction | 11 / 171 (6.4) | 5 / 174 (2.9) | 4 [-1 to 8] | 2.24 [0.79 to 6.31]
Number of patients with a conversion to OSR
EVAR-1^13^ - Secondary intervention during 30 days or primary admission | 10 / 531 (1.9) | NA
DREAM^81^ | 3 / 171 (1.7) | NA
Number of patients with secondary interventions (during 30 days or during primary admission)
EVAR-1^13^ | 52 / 531 (9.8) | 30 / 516 (5.8) | 4 [1 to 7] | 1.68 [1.09 to 2.60]
Correction of endoleak | 18 / 531 (3.4) | 1 / 516 (<1)
Re-exploration of OSR | NA | 15 / 516 (2.9)
Number of patients with endoleaks and postoperative complications (categories with ≥5 patients): after discharge (4 years)
EVAR-1^13^ | 186 / 529* (35.1) | 44 / 519* (8.5) | 27 [22 to 31] | 4.15 [3.06 to 5.63]
Endoleak, type 1 | 27 / 529 (5.1) | NA
Endoleak, type 2 | 79 / 529 (14.9) | NA
Endoleak, type 3 | 8 / 529 (1.5) | NA
Graft rupture | 9 / 529 (1.7) | 0 / 519
Graft migration | 12 / 529 (2.3) | NA
Graft kinking or endotension | 12 / 529 (2.3) | NA
Re-exploration of OSR | NA | 16 / 519 (3.1)
Other surgery required | 13 / 529 (2.5) | 16 / 519 (3.1) | -1 [-3 to 1] | 0.80 [0.39 to 1.64]
Number of patients with reintervention: after discharge (4 years)
EVAR-1^13^ | 81 / 529* (15.3) | 36 / 519* (6.9) | 8 [5 to 12] | 2.21 [1.52 to 3.21]
Number of patients with endoleaks and postoperative complications with reintervention: after discharge (4 years)
Endoleak, type 1 | 17 / 529 (3.2) | NA
Endoleak, type 2 | 17 / 529 (3.2) | NA
Endoleak, type 3 | 4 / 529 (<1) | NA
Graft rupture | 3 / 529 (<1) | 0 / 519
Graft migration | 7 / 529 (1.3) | NA
Graft kinking or endotension | 2 / 529 (<1) | NA
Re-exploration of OSR | NA | 16 / 519 (3.1)
Other surgery required | 13 / 529 (2.5) | 16 / 519 (3.1) | -1 [-3 to 1] | 0.80 [0.39 to 1.64]

* Based on the number of successful EVARs and OSRs completed

NA = Not applicable

### Midterm Mortality and Morbidity (Table 4 on page 44, Figures 6 and 7 on pages 50 and 51, and Appendix E, Table E6)

In both EVAR-1 and DREAM, reduction in all-cause mortality seen with EVAR at 30 days had disappeared after 2 years (Table 4 and Figure 6). Pooled all-cause mortality was similar between EVAR and OSR groups, 12.7 percent versus 13.2 percent (ARR = -1. 95 percent CI -4 to 3), respectively (DREAM, EVAR-1). It is unclear whether this was just the endovascular group catching up on delayed deaths, or if late mortality will continue to increase with EVAR due to complications or failure to prevent rupture. Both studies reported some advantage for EVAR in aneurysm-related deaths at 2 years (Figure 7), but this may be because all early post-operative deaths (mostly open) are classified as aneurysm-related, whereas late aneurysm-related deaths (mostly EVAR) may be easily misclassified as something else (Table 4 and Figure 6). Overall, 2.5 percent of EVAR deaths were classified as aneurysm-related compared with 5.6 percent for the OSR control, risk reduction of 3 percent [95 percent CI -5 to -1]. The EVAR-1 trial presented results at 4 years after randomization. All-cause mortality was similar between EVAR and OSR, but aneurysm-related mortality continued to be significantly lower in the EVAR group, 3.5 percent versus 6.3 percent (ARR = -3, 95 percent CI -5 to 0). No significant interactions were reported for all-cause or AAA-related mortality with age, sex, AAA diameter, or creatinine concentration subgroups.

Figure 6. Endovascular Repair Versus Open Repair: Midterm All-Cause Mortality

Figure 7. Endovascular Repair Versus Open Repair: Aneurysm-Related Mortality

In DREAM the rate of survival free of moderate or severe complications was similar in the two groups at two years (65.6 percent [EVAR] versus 65.9 percent [OSR]). No details on specific adverse events, including graft complications were reported. No documented postoperative AAA ruptures were reported, although there was one possible but unconfirmed case.^12^

### Midterm Endoleaks and Secondary Interventions (Table 5 on pages 45–46, and Appendix E, Table E6)

At 4 years after randomization, the overall rate of complications in EVAR-1 was five times as common with EVAR compared with OSR, 17.6 vs. 3.3 per 100 person years. However, a large percentage of these complications included radiographic detected endoleaks which are often asymptomatic and do not require a reintervention. Complications occurred in 35 percent of successfully completed EVAR procedures compared to 8.4 percent of OSRs completed [absolute risk difference of 27 percent; 95 percent CI 22 to 31] (Table 5). The most frequent complications were endoleak type 2 (42 percent), endoleak type 1 (15 percent), graft migration (6 percent) and graft thrombosis (6 percent). Reinterventions occurred three times as often in the EVAR group, exceeding 20 percent at 4 years in contrast to 6 percent for the OSR group. In DREAM the rate of reintervention after EVAR was almost three times the rate after OSR during the first nine months of followup. Thereafter, reintervention rates similar (Appendix E *, Table E6). Most reinterventions reported in EVAR-1 were endovascular, primarily repairing endoleaks. In the OSR group, reexploration of OSR was the most common re-intervention (44 percent of reinterventions). Overall, 14 EVAR patients required conversion to OSR, including eight completed after initial discharge from the hospital.

### Health Related Quality of Life (Appendix E, Figures E4–E8)

The DREAM study reported on quality of life (Appendix E, Figures E4 and E5) and sexual function from the first 153 patients who underwent randomization. The preoperative scores were comparable to the general population of similar age. The physical function but not mental health scores of the SF-36 favored the EVAR group in the early postoperative period, but by six months, scores in the OSR group equaled or surpassed those in the EVAR group.^80,^ ^81^ Similar findings were reported for sexual function.

In EVAR-1, EQ5D and SF-36 physical component summary scores were lower with OSR to 3 months, with no differences after or at any point in the SF-36 mental component summary scores (Appendix E, Figures E6–E8).

### EVAR Versus No Intervention for AAA ≥5.5 cm in Patients Judged Medically Unfit for OSR (Appendix E, Table E7)

Study and patient characteristics. The EVAR-2 study is the only RCT that has evaluated EVAR versus no intervention for AAA ≥5.5 cm among individuals judged to be medically unfit for OSR (Appendix E, Table E7). This study was conducted at the same clinical centers and in parallel with EVAR-1. It enrolled 338 patients at 31 hospitals in the United Kingdom. Each center had to have performed and submitted to the RETA registry at least 20 EVAR procedures. Patients ≥60 years of age, with AAA diameter ≥5.5 cm were considered for participation in the EVAR-1 trial. If they had suitable vascular anatomy for EVAR and were judged medically unfit for major surgery as determined locally by surgeon, radiologist, anesthesiologist, and cardiologist they were offered randomization to EVAR or no intervention. In general, unacceptable surgical risk was due to severe cardiopulmonary conditions. Nearly 90 percent of enrollees were men. The mean age was 76.4 years and mean AAA diameter = 6.3 cm. Local centers could select the graft. Zenith grafts were inserted in 59 percent of patients, Talent in 21 percent, Excluder in 7 percent, and Aneurex in 6 percent. Bifurcated grafts were used in 87 percent of patients. Further description of the grafts was not provided. The mean duration of followup was 3.3 years. One subject randomized to receive EVAR declined and 47 patients randomized to no intervention received treatment with EVAR (35) or OSR (12). The stated reason (n) for repair included rupture (2); tender AAA (11), fast AAA growth (5), became fit for OSR (1), patient preference (14); unknown (14).

### Overall and AAA Related Mortality (Tables 6 and 7 on pages 47 and 48 and Appendix E *, Tables E8 and E9)

All-cause mortality was higher in patients receiving EVAR compared to no intervention though not statistically so (44.6 percent vs. 39.5 percent; HR = 1.21; [95 percent CI 0.87 to 1.69; p = 0.25]) (Table 6). Overall mortality at 4 years for both groups combined was 64 percent according to Kaplan-Meier estimates (Table 7). AAA rupture occurred in 3.9 percent EVAR patients and 12.2 percent in the no intervention group (rupture rate in the no intervention group = 9.0 per 100 person years.) AAA specific mortality was similar between groups (12 vs. 13 percent) (HR = 1.01 [0.55 to 1.84]).

Table 6 Mortality for the EVAR-2 Trial (N=338), EVAR versus no intervention (NI) of AAA

Outcome | EVAR Events, n / N (%) | NI Events, n / N (%) | Hazard Ratio [95%CI]
All-cause mortality | 74 / 166 (44.6) | 68 / 172 (39.5) | 1.21 [0.87 to 1.69]
Aneurysm-related mortality | 20 / 166 (12.0) | 22 / 172 (12.8) | 1.01 [0.55 to 1.84]
Mortality prior to operation | 14 / 166 (8.4) | 57 / 172 (33.1)
Mortality <30 days after primary operation. Of the 172 patients in the no intervention group, 125 had no intervention at followup and 47 had AAA repair (35 EVAR and 12 OSR) | 13 / 150 (8.7) | 1 / 47 (2.1)
Mortality <30 days after primary operation, AAA procedure-related (elective) | 13 / 150 9% [95%CI 5 to 15] | 1 / 47 (2.1)
Mortality >30 days after primary operation | 47 / 137 (34.3) | 10 / 46 (21.7)
Total number of patients with complications | 58 / 178 33% [95%CI 26 to 40] | NA
Type of complication
Endoleak, type 1 | 10 / 178 (5.6)
Endoleak, type 2 | 17 / 178 (9.6)
Endoleak, type 3 | 5 / 178 (2.8)
Graft rupture | 1 / 178 (<1)
Graft migration | 2 / 178 (1.1)
Graft thrombosis | 7 / 178 (3.9)
Other surgery required | 8 / 178 (4.5)
*Total number of patients with reintervention | 32 / 178* (18.0) 18% [95%CI 13 to 24]
Reason for reintervention
Endoleak, type 1 | 8 / 178 (4.5)
Endoleak, type 2 | 3 / 178 (1.7)
Endoleak, type 3 | 3 / 178 (1.7)
Graft rupture | 1 / 178 (<1)
Graft migration | 0
Graft thrombosis | 5 / 178 (2.8)
Other surgery required | 8 / 178 (4.5)

* Includes 12 patients randomized to No Intervention

NA = Not applicable

Table 7 Kaplan-Meier estimates of mortality and complications according to treatment arm for EVAR versus no intervention of AAA: EVAR-2 randomized controlled trial

Group | | Year 1 | Year 2 | Year 3 | Year 4
1. All-cause mortality (extracted from graph)
EVAR (n=166) | Proportion dying | 20% | 37% | 52% | 66%
| Number at risk | 129 | 58 | 23 | 6
No intervention (n=172) | Proportion dying | 16% | 30% | 47% | 62%
| Number at risk | 139 | 71 | 29 | 9
2. Aneurysm-related mortality (extracted from graph)
EVAR (n=166) | Proportion dying | 10% | 11% | 14% | 14%
| Number at risk | 129 | 58 | 23 | 6
No intervention (n=172) | Proportion dying | 8% | 10% | 19% | 19%
| Number at risk | 139 | 71 | 29 | 9
3. Complications(extracted from graph): (defined as graft rupture, graft infection, graft migration, endoleaks, graft thrombosis, graft stenosis, renal infarction, anastomotic aneurysm, iliac dilation, technical problem of graft insertion, other surgery required)
EVAR (n=166) | Proportion with complications | 24% | 30% | 37% | 43%
| Number at risk | 105 | 47 | 14 | 5
No Intervention (n=172) | Proportion with complications | 4% | 7% | 11% | 18%
| Number at risk | 137 | 69 | 26 | 7
4. Reinterventions (extracted from graph)
EVAR (n=166) | Proportion with reinterventions | 16% | 18% | 21% | 26%
| Number at risk | 115 | 55 | 20 | 7
No Intervention (n=172) | Proportion with reinterventions | 2% | 4% | 4% | 4%
| Number at risk | 137 | 70 | 29 | 9

30-day mortality and treatment-related complications. Mortality within 30 days of the primary procedure occurred in 8.7 percent of patients assigned to EVAR and 2.1 percent among the 47 patients in the no intervention group who subsequently underwent either EVAR or OSR (Table 6, and Appendix E, Table E8).

Among patients having a successful EVAR (including the 12 randomized to no intervention) 32.6 percent had a study defined post-intervention complication and 18 percent required reintervention (Tables 6–7 and Appendix E, Table E8). Endoleaks occurred in 18 percent of patients, and there was one graft rupture. The most common reason for reintervention was for repair of endoleaks (mostly type 1). Four-year point estimates for complications were 43 percent vs. 18 percent; EVAR vs. no intervention; for reintervention: 26 percent and 4 percent. Complications following EVAR were comparable in EVAR-1 vs. EVAR-2 patients (43 percent vs. 41 percent). However, the reintervention rate was higher in unacceptable surgical risk EVAR-2 patients (11.5 per 100 person years) compared to EVAR-1 (6.9 per 100 person years).

Health related quality of life. Baseline quality of life scores were lower in EVAR-2 participants compared to EVAR-1 enrollees. There were no differences in quality of life or health status scores between patients assigned to EVAR versus no intervention as measured by the EuroQol 5-D and SF-36 questionnaires (physical and mental components) at any time point among patients who were still alive and completed forms. (Appendix E, Table E9). The authors state that because their results demonstrate that “compared to no intervention EVAR did not show a survival benefit, had little effect on Health Related Quality of Life, was more costly, and involves a continuing need for surveillance and reintervention, they did not see a need to pursue cost-effectiveness modeling at this time (i.e., no intervention was a dominant strategy). Continued monitoring of patients for an additional 6 years is planned.”

Patient preferences. There are few data to accurately determine patient treatment preferences according to age, race, AAA size, and comorbid conditions. Determining patient preference by rates or volume of a given procedure is subject to influences by provider or industry. We looked at registries of patients screened for participation in RCTs of OSR versus surveillance and delayed OSR for AAA <5.5 cm, EVAR versus OSR for patients judged medically fit for OSR who have AAA ≥5.5 cm, and EVAR versus no intervention among individuals judged medically unfit for OSR who have AAA ≥5.5 cm. Estimating preferences by these methods is difficult because preferences are not known among patients refusing to be considered for enrollment. Additionally, in the two countries conducting EVAR trials, EVAR outside the RCT setting was limited. Patient willingness to participate in and receive EVAR may have been influenced by the opportunity to be treated with otherwise unavailable technology.

Among patients with small AAA and eligible for UKSAT randomization to early OSR or ultrasonographic surveillance, 14 percent refused randomization (reasons not stated). Among those randomized to early OSR 2.3 percent refused surgery. Among those randomized to ultrasonographic screening and delayed OSR 7.2 percent had OSR against protocol. In the ADAM study 2 percent eligible patients refused randomization. In the surveillance group, 9 percent had procedures performed despite the fact that the AAA did not meet criteria for OSR

In DREAM, one percent declined to undergo AAA repair. One patient assigned to OSR crossed over to EVAR. In EVAR-1, 24 percent eligible and offered randomization refused randomization. Stated treatment preferences among those refusing included EVAR (32 percent), OSR (60 percent), no intervention (8 percent), and unknown (2 percent).

Patients who were eligible but refused entry into EVAR-2 were evenly divided between preference for EVAR and no intervention. Eight percent assigned to no intervention subsequently received intervention due to patient preference. Only one patient assigned to EVAR refused. How RCT results will influence preferences in the U.S. is not known.

## Evidence from Nonrandomized Controlled Trials, Registries, Case Series, and Comparative Studies Evaluating EVAR

### Study and Patient Characteristics

The evidence of the effectiveness and adverse effects of EVAR from sources other than RCTs is based primarily on an update of a recently published systematic review by Drury (http://www.nice.org.uk/pdf/ip/AAA%20stent%20review%20body%20report%20for%20web.pdf.^6^ The authors included 47 studies published between 2000 and early 2004 (n=19,160, ranging from 46 to 4,613), including one RCT,^11^ nine nonrandomized controlled trials (NRCTs) in comparison to OSR,^54,^ ^83^–^90^ 16 comparative (two or more subgroups undergoing EVAR) observational studies,^56,^ ^91^–^105^ and 21 case series.^57,^ ^106^–^125^ Studies were excluded if they were case series with fewer than 50 patients, not primary studies, assessed ruptured AAA, had insufficient outcomes of interest, or more recent or relevant publications were available. We verified or corrected results from their included studies, summarized findings, updated with data from two recently published national registries, Lifeline (conducted in the U.S., n=2,664)^126^ and RETA (n=1,000)^127^ and information available on the FDA website from device-specific data. Additionally, we provide information from a post-hoc defined “high-risk subgroup” of patients enrolled in these five mutlicenter investigational device exemption clinical trials leading to FDA approval.^14^ Discussion of results from this report are provided under Key Question 3.

Studies were included if the intervention was EVAR, included adults with asymptomatic infrarenal AAA undergoing elective intervention, and assessed clinical outcomes related to efficacy/safety of EVAR. Patients with thoracic and thoraco-abdominal aneurysms and symptomatic or ruptured aneurysms were excluded. Main clinical outcomes included EVAR deployment success, primary and 30-day technical success, aneurysm rupture following successful EVAR, conversion rates (primary and secondary), and secondary interventions. Complications of EVAR were assessed by the frequency of technical problems (stent/graft complications and endoleaks) and major adverse events including 30-day mortality.

Mean ages of the study participants ranged from 65 to 76 years and mean followup times ranged from 7 to 36 months for the studies reporting these variables. AAA diameter ranged from 5 to 7 cm with a mean of 5.8 cm. The average AAA size would be classified as “large.” Over 70 percent of studies had a mean followup of at least 12 months, seven with 24 months. Mean followup was not reported in 12 studies. Nearly 90 percent of patients were men. Most had coexisting medical conditions including diabetes (14 percent), hypertension (54 percent), coronary artery disease (59 percent), tobacco use (67 percent), and chronic obstructive pulmonary disease (35 percent).

The methodological quality of included studies reported varied considerably. Reported limitations included lack of detail regarding inclusion/exclusion of study participants, description of dropouts or patients lost to followup, operator experience, and blinding of outcomes assessors. Furthermore, because these studies were not randomized trials, it is not possible to make definitive statements about the relative effectiveness or adverse effects of different endografts. Generally, statistical analyses of study outcomes were not adjusted for confounding factors. The majority of the included studies did not provide a source of funding. Funding was provided by device manufacturers (eight studies),^87,^ ^94,^ ^95,^ ^99,^ ^104,^ ^105,^ ^108,^ ^123^ and the U.S. government in one.^116^

## Results

### Mortality

30-day mortality. Fourteen case-control reports, including registries or nonrandomized but controlled trials, compared 30-day mortality of EVAR to OSR.^51,^ ^54,^ ^84^–^88,^ ^90,^ ^126,^ ^128^–^132^ There was a higher 30-day mortality in the OSR group, 3.8 percent versus 1.5 percent for EVAR (absolute risk reduction of 2 percent [95 percent CI 2 to 3] favoring EVAR). Incidence and risk reduction in mortality for EVAR were similar to results reported from RCT (Appendix E *, Table E10). The pooled 30-day mortality rate for non-device specific EVAR as reported from both case series and comparative studies was slightly higher than either the RCT or the comparative studies (2.6 percent) and ranged from 0 to 8.4 percent (Appendix E, Table E11).

All-cause and AAA-related mortality. All-cause and AAA-related deaths from reports limited to registries and device-specific studies are shown in Appendix E, Table E12. Mean followup times varied widely or were not reported, limiting interpretation of the results. In the pooled Lifeline registry comprised of device trials conducted in the U.S., 23 percent of patients had died at a mean followup of 34 months, nearly 2 percent due to AAA-defined cause.^126^ In data not shown, the overall incidence of AAA-related death was 3.0 percent (range 1.3 percent to 6.8 percent) in three studies (n=1,171) with followup periods ranging from 21 to 36 months. Non-AAA mortality was assessed in eight studies (n=1,228), including one nonRCT. In the nonRCT, using the Talent device, mortality not related to AAA following EVAR was 8.3 percent versus 4.8 percent for OSR at a mean followup of 13 months.^87^

### Early and Delayed Aneurysm Rupture (Appendix E, Table E13)

Nine studies (n=8,772) including the four clinical trials comprising Lifeline, reported incidence of early AAA rupture, defined as occurring within 30 days or less following EVAR. The rupture rate was 0.2 percent (16 events) and ranged from 0 percent to 1.6 percent. Delayed rupture, occurring after 30 days postoperatively, was reported in 18 studies (n=9,720). The percent of delayed rupture following EVAR was 0.5 percent during mean followup times ranging from 7 to 72 months. In the device-specific studies, early and late ruptures were reported only for AneuRx device, three (0.3 percent) and ten (0.84 percent), respectively.^124^

### Primary and Delayed Conversion to OSR (Appendix E, Table E14)

Primary conversion is defined as conversion to OSR immediately after a failed EVAR procedure. Primary conversion results were reported in 18 studies (n=10,832) including the four clinical trials comprising Lifeline. The overall percentage of patients converting to OSR was 2.2 percent and ranged from 0 to 10 percent. In the device-specific trials, primary conversion ranged from 0 percent for the Excluder device up to 9.7 percent for the EGS.^89,^ ^133^ In a sub-study of the AneuRx clinical trial, Shames compared EVAR outcomes between men (n=203) and women (n=42) (data not shown).^104^ Six women (14 percent) required conversion to OSR compared to one man. Two studies compared early to late experience in performing EVAR. Conversion to OSR for “early experience” was 27 percent and 8.9 percent compared to 4.5 percent and 0 percent for “late experience” in the Flora and Resch studies, respectively.^93,^ ^117^

A delayed conversion to OSR was considered to be a conversion after a successful EVAR procedure. The pooled percentage occurrence of delayed conversions from 18 studies (n=10,141) was 1.8 percent with mean followup times ranging from 7 to 72 months. In the device-specific trials, delayed conversion was reported for 38 patients receiving AneuRx (3.2 percent)^124^ Only one study had occurrences of delayed conversion greater than 5 percent.^93^

### Secondary Intervention Following EVAR (Appendix E *, Table E15)

Secondary intervention was defined by Drury as any surgical or radiological procedure following EVAR that was conducted to maintain exclusion of the aneurysm sac from the circulation or to maintain graft patency. The number and percentage of secondary interventions for 22 studies (n=10,793) are shown in Appendix E, Table E15. Overall, 15.3 percent (range 3.8 to 55.5 percent) of analyzed patients required a secondary procedure within mean followup times ranging from 6 to 72 months. In the device-specific studies, secondary interventions were undertaken for 12 and 13 percent of patients receiving Powerlink and Excluder devices after approximately 2 years, respectively.^133,^ ^134^ For patients receiving Ancure and EGS devices, 37 percent followed for 5 years required a secondary procedure.^89^

### Additional Outcomes

The Drury review assessed clinical outcomes not examined further in our report. These include: (1) deployment success; (2) primary and 30-day technical success; (3) change in aneurysm size during followup; (4) procedural blood loss; (5) length of intensive care unit (ICU) stay; and (6) length of hospital stay. The results are summarized: (http://www.nice.org.uk/pdf/ip/AAA%20stent%20review%20body%20report%20for%20web.pdf).

Successful EVAR deployment, defined as EVAR placement in the correct position without surgical intervention or OSR conversion, was reported in 13 studies (n=5,480).^56,^ ^87,^ ^89,^ ^99,^ ^102,^ ^103,^ ^106,^ ^108^–^110,^ ^114,^ ^115,^ ^120,^ ^121,^ ^125^ Deployment success rate was 97 percent. In two device-specific nonRCTs, success for Ancure/EGS and Talent was 93 percent and 99 percent, respectively.^87,^ ^89^

Primary technical success was reported in 11 studies (n=4,998).^56,^ ^87,^ ^89,^ ^92,^ ^99,^ ^102,^ ^103,^ ^108,^ ^109,^ ^112,^ ^116,^ ^120^–^122,^ ^125^ The majority of studies defined this outcome as the successful placement of the endoluminal-stent with complete exclusion of the aneurysm from the circulation.^87,^ ^92,^ ^99,^ ^109,^ ^125^

Three studies provided an alternative definition^56,^ ^103,^ ^116^ and four studies^102,^ ^108,^ ^112,^ ^120^ provided no definition. Success was verified with either angiogram upon completion or pre-discharge angiograms. Primary technical success varied widely, from 61 to 91 percent, (80 percent overall). One nonRCT (Talent) reported a success of 70 percent.^87^ Thirty-day technical success was defined as successful placement of the graft resulting in complete exclusion of the AAA, with or without prior secondary intervention. Overall success was 91 percent in eight studies (n=1,493) and ranged from 77 to 100 percent. Success for the Talent study was 86 percent.^87^

Increase in AAA size was reported in 14 studies (n=2,509)^83,^ ^87,^ ^95,^ ^96,^ ^108^–^113,^ ^121,^ ^122,^ ^124,^ ^135^ and ten (n=2,065) reported reduction in AAA^83,^ ^95,^ ^96,^ ^108,^ ^110,^ ^112,^ ^113,^ ^121,^ ^124,^ ^135^ following EVAR. Eight studies reported significant change as an increase or decrease of greater than 5 mm.^87,^ ^95,^ ^110^–^112,^ ^122,^ ^124,^ ^135^ One study defined decrease as a change over 10 mm and increase as a change over 5 mm from preoperative size.^83^ The range of increase in the included studies was 0 – 27 percent with an overall average of 7.7 percent. Approximately 44 percent of patients experienced a decrease in AAA (range 11 – 82.5 percent).

Overall procedural blood loss following EVAR was 397 ml, reported in 12 studies (n=2,594).^56,^ ^84,^ ^85,^ ^87^–^89,^ ^96,^ ^106,^ ^108,^ ^110,^ ^116,^ ^121^ Mean blood loss was less for EVAR (414 ml, range 96–783) compared to OSR (1,329 ml range 451–1,800). Mean length of ICU stay with EVAR was less than one-half of OSR (0.7 vs. 1.6 days).^11,^ ^84,^ ^86^–^89^ The mean length of hospital stay for EVAR from nine nonRCT was also less than one-half that of OSR (4.2 days vs. 9.9 days).

### Endoleaks and Complications

Safety of EVAR was assessed according to the incidence of EVAR device-related adverse events, or technical complications. Endoleaks are included in this section although they are not classified as a complication. Endoleaks, detected and classified through radiographic imaging, are often asymptomatic and do not require a reintervention. Complications included stent migrations, fractures, graft-limb thrombosis, graft stenosis, and access artery injury.

Endoleaks (Appendix E *, Tables E16–E18)

Any endoleaks. The incidence of any EVAR endoleaks is shown in (Appendix E, Table E16). Data were extracted from two registries, RETA and Lifeline with additional data from the four clinical trials comprising Lifeline. Within 30 days postoperatively, any endoleaks occurred in nearly one-quarter in the U.S. Lifeline series^126^ and 14.6 percent in the European RETA database.^127^ For the individual devices, incidences ranged from 13.9 percent AneuRx^124^ to 22.7 percent for Powerlink.^134^ The incidence was two to three fold as high (42.2 percent) at discharge for combined Ancure and EGS bifurcated devices.^89^

Type I endoleaks. Ten studies (n=2,617) reported occurrences of Type I endoleaks within 30 days following EVAR (Appendix E, Table E17). The overall incidence was 4.2 percent. In the device-specific studies this ranged from 0.9 percent (Powerlink and AneuRx) to 5.8 percent for Talent.^134^ ^87,^ ^124^ The overall incidence was 3.5 percent (range from 0–14 percent) after one year in 13 studies (n=2,544) reporting. The incidence of Type 1 endoleaks beyond 1 year was 6.7 percent (range 0 to 21.5 percent) for 18 studies reporting (n=7,848).

Type II endoleaks. Eleven studies (n=2,712) reported occurrences of Type II endoleaks within 30 days following EVAR (Appendix E, Table E18). The overall incidence was 10.5 percent with a wide range (1.4–31.2 percent). The percentage of events for the device-specific studies was 1.4 to 19.3 percent for 2 AneuRx studies ^102,^ ^124^ 11.7 percent for Excluder, ^133^ and 20 percent for Powerlink.^134^ The highest number of events occurred in the combined Ancure and EGS study,^89^ although this event was reported for bifurcated grafts only. At one year, 14.7 percent of individuals had a Type II endoleak. For the device-specific studies, the 1-year range was 5.4 percent (Talent) up to 21.8 percent (combined Ancure and EGS, bifurcated grafts only).^87,^ ^89^ After 1 year the percent of events was still 10.2 percent (range 1.0–20.8 percent; 14 studies; n=7,066).

Type III endoleaks. Type III endoleaks were infrequent. Three studies (n=1,290) reported 30 day outcomes. All 15 events occurred in the RETA registry.^127,^ ^133,^ ^134^ Overall, 4.0 percent had a Type III endoleak after 1 year (nine studies, n=6,599). The majority were from Eurostar.^119^ Of the device-specific studies, only AneuRx reported events (8 of 383, 2.1 percent).^124^

Technical complications. (Appendix E *, Table E19). The outcome “any technical complication” for the duration of postoperative hospitalization was reported by the RETA registry.^127^ There were 55 events in 976 patients (5.6 percent). Stent migration was defined as caudal displacement greater than 10 mm. Stent migration within 30 days following EVAR or up to discharge occurred in less than 1 percent of patients in the two registries, Lifeline and Eurostar providing data.^120,^ ^126^ The one year stent migration rate was less than 1 percent for three studies reporting (n=1,599). After 1 year, 4.4 percent had stent migration with a wide range in results (1.7–18.9 percent, eight studies, n=7,027). Stent migration occurred in over 6 percent of patients in the AneuRx device study.^124^

No stent fractures were reported in the 47 included studies by Drury. Stent wire fractures can occur without a full stent fracture and are typically detected by followup x-rays or CT scans. Stent-wire fractures were reported in three studies, two device-specific.^87,^ ^108,^ ^134^ Overall, 17 events in 659 patients occurred (2.6 percent). The Powerlink study reported no stent wire fractures while the Talent reported an incidence of 4.6 percent.^87,^ ^134^

Graft-limb thrombosis was reported in five studies (n=659) within 30 days following EVAR (2.4 percent, range 0.7 to 6.3 percent). Incidences for the two device-specific studies were comparable. The overall percentage was similar at 1 year, 2.5, with a range of 0 to 11 percent (11 studies, n=1,657). After 1 year, the incidence increased to 3.8 percent (range 1.9 to 6.1 percent, eight studies, n=6,602). The 1-year incidence for device-specific Powerlink and combined Ancure and EGS reports were 2.1 and 5.4 percent, respectively.^89,^ ^134^

Graft stenosis was reported by four studies. Only Eurostar provided data within 30 days (n=2,862) and greater than 1 year (n=4,613) following EVAR (0.3 percent and 1.4 percent respectively). Up to 1 year, the overall incidence of graft stenosis was 2.7 percent in three studies reporting (n=365), including one device-specific study (Powerlink), which reported three events in 192 patients.^134^ In data not shown, access artery injury was reported in seven studies (n=2,561) with an overall incidence of 4.8 percent (range 1.4–12.9 percent).^89,^ ^92,^ ^102^–^104,^ ^109,^ ^118,^ ^121^

Question 2. What is the relationship of volume, both hospital and physician, to the benefits and harms of endovascular procedures to repair of AAA?

## Results

### EVAR of AAA

The literature search did not find any qualifying studies of the association between the volume of endovascular AAA repairs done by hospitals or physicians and any beneficial or harmful outcome.

The only report from the U.S. was based on a statewide discharge database in New York that compared hospitals that did fewer than five EVAR to repair AAA to hospitals doing 30 or more.^54^ The crude in-patient mortality rates of 1.9 percent versus 0.8 percent did not differ significantly in this small sample. Investigators were not able to make adjustments for potential differences in risk due to patient, physician, or hospital characteristics.

Analysis of data in a European registry did not find a relationship between 30-day mortality in the first 11 cases versus subsequent cases treated at a medical center.^57^ Midterm outcomes were related to center experience. However, methodological issues discussed in the Background section, including use of withdrawn devices that are not used in the U.S. in earlier cases, make it difficult to determine whether these observations would apply to contemporary practice in the U.S.^58^

### OSR of AAA

Previous studies of the relationship between hospital and surgeon volume of OSRs and outcomes were reviewed to inform future studies of EVAR. Table 8 on pages 59–64 summarizes studies of relationships between the volume of OSRs of AAA and outcomes in the United States in the 1990s. Endovascular repair was primarily an investigational procedure during this time, and these findings should not be extrapolated to current practice where endovascular procedures are being used to repair a substantial select fraction of the AAA.

Table 8 Summary of studies of relationships between hospital and surgeon volume and mortality of OSR of unruptured AAA in the 1990s

Reference(s) [Period of Study] Population | Outcome | Volume | Analysis | Risk Adjustment | Volume Groups (n) | Unadjusted Mortality (%) | Adjusted Volume Effect
Birkmeyer^136^ | Death before discharge or within 30 days | Estimated average annual number of AAA repairs over 6 years | Logistic regression with patients as unit of analysis adjusted for clustering | Age, sex, race, income, year, acuity of admission, Charlson comorbidity score (19 conditions excluding the indication for surgery and complications) | Overall | 5.7
Goodney^15^ [1994-1999] | | | Goodness-of-fit: NR | | Annual hospital volume | | Odds ratio
All fee-for-service Medicare enrollees over 65 years old who were discharged from a hospital. | | | Discrimination: NR | | <17 (1900) | 7.8 | reference
Mean Age: NR | | | | | 17–30 (426) | 5.9 | 0.79 (0.73–0.86)
Male: 76% | | | | | 31–49 (257) | 5.2 | 0.70 (0.64–0.76)
| | | | | 50–79 (156) | 5.3 | 0.71 (0.65–0.78)
| | | | | >79 (80) | 4.4 | 0.58 (0.53–0.65)
| | | | | Subgroups
| | | | | Low predicted risk
| | | | | Hospital volume <17 | 5.6
| | | | | Hospital volume >79 | 3.3
| | | | | High predicted risk
| | | | | Hospital volume <17 | 12.4
| | | | | Hospital volume >79 | 7.4
Birkmeyer^137^ [1998-1999] | Death before discharge or within 30 days | Estimated average annual number of AAA repairs over 2 years | Logistic regression with patients as unit of analysis adjusted for clustering within surgeon and hospital via hierarchical mixed models; surgeon and hospital volume tested in separate and combined models | Age, sex, race, income, year, acuity of admission, Charlson comorbidity score (19 conditions excluding the indication for surgery and complications), hospital ownership, teaching status and urban location | Overall | NR
All fee-for-service Medicare enrollees over 65 years old who were discharged from a hospital. | | | Goodness-of-fit: NR | | Surgeon volume
Mean Age: NR | | | Discrimination: NR | | Low <8/year (NR) | | 6.2
Male: 77% | | | | | Med 8–17.5/year (NR) | | 4.6
| | | | | High >17.5/year (NR) | | 3.9
| | | | | Low volume surgeon | | Odds ratio
| | | | | High volume surgeon | | 1.65 (1.46–1.86)
| | | | | | | reference
| | | | | Hospital volume <27.5/yr
| | | | | Low surgeon (3279) | | 6.4
| | | | | Medium surgeon (800) | | 5.0
| | | | | High surgeon (218) | | 5.2
| | | | | Hospital volume 27.5–60.5/year
| | | | | Low surgeon (1333) | | 6.1
| | | | | Medium surgeon (642) | | 4.3
| | | | | High surgeon (282) | | 3.9
| | | | | Hospital volume >60.5/yr
| | | | | Low surgeon (795) | | 6.0
| | | | | Medium surgeon (379) | | 4.3
| | | | | High surgeon (310) | | 3.6
| | | | | Controlling for hospital volume
| | | | | Low volume surgeon | | 1.40 (1.23–1.59)
| | | | | High volume surgeon | | reference
| | | | | Hospital volume
| | | | | Low <50/year (NR) | | 5.4
| | | | | High >50/year (NR) | | 4.3
| | | | | | | Odds ratio
| | | | | Low <50/year | | 1.40 (1.23–1.59)
| | | | | High >50/year | | reference
| | | | | Controlling for surgeon volume
| | | | | Low volume hospital | | 1.17 (1.02–1.35)
| | | | | High volume hospital | | reference
Dimick^16^ [1996 & 1997] | In-hospital death | AAA repair procedures done in sample hospitals each year | Logistic regression with patients as unit of analysis not adjusted for clustering. | Age, sex, race, acuity of admission, 10 comorbid conditions (Charlson index as modified by Romano). No mention of excluding conditions that might have been complications. | Overall | 3.8
National Inpatient Sample (stratified random sample of 20% of all discharges from non federal hospitals | | | Goodness-of-fit: NR | | Hospital volume | | Odds Ratio
Mean Age: | | | Discrimination: NR | | ≤30/year (76 & 91) | 4.7 | 1.71 (1.37–2.14)
72±8.1 yrs | | | | | >30/year (431 & 445) | 3.1 | reference
Male: 79% | | | | | Subgroups
| | | | | Age <65
| | | | | Hospital ≤30/year | 2.7
| | | | | Hospital >30/year | 1.0
| | | | | Age <65 & male
| | | | | Hospital ≤30/year | 2.5
| | | | | Hospital >30/year | 0.8
| | | | | Age <65 & female
| | | | | Hospital ≤30/year | 3.9
| | | | | Hospital >30/year | 1.9
| | | | | Age >65
| | | | | Hospital ≤30/year | 5.2
| | | | | Hospital >30/year | 3.5
| | | | | Age >65 & male
| | | | | Hospital ≤30/year | 4.6
| | | | | Hospital >30/year | 3.2
| | | | | Age >65 & female
| | | | | Hospital ≤30/year | 7.1
| | | | | Hospital >30/year | 4.4
Dimick^138^ [1997] | In-hospital death | AAA repair procedures done in sample hospitals. AAA repairs done by surgeon in all hospitals in sample. | Logistic regression with patients as unit of analysis adjusted for clustering by hospital. | Age, sex, race, acuity of admission, type of procedure code (resection vs. by pass), 10 comorbid conditions (Charlson index as modified by Romano). No mention of excluding conditions that might have been complications. | Overall | 4.2
60% of National Inpatient Sample that had surgeon identifiers | | | Goodness-of-fit: OK | | Hospital volume | | Odds Ratio
Mean Age: 72±8 years | | | Discrimination: | | Low <35 | 5.5 | reference
Male: 79% | | | c-statistic 0.71 | | High ≥35 | 3.0 | 0.7 (0.49–0.98)
| | | | | Surgeon volume
| | | | | <10 | 5.6 | reference
| | | | | ≥10 | 2.5 | 0.6 (0.40–0.88)
| | | | | Surgeon specialty
| | | | | General | 5.5 | 1.76 (1.1–2.9)
| | | | | Cardiac | 4.0 | 1.47 (0.85–2.6)
| | | | | Vascular | 2.2 | reference
| | | | | Low volume hospital
| | | | | Low volume surgeon | 6.5
| | | | | High volume surgeon | 3.2
| | | | | General surgeon | 6.3
| | | | | Cardiac surgeon | 5.9
| | | | | Vascular surgeon | 2.7
| | | | | High volume hospital
| | | | | Low volume surgeon | 4.2
| | | | | High volume surgeon | 2.4
| | | | | General surgeon | 4.4
| | | | | Cardiac surgeon | 2.5
| | | | | Vascular surgeon | 1.9
Khuri^139^ [1991-1997; fiscal years that begin in October] | 30-day postoperative mortality | Annual volume per hospital derived as total number of AAA repairs done in a hospital/years hospital contributed to database | Logistic regression with patient as unit of analysis to derive expected number of deaths per hospital, and estimate expected (risk adjusted) mortality | Age, emergency procedure, American Society Anesthesia class, weight loss, albumin, white blood cell count, blood urea nitrogen plus 60 other insignificant factors | Overall | 4.7
Veterans Affairs medical centers in the prospective National Surgical Risk Study or Surgical Quality Improvement Program | | | Goodness-of-fit: NR | | Hospital volume | | O/E Ratio
Mean Age: 69±6.9 | | | C-statistic: 0.75 | | 0–3/year (26) | 8.2±17.3 | 1.75±4.9
Male: 99% | | | Mixed effects hierarchical logistic regression; level 1 regression of death on patient characteristics; level 2 regression of hospital volume on risk adjusted mortality | | 4–6/year (26) | 5.3±5.6 | 0.92±1.0
| | | | | 7–10/year (26) | 4.4±3.0 | 0.93±0.7
| | | | | 11–32/year (26) | 4.6±2.7 | 1.08±0.7
| | | | | | | p=0.65
| | | | | | | Correlation r = -0.11 between hospital O/E and volume
| | | | | | | p=0.28
| | | | | | | Regression coefficient β= -0.028 ±0.021
| | | | | | | p=0.10
Dardik^140^ [1990-1995] | In-hospital death | Total number of elective AAA repairs done by hospitals and surgeons operating in sample hospitals over 6-year period | Logistic regression presumably with patient as unit of analysis, adjustments for clustering not reported | Age, sex, race, Medicaid, hypertension, diabetes, chronic obstructive pulmonary disease, cardiac disease, renal disease, smoking history | Overall | 3.5
Discharges from nonfederal, acute care hospitals in Maryland excluding urgent and emergent admissions | | | Goodness-of-fit: NR | | Hospital volume | | Odds Ratio
Mean Age: 70±7.5 years | | | Discrimination: NR | | <50 (30) | 4.3±0.8 | 2.1 (1.04–4.27)
Male: 78% | | | | | 50–99 (9) | 4.2±0.8 | NR
| | | | | 100 or more (7) | 2.5±0.5 | reference
| | | | | Surgeon volume
| | | | | 1 (71) | 9.9±3.6 | 3.26 (1.32–8.03)
| | | | | 2–9 (83) | 4.9±1.1 | NR
| | | | | 10–49 (56) | 2.8±0.5 | reference
| | | | | 50–99 (6) | 2.9±0.9 | NR
| | | | | 100 or more (3) | 3.8±1.0 | NR
Sollano^141^ [1990-1995] | In-hospital death | Total number of nonruptured AAA repairs done in hospitals over 6-year period | Logistic regression with patients as unit of analysis not adjusted for clustering | Age, sex, race, admission acuity, transfer admission, payer, service intensity weights based on DRG cost ratings were tested | Hospital volume per 100 cases (9,847) | 5.5 | Odds Ratio
Discharges from nonfederal, acute care hospitals in New York excluding emergency repairs | | | Goodness-of-fit: OK | | Average of hospital volumes | | 0.82 (0.76–0.90)
Age: NR | | | C-statistic: 0.68 | | 15 (131) | 8.2
Male: NR | | | | | 62 (33) | 5.8
| | | | | 105 (13) | 5.5
| | | | | 171 (5) | 3.3
| | | | | 193 (3) | 4.8
| | | | | 260 (2) | 5.4
| | | | | 292 (5) | 4.7
| | | | | 334 (1) | 3.3
| | | | | 433 (1) | 2.6
Pearce^142^ [1992-1996] | In-hospital death | Annual hospital and surgeon AAA repairs done in sample hospitals | Logistics regression using logarithm of volume measures not adjusted for clustering although presumably patients were the unit of analysis | Age, sex, emergency admission, length of stay, year, hospital bed size, teaching status and ownership | Overall | 5.7 | Odds Ratio
Discharges from nonfederal, acute care hospitals in Florida | | | Goodness-of-fit: NR | | Median hospital volume/year | | 0.88* per doubling of volume
Median [IQR] | | | C-statistic: NR | | 32 [18, 46] (162)
Age: 72 [67–77] | | | | | Median surgeon volume/year | | 0.90* per doubling of volume
Male: 81% | | | | | 9 [5, 15] (609)
| | | | | Vascular certification | | 0.77* versus not certified for vascular surgery
| | | | | 18% of repairs (62)
| | | | | | | *p <0.01 (CI's NR)

NR = not reported. CI = confidence interval. RR = relative risk. O/E = observed/expected. IQR = interquartile range.

Five studies of OSR of AAA used a national sample of hospital discharges, discharges of elderly Medicare enrollees, or operations in VA medical centers.^15,^ ^16,^ ^136^–^139^ Three investigations analyzed hospital discharges in Maryland, Florida, or New York.^140^–^142^ All studies were retrospective analyses of available databases. The VA study was the only one that had prospectively collected preoperative data including clinical variables.^139^ Corresponding with the incidence of AAA, all samples were predominantly elderly males, and data for females is sparse.

Death was the primary outcome in all analyses. In-hospital death was analyzed in five of the eight reports^16,^ ^138,^ ^140^–^142^ Others included deaths within 30-days to avoid bias that can be introduced by differences in hospital length of stay.^143^ Hospital volume was analyzed in all studies. Two studies of Medicare data attempted to estimate each hospital's total volume, not just operations covered by Medicare.^15,^ ^136,^ ^137^ Volume measures reflected periods of time that varied from 1 to 6 years. Some were analyzed as average annual volume, while others reported total volume during the period of study. Half of the studies included a measure of surgeon volume. Only one examined the surgeon's specialty.^138^ All studies ignored procedures that were done prior to the period of study as well as the surgeon's experience doing other types of vascular operations.

All studies employed logistic regression models with patients as the unit of analysis. Four studies did not report adjustments for clustering of patients within hospitals (or surgeons).^16,^ ^140^–^142^ Two studies utilized hierarchical regression models with hospitals and or surgeons as random effects.^137,^ ^139^ Age and sex were used as covariates in all analyses except the VA study that was nearly 100 percent male. Race (white versus non-white) was included in six studies.^15,^ ^16,^ ^136^–^138,^ ^141,^ ^142^ Two studies did not attempt to include co-morbidities because of concerns about completeness of diagnoses listed on discharge abstracts and the inability to differentiate postoperative complications from preexisting conditions.^141,^ ^142^ Admission acuity was a covariate in all studies except one that excluded urgent and emergency admissions. Most excluded hospital transfers. Other covariates used by some, but not all, included year to control for time trends, estimated patient income or type of insurance, service intensity of DRGs, hospital length of stay, and characteristics such as bed size, ownership, being a teaching facility for physicians, and urban location. Information about aneurysm characteristics was not available for risk adjustment in any of the eight investigations. Another analysis of the data in Nationwide Inpatient Sample from 1998 to 2001 found that use of low volume hospitals (<10 AAA repairs/year) was associated with race/ethnicity, geographic region, rural setting, Medicaid, and lack of insurance and non-elective admissions.^144^ If these variables are also associated with outcomes, they need to be controlled when estimating the effects of volume. Only two studies reported how well their regression model fit the data and three reported how well their model discriminated deaths. Reported c-statistics were modest, ranging from 0.68 to 0.75.

Overall mortality in the studies ranged from 3.5 percent to 5.7 percent. Seven of eight studies reported that significantly lower adjusted mortality was associated with higher volume hospitals. Two studies suggested that the volume effect was relatively consistent in patient subgroups with different preoperative risks of death.^15,^ ^16^ Cutpoints for hospital volume that were associated with lower adjusted mortality ranged from 17 to 100 AAA OSR per year. These cutpoints were arbitrary and studies did not report analyses specifically to determine a volume threshold(s). The highest volume in the VA study that did not find an association between hospital volume and mortality was 32 procedures per year. This was the only study that prospectively collected and incorporated numerous preoperative clinical variables for risk adjustment. A summary plot of mortality versus volume from all studies was not possible given varying measures of mortality and volume and broad volume categorizations. Some studies only reported risk-adjusted results for volume analyzed as a logarithm-transformed continuous variable.

All three studies that analyzed surgeon volume reported that surgeon volume had an effect that was independent of hospital volume.^137,^ ^138,^ ^140^ One study that reported how surgeon volume altered the effect of hospital volume indicated that the addition of surgeon volume to the regression model greatly reduced, but did not eliminate, the effect of hospital volume.^137^ Surgeon volume was inversely related to mortality when surgeon specialty was taken into account in the two studies.^138,^ ^142^ These studies did not identify a volume cutpoint that could be used to identify surgeons who perform enough AAA repairs to maintain optimal outcomes.

### Summary of Results

Adequate studies of the relationship between the volume of EVAR procedures done by hospitals and physicians in the United States have not been reported to date. Most previously published studies of OSRs of AAA done by hospitals and surgeons suggest that there is an inverse relationship between volume and short-term mortality. Whether or not a similar inverse relationship exists between the volume of EVAR procedures done by hospitals or physicians and mortality or any other outcome has not been established. The poorly defined relationship between the volume of OSR and short-term mortality should not be extrapolated to EVAR. Studies specific to EVAR that address important limitations of previous volume-outcome studies discussed in the Background section are needed to guide policy.

Question 3: How do the characteristics of the aneurysm (size/location/shape) and the patient (age/gender) affect the benefits and harms of endovascular and open-surgical repair?

## Aneurysm Location and Morphology

Only elective repair for asymptomatic AAA are considered. Patients enrolled in RCT all had infrarenal AAA. There are no outcomes data based on AAA morphology or classification. The following information is provided to summarize the epidemiology of AAA enrolled in RCTs to serve as a benchmark for estimating relevance to future study design or practice.

In the small aneurysm trials of OSR versus active surveillance, patients were ineligible if they had suprarenal or juxtarenal aneurysm (defined by an anticipated need for reimplantation of a main renal artery). RCT results have not provided outcomes according to AAA morphology class (i.e., whether the aneurysm was confined to the aorta, involved the aortic bifurcation, proximal common iliac arteries, or extended into one or both of the iliac bifurcations). There are no data based on whether AAAs were considered “sacular” versus “fusiform.” DREAM provides extensive information on AAA morphology. Nearly 70 percent had cylindrical or fusiform AAA, approximately 60 percent of AAA were considered to involve the aortic bifurcation and have normal iliac arteries, and 18 percent extended into one or both iliac arteries. “Unfavorable features” of the infrarenal neck as defined by an angulation of more than 90 degrees, diameter of more than 18 mm, and a diameter of less than 6 mm or more than 50 percent stenosis was reported in about one-half, while extensive iliac calcification was reported in 70 percent.

Among patients assigned to OSR, nearly 60 percent received a conventional aortoaortic tube graft, while one-third received an aortobiliac (bifurcated graft). Among EVAR patients, more than 90 percent received aortobiiliac EVAR. Parlani evaluated patients with iliac aneurysms versus those without iliac aneurysms and noted no differences in mortality, complications, or need for reinterventions after EVAR.^96^

### Aneurysm Size (Small AAA)

Natural History: AAA initial or attained diameter is the biggest known predictor of rupture risk. AAA typically have been classified as small (<5.5 cm) or large. These classifications have been used for inclusion criteria in RCTs and clinical decision making.

The annual rupture rate for AAA <5.5 cm was less than 1 percent in patients enrolled in the active surveillance arm of ADAM and UKSAT. A cohort of 2,257 adults was comprised of patients enrolled in the UKSAT trial and the associated study for patients' ineligible or refusing randomization. After 3 years the annual rate of AAA rupture was 2.2 percent. Additional analyses assessed the risk of rupture and last known or estimated AAA diameter categorized as ≤3.9 cm, 4.0 to 4.9 cm, 5.0 to 5.9 cm, and ≥6.0 cm. The number of ruptures per 100 patient years increased from 0.3 for AAA <3.9 cm to 1.5 and 6.5 for patients with AAAs 4.0 to 4.9 cm and 5.0 to 5.9 cm respectively. A Mayo Clinic study suggested that a 1 cm larger initial diameter was associated with an approximately 50 percent increase in the adjusted rupture risk.

OSR. As noted previously (Question 1) both ADAM and UKSAT analyzed mortality according to treatment arm (early OSR versus surveillance) and age or aneurysm diameter at baseline, based on tertile groups. The adjusted hazard ratio at 8 years followup in UKSAT tended toward a greater benefit of early OSR among younger patients, men, and those with larger aneurysms. However, neither study demonstrated a significant interaction between treatment group and age baseline, AAA diameter, or gender. The reported test of interaction was not significant across AAA size (p = 0.28) or age (p = 0.18). Calculated risk differences, reported relative risks, and tests for interaction from ADAM were not significant and had point estimates favoring surveillance. In UKSAT, the overall death rate for patients who continued to smoke was 12.0 per 100 patient years compared to 3.8 per 100 patient years for patients who no longer smoked. Results were not reported according to randomized treatment assignment. Results from ADAM demonstrated that independent predictors of death among all enrollees included higher serum creatinine level, lower weight, diagnosis of COPD or diabetes, larger AAA diameter, lower forced expiratory volume in one second, and nonuse of a beta-blocker. There were few women enrolled in either trial. The test for interaction with gender was not significant in UKSAT (p = 0.40). However, fatal ruptures were nearly three times more common in women than men and the risk of AAA rupture was four times higher among women. Greater than 90 percent of enrollees were of white race, and no outcomes according to race were provided.

EVAR. Despite an RCT that reported no benefit in survival or quality of life with immediate OSR versus active surveillance in patients with AAA <5.5 cm there is a possibility that some of these patients might benefit from EVAR, especially if EVAR morbidity is very low. One study recently began recruitment to evaluate EVAR versus surveillance for small AAA. The estimated rupture rate for the surveillance group used in sample size calculations for this trial are higher than reported in the two trials of OSR versus surveillance.

### Large AAA

No intervention. The rupture rate for large AAA in patients judged fit for OSR is difficult to determine because most undergo early AAA repair. Lederle reported that the 1-year incidence of probable rupture by initial AAA diameter in those refusing or judged medically unfit for OSR. Rupture rates were 9.4 percent for AAA of 5.5 to 5.9 cm, 10.2 percent for AAA of 6.0 to 6.9 cm, and 32.5 percent for AAA ≥7.0 cm. Among patients who attained an AAA diameter exceeding 8.0 cm, 25.7 percent ruptured within 6 months.^36^ The rupture rate among the no intervention group in EVAR-2 was lower than that reported by Lederle. In EVAR-2, (mean AAA = 6.3 cm) AAA rupture occurred in 12.2 percent of individuals in the no intervention group (rupture rate in the no intervention group = 9.0 per 100 person years).

EVAR versus OSR or no intervention. Outcomes of EVAR from randomized controlled trials for large AAA were assessed relative to OSR or no intervention based on whether patients were considered medically fit for OSR. Enrolled patients were all considered candidates for EVAR. However, the proportion of patients with large AAA (i.e., ≥5.5 cm) who might be eligible for EVAR in clinical settings was estimated from the EVAR-1 and 2 trial registries as 54 percent.^13^ This is consistent with other reports from EVAR utilization patterns in the U.S. where an estimated 40–80 percent of AAA could be amenable to EVAR based on aneurysm size, morphology, and patient surgical risk characteristics.^39,^ ^40^ Data from the EVAR-2 trial suggests that approximately one-fifth of patients with large AAA who are EVAR candidates are judged medically unfit for OSR.^145^

Patient characteristics. In trials of EVAR vs. OSR over 90 percent of enrollees were male with an average age of 70 years. Almost all were white. The mean AAA diameter ranged from approximately 5.4 cm in the small study by Cuypers to 6.5 cm in EVAR-1. More than 40 percent of patients had a history of cardiac disease, 10–16 percent diabetes, and the majority were current or past smokers. No outcomes by race or these selected comorbidities were reported.

Detailed findings from RCTs of EVAR versus OSR or no intervention are described in Question 1. In the DREAM trial the perioperative survival advantage with EVAR as compared with OSR was not sustained after the first postoperative year. In the early postoperative period there was a small quality of life advantage for EVAR. At 6 months and beyond QOL was better after OSR. In the larger EVAR-1 trial, compared with OSR, EVAR offered no advantage in all-cause mortality and health related quality of life, was more expensive, and was associated with a greater number of complications and reinterventions. There was a 3 percent better AAA-related survival with EVAR, though it is possible that cause of death ascertainment was biased against later AAA related deaths in the EVAR group. There were no significant interactions for all-cause or AAA-related mortality with age, sex, aneurysm diameter, or creatinine concentration. Followup time period suggested that hazard ratios for AAA-related mortality, total mortality, complications, and need for intervention began to favor OSR after 6 months.

Patients in EVAR-2 were considered medically unfit for OSR and had large AAA (mean AAA diameter = 6.4 cm; range = 6.0–7.4).^145^ Patients were older (76 vs. 70 years) and had worse pulmonary function based on spirometry (FEV_1_: 1.6 vs. 2.1L) than patients enrolled in EVAR-1. Baseline blood pressure, serum creatinine, and cholesterol levels as well as the percent males or individuals with diabetes, smoking, or cardiac history appeared similar. The severity or duration of these comorbidities was not described in detail, but 2 year mortality in the no intervention group was greater than 60 percent. In the EVAR-2 trial, EVAR resulted in a 30-day operative mortality of 9 percent in patients unfit for OSR. EVAR did not improve overall or AAA related mortality or quality of life over no intervention and was associated with a need for continued surveillance and reinterventions at increased cost.

There were no significant interactions for the effect of EVAR with age, sex, aneurysm diameter, or creatinine concentration. The 30-day EVAR mortality was higher in the sicker EVAR-2 patients than those receiving endovascular repair who were judged fit for surgery in EVAR-1 (9 percent and versus 1.7 percent; p <0.0001). Additionally, compared to healthy EVAR-1 patients, there was a greater need for internal iliac artery embolization, blood products, renal dialysis, length of hospital stay (and a trend for overall reintervention rate).

A wide range of EVAR devices was used in these trials. Over 90 percent of EVAR procedures used commercially available aortobiiliac device systems while aorto-aortic (tube) grafts were used in the majority of OSRs. Selection for both EVAR and OSR was based on the discretion of the surgical team. The most commonly used EVAR devices were Zenith (33–59 percent of devices) and Talent (27 to 33 percent). Additional description of the devices was not provided. Prior to participating, investigators were required to submit data related to at least 20 completed EVAR procedures.

### High Surgical Risk Patients

No randomized trials of EVAR versus OSR have specifically limited recruitment to patients judged to be at high surgical risk due to age, medical comorbidities, or abdominal anatomy (e.g., horseshoe kidney, abdominal adhesions, etc.). As noted previously, patients enrolled in the EVAR and OSR trials were elderly and had numerous comorbid conditions that would result in a limited life expectancy and a relatively high surgical risk. One report enrolled 100 patients believed to be at high risk for complications from OSR and subsequently treated them with the Zenith AAA EVAR.^131^ Pathophysiologic conditions used to determine high risk status included age >80 years, creatinine >2.0 mg/dL, disabling COPD, ejection fraction <25 percent, stroke with residual deficit, medically intractable hypertension, previous renal bypass surgery, or myocardial infarction within the past 6 months. Mean baseline AAA and patient characteristics were not reported and it is not clear how many, if any, of these patients were considered “medically unfit” for OSR. Based on Kaplan-Meir plot estimates, overall survival at 1 year was 92 percent and at 2 years was 78 percent (number at risk not provided). AAA reported survival was estimated at 94 percent for both 1 and 2 year. An additional report evaluated outcomes of EVAR and OSR in a “high surgical risk” subgroup of patients entered into any of five nonrandomized multicenter IDE studies leading to FDA approval of EVAR devices.^14^ Patients with AAA ≥5.5 cm were retrospectively categorized as “high surgical risk” based on age >60 years and having at least one cardiac, pulmonary, or renal comorbidity. Inclusion, criteria for the IDE studies required that patients were candidates for OSR, though in one study patients were prospectively defined as being at high risk for OSR complications as noted above. Three-quarters of “high-risk” patients had only one comorbid category and <1 percent had all three categories. There were 14.2 percent endoleaks reported at 30 days, 17.5 percent at 1 year, and 18.9 percent at 4 years. Endograft migration occurred in 2.7 percent at 4 years. Major complications were not reported. After 4 years, deaths categorized as due to AAA were similar between EVAR and OSR patients (4.2 percent and 5.1 percent respectively (p = 0.58). Overall-survival in EVAR treated patients was 10 percent lower compared to OSR (56 percent vs. 66 percent), though this difference was not statistically significant (p = 0.23).

### Device-Specific Results from FDA Reports and Lifeline Registry (Tables 9 and 10 on pages 70–72)

Few studies provided an evaluation according to device or patient characteristics. We previously described results from nonrandomized studies of EVAR with description of device-specific results (key question 1 results from nonrandomized trials). A summary of some of these findings is also provided here with attention to reports from the United States (Tables 9 and 10). Pooled results from EVAR devices (n = 3,016) included in the published Lifeline report (Ancure, AneuRx, Excluder, and Powerlink) as well as FDA data related to the Cook-Zenith device and corresponding OSR controls (n = 414) are provided. Information from manufacture/device specific FDA reports is summarized. None represent direct comparisons from randomized trials. Patient or aneurysm factors could influence outcomes. Therefore, it is hazardous to make definitive statements regarding relative safety or effectiveness.

Table 9 LIFELINE, FDA, and RCT data for patients undergoing EVAR for AAA

| Pooled LIFELINE* and FDA Cook Zenith (n=3, 016) | SVS Outcomes Database “High Risk” (n=565) | FDA Guidant ANCURE (n=121) | FDA Medtronic ANEURX (n=416) | FDA Gore EXCLUDER (n=235) | FDA Endologix POWERLINK (n=192) | FDA Cook ZENITH (n=352**) | DREAM RCT (n=173) | EVAR 1 RCT (n=543) | EVAR 2 RCT (n=166)
Demographics/comorbidities
Mean age (range) | 73 | 75.7 ± 7.0 | 73.2 ± 7.1 | 73 (45–93) | 73 (48–91) | 73.2 ± 7.0 | 73.1 ± 7.0 | 70.7 ± 6.6 | 74.2 ± 6.8 | 76.8 ± 6.2
Mean preop AAA diameter | 5.6 | 6.4 ± 0.8 | 5.8† | 5.7† | 5.6† | 5.2† | 5.7† | 6.1 ± 0.9 | 6.5 ± 0.9 | 6.4† (6.0–7.0)
Male (%) | 89 | 89.2 | 92.6 | 89 | 87 | 88.5 | 92.6 | 93 | 91 | 85
CHD (%) | 78.6 | 69.5 | 65.3 | 11 | 62 | 45.8 | 36.8 (MI) | 40.9 | 44 | 65
HTN (%) | 64 | 66.9 | 62.8 | 64 | NR | 63.9 | 65.2 | 57.9 | SBP=148 | SBP=139
DM (%) | 12.3 | 13.8 | 12.4 | 12 | NR | 13.1 | 13.8 | 9.9 | 9 | 15
COPD (%) | 28.3 | 60.5 | 39.7 | 24 | 26 | 31.8 | 23.9 | 27.5 | FEV_1_=2.1 | FEV_1_=1.6
Smoking Hx (%) | 86.5 | 84.9 | 90.8 | 86 | 89 | 82.8 | 86.7 | 64.9 | 79 | 94
Outcomes
Mortality ≤30 days (%) | 1.6 | 2.8 crude; 2.9‡ | 4.2 | 1.7 | 1.3 | 1 | 1.1 | 1.2 | 1.7 | 8.7
Mortality 2 years (%) | 13.0 | 24.6; 26‡ | NR | NR | 12.8; 13.0‡ | NR | 8.5†† | 11.6; 10.3‡ | 13.1 | 38.0‡
AAA-related Mortality 2 years (%) | 2.0 | 3.5; 3.8‡ | NR | NR | 1.7; 2.0‡ | NR | 1.0†† | 1.2; 2.1 cumulative rate | 2.9 | 12.0‡
Mortality 4 years (%) | 19.9 | 36.1; 44.0‡ | NR | NR | 22.1; 23.0‡ | NR | NR | NR | 18.4; 26.0‡ | 44.6; 44.0‡
AAA-Mortality 4 years (%) | 2.1 | 3.7; 4.2‡ | NR | NR | 2.6 | NR | NR | NR | 3.5; 4.0‡ | 12.0; 14.0‡
Major complications/adverse events (AEs) ≤30 days (%) | NR | NR | 35.6 | NR | 13.6 Major AEs | 18.8 Serious AEs | 24.4 AEs | 11.7 systemic; 16.4 local | NR | 32.6 (58/178 patients with successful EVAR)
Major complications/AEs >30 days (%) | NR | NR | NR | NR | 46.8 at 2 years Major AEs | 34.9 at 1 year Serious AEs | 32.4 at 1 year AEs | 16.9 at 2 years | 35.2 at 4 years | 43.0‡
Primary conversion (%) | 2.3 | NR | 5.8 | 1.7 | 0 | 1.6 | 0 | 1.7 | 1.9 | 0 (unfit for OR)
Conversions ≤12 months (%) | 2.5 (75/3015) 28 post 6 months | NR | 7.4 | 1.9 | 0 10 post 24 months | 2.1 | 0.85; 2 post 12 months | NR | 14 at 4 y | NA
Secondary interventions ≤30 days (%) | 15.6 (415/2664) LIFELINE | NR | NR | NR | NR | NR | NR | Reported for 2 endoleaks | 9.8 | 18.0
Secondary interventions ≤12 months (%) | 15.4 (464 / 3015) | NR | NR | 6.7 | 6.4‡‡ | 9.9 | 10.3 | NR | NR | NR
Secondary intervention >12 months (%) | 83, 81, 73 reintervention free: 2, 4, 6 years | NR | NR | NR | 5.9‡‡: 12–24 months | NR | 3.4 | 12.5 at 2 years | 15.3 at 4 years | 26.0‡
Aneurysm rupture ≤12 months (%) | 0.17; 14 post 12 months | <1; 2 at 1 year 5 post 12 months | 0 | 0.2 | 0 | 0 | 0.28 | None (considered in 2 patients) | NR, AAA deaths only | 9 before repair
Endoleaks ≤30 days (%) | NR | 14.2 | 51.8 | 46.6 | 21.7 | 22.7 | 16.8 | 2 reintervention | 18 reintervention | 18.0
Endoleaks ≤12 months (%) | NR | 17.5 | 33 | 17.4 | 17.3 | 14.1 | 3 | NR | 21.6 at 4 years | NR

* N=2,664; Pooled clinical trial data for ANCURE, ANEURX, EXCLUDER and POWERLINK

** EVAR group comprised of Standard Risk (SR) group (n=200), High Risk group (n=100) and Roll-in group (n=52)

† Based on median of diameter ranges (Interquartile range if provided)

†† SR group only

‡ Estimated from Kaplan-Meier analysis

‡‡ For endoleak and aneurysm size increases

NR Not reported

Table 10 Summaries of LIFELINE, FDA data, and RCT data for patients undergoing OSR (or no intervention) for AAA

| Pooled LIFELINE* and FDA Cook Zenith (n=414) | SVS Outcomes Database “High Risk” (n=61) | FDA Guidant ANCURE (n=111) | FDA Medtronic ANEURX (n=66) | FDA Gore EXCLUDER (n=99) | FDA Endologix POWERLINK (n=66) | FDA Cook ZENITH (n=80) | DREAM RCT (n=174) | EVAR 1 RCT (n=539) | EVAR 2 RCT No Intervention (n=172)
Demographics/comorbidities
Mean age (range) | 69.8 | 74.2 | 71.6 ± 7.0 | 69 (49–85) | 70 (51–87) | 69.7 ± 7.9 | 69 ± 7.0 | 69.5 ± 6.8 | 74 ± 6.1 | 76 ± 6.7
Mean preop AAA diameter | 5.8 | 6.6 ± 1.0 | 5.6** | 6.0** | 6.0** | 5.9** | 6.4** | 6.0 ± 0.9 | 6.5 ± 0.9 | 6.3** (6.0–7.0)
Male gender (%) | 81 | 67.2 | 76.6 | 85 | 74 | 86.4 | 88.6 | 90.2 | 91 | 85
CHD (%) | 53.4 | 67.3 | 61.3 | 8 | 54 | 59.4 | 28.8 (MI) | 46.6 | 43 | 73
HTN (%) | 69.8 | 72.1 | 71.2 | 56 | NR | 69.7 | 83.3 | 54.0 | SBP=147 | SBP=138
DM (%) | 13 | 16.4 | 9.9 | 9 | NR | 18.2 | 15.2 | 9.8 | 12 | 13
COPD (%) | 26.6 | 70.5 | 29.7 | 36 | 25 | 24.2 | 17.9 | 17.8 | FEV_1_=2.1 | FEV_1_=1.7
Smoking Hx (%) | 87.8 | 77.1 | 90.1 | 82 | 85 | 85.7 | 95 | 54.0 | 92 | 93
Outcomes
Mortality ≤30 days (%) | 1.4 | 4.9 crude; 5.1† | 2.7 | 0 | 0 | 6.1 | 2.5 | 4.6 | 4.7 | NA
Mortality 2 years (%) | 7.8 | 13.1; 14† | NR | NR | 6.1; 7.0† | NR | NR | 10.1; 10.4† | 14.3; 16.0† | 30.0
AAA-related Mortality 2 years (%) | 1.2 at 1 year | 4.9; 5.2† | NR | NR | 2.0; 2.0† | NR | NR | 4.5; 5.7 cumulative rate | 5.9; 6.0† | 11.0†
Mortality 4 years (%) | 12.6 | 24.6; 44.0† | NR | NR | 12.1; 15.0† | NR | NR | NR | 20.2; 29† | 62.0†
AAA-related Mortality, 4 years (%) | NR | 4.9; 5.2%† | NR | NR | 2.0 | NR | NR | NR | 6.3; 7.0† | 19.0†
Major complications/adverse events (AEs) ≤30days (%) | NR | NR | 44.1 | NR | 57.0 | 34.9 Serious AEs | 42.5 AEs | 26.4 Systemic; 8.6 Local | NR | NR
Major complications/AEs >30days (%) | NR | NR | NR | NR | 66.0 | 45.5 Serious AEs | 51.0 AEs | 19.4† at 2years | 8.5; 9.0† at 4 years | 18.0† at 4 years
AAA rupture ≤12 months (%) | NR | 0 | NR | NR | 0 | NR | NR | 0 | NR | 21 total at 4 years

* Pooled trial data for ANCURE, ANEURX, EXCLUDER and POWERLINK;

** Based on median of diameter ranges;

† Estimated from Kaplan-Meier analysis

NR = Not reported

Compared to RCT enrollees, patients receiving EVAR included in these reports had smaller AAA (mean = 5.6 cm). Compared to the listed OSR controls, EVAR patients had slightly smaller AAA (5.6 vs. 5.8 cm), were older (73 vs. 70 years), more frequently male (89 vs. 81 percent), and have a history of coronary artery disease (79 versus 53 percent). Across devices there were no large differences in mean age, AAA diameter, gender, or comorbid conditions.

The number of EVAR devices submitted for FDA review ranged from 121 for Ancure to 416 for AneuRx. The pooled results as well as device-specific data obtained separately from FDA websites indicates that 30-day mortality rates with different devices ranged from 1 percent with Gore Excluder to 4.2 percent with Guidant Ancure. EVAR and OSR 30-day mortality rates were 1.6 and 1.4 percent respectively. Major complications or adverse events within 30 days were not provided in the Lifeline report but ranged from 13.6 percent in FDA reports with Gore Excluder to 35.6 percent with Guidant Ancure.

### Device-Specific Results from Published Nonrandomized Studies

The mean AAA diameter was ≥5 cm in patients included in the nonrandomized-EVAR reports, and available outcomes would be considered related to large AAA. However, three reports describe outcomes of EVAR for small versus large AAA.^94,^ ^100,^ ^146^ Arko reported no significant difference in endoleaks between small, medium, or large AAA (p = 0.41). Ouriel reported that in a cohort of 700 patients treated with EVAR, overall survival, AAA related death, conversion, and Type 1 endoleaks were worse in large (≥5.5 cm) versus small AAA. Similar results from the Eurostar registry were noted by Peppelenbosch.

In the device-specific published studies (which often included additional patients and outcomes data compared to the FDA reports), early and late ruptures were reported only for AneuRx device and were 0.3 and 0.8 percent respectively.^124^ Primary conversion ranged from 0 percent for the Excluder device up to 9.7 percent for the EGS. In a sub study of the AneuRx clinical trial, Shames compared EVAR outcomes between men (n = 203) and women (n = 42) (data not shown).^104^ Six women (14 percent) required conversion to OSR compared to one man. The incidence of delayed conversions for 18 studies (n = 10,141) was 1.8 percent with mean followup times ranging from 7 to 72 months.

In device-specific trials delayed conversion was reported for 3.2 percent of patients receiving AneuRx. Secondary interventions were undertaken for 12 percent, and 13 percent of patients receiving Powerlink and Excluder devices after approximately 2 years. For patients receiving Ancure and EGS devices, 37 percent followed for 5 years required a secondary procedure.

The incidence of any EVAR endoleaks is shown in Table 9. Data were extracted from two registries, RETA and Lifeline, with additional data from four clinical trials comprising Lifeline. Within 30 days postoperatively, the percentage of any endoleaks for the two registries was 24.7 percent for Lifeline and 14.6 percent for RETA. For the individual devices, incidences ranged from 13.9 percent AneuRx to 22.7 percent for Powerlink. Incidence was 42.2 percent at discharge for combined Ancure and EGS devices. This included only bifurcated grafts.

The overall incidence of Type I endoleaks within 30 days following EVAR was 4.2 percent and ranged from 0.9 percent to 11 percent. The percentage of events in the device-specific studies ranged from 0.9 percent (Powerlink and AneuRx) to 5.8 percent for Talent. Overall incidence of Type III endoleaks within 30 days following EVAR was 1.2 percent in three reports, including Powerlink and Excluder. Powerlink and Excluder reported no Type III endoleaks at any followup period.

There was a wide range in the percentage of Type II endoleaks within 30 days following EVAR (1.4 percent to 19.3 percent in two AneuRx studies, 11.7 percent for Excluder and 20 percent for Powerlink). The highest number of events occurred in the combined Ancure and EGS study, although this event was reported for bifurcated grafts only. In 12 studies (n = 2,598) 14.7 percent had events at 1 year. The range was 5.4 percent (Talent) to 21.8 percent (combined Ancure and EGS, bifurcated grafts only). The Powerlink study reported no stent fractures.

Graft-limb thrombosis was reported in five studies (n = 659) within 30 days following EVAR with an overall incidence of 2.4 percent (range 0.7 percent to 6.3 percent). Incidences for the two device-specific studies were comparable. The 1 year incidence for device-specific Powerlink and combined Ancure and EGS NRCTs were 2.1 percent and 5.4 percent, respectively. Up to 1 year, the overall incidence of graft stenosis was 2.7 percent in three studies reporting, including one device-specific study Powerlink which reported events in 1.6 percent of patients.

Question 4: What are the costs-benefits for each of the procedures?

Aside from studies developing Markov models to estimate lifetime costs and the cost effectiveness of EVAR and OSR, the majority of studies reviewed for the economic analysis report either on the costs associated with the initial elective procedure (EVAR, OSR, or both) or on costs of followup care for EVAR. If studies reporting on cost also include measures of effectiveness, we report those findings as well as conclusions regarding cost effectiveness.

The results of the two EVAR RCTs for AAA ≥5.5 cm (EVAR vs. OSR and EVAR vs. no intervention) were used as the basis for a cost-effectiveness modeling. With those two exceptions, most of the data on costs or effectiveness (rarely both) come from observational studies, some of which are simply case series with no comparative analysis.

All of the retrospective reviews and prospective case series included in our analyses have taken an institutional perspective and report only the costs incurred by the hospital(s) and/or clinics. None take the societal perspective of including the cost or quality of life associated with the patient's or caregiver's time lost from work or other activities while hospitalized, traveling, or attending followup visits.

Table 11 on page 79 presents an overview of the included studies. These studies vary not only by type (i.e., RCTs, systematic reviews, Markov models, retrospective reviews, and prospective case series), but also along several substantive dimensions including country, population, time horizon, type of grafts, patient selection criteria, and economic perspective (societal or institutional). A few studies report on hospital incentives supporting the use of these two procedures within the context of their profitability relative to Medicare reimbursement rates for DRGs 110 and 111 (AAA repair with and without complications, respectively).

Table 11 Overview of studies

Procedures | Authors (Reference) | Study Type | Publication Year | Cohort Year | Country | Sample Size | Timeframe | Main Cost Results
EVAR, OSR | Bosch^149^ | Markov CEA | 2002 | Not applicable | USA | Not applicable | lifetime | $EVAR >$OSR
| Patel^150^ | Markov CEA | 1999 | Not applicable | USA | Not applicable | lifetime | $EVAR >$OSR
| Michaels^17^ | Markov CEA | 2005 | Not applicable | UK | Not applicable | 10 years | $EVAR >$OSR
| EVAR-1^13^ | RCT | 2005 | 1999 | UK | 543, 539 | 4 years | $EVAR >$OSR
| Angle^151^ | Retrospective review | 2004 | 2000-2001 | USA | 55, 64 | Hospital | $EVARh >$OSRh
| Bosch^154^ | Retrospective review | 2001 | 1997-1999 | USA | 181, 273 | Hospital | $EVARh >$OSRh
| Clair^152^ | Retrospective review | 2000 | 1998 | USA | 45, 94 | Hospital | $EVARh >$OSRh
| Dryjski^156^ | Retrospective review | 2003 | 2000 | USA | 73, 57 | Hospital | $EVARh >$OSRh
| Hayter^157^ | Retrospective review | 2005 | 1995-2004 | Australia | 55, 140 | Hospital + 1 year followup | $EVAR >$OSR
| Lee^51^ | Retrospective review | 2004 | 2001 | USA | 2565, 4607 | Hospital | $EVARh >$OSRh
| Sternbergh^64^ | Retrospective review | 2000 | 1996-1997 | USA | 131, 49 | Hospital | $EVARh >$OSRh
| Maher^33^ | Systematic review | 2003 | Not applicable | Not applicable | Not applicable | Not applicable | $EVAR >$OSR
EVAR, CM | Michaels^17^ | Markov CEA | 2005 | Not applicable | UK | Not applicable | 10 years | $EVAR >$CM
| EVAR-2^145^ | RCT | 2005 | 1999 | UK | 166, 172 | 4 years | $EVAR >$CM
EVAR only | Prinssen^159^ | Prospective review | 2004 | 1994-2000 | Netherlands | 77 | Followup surveillance | $EVAR only
| Bertges^153^ | Retrospective review | 2003 | 2000-2001 | USA | 221 | Hospital | $EVAR only
| Lester^158^ | Retrospective review | 2001 | 1994-1999 | USA | 91 | Hospital | $EVAR only
OSR, CM | UKSAT^147^ | RCT | 1998 | 1991-1995 UKSAT | UK | 563, 527 | 18 months post randomization | $OSR >$CM
| Schermerhorn^148^ | Markov CEA | 2000 | Not applicable | UK | Not applicable | Lifetime | $OSR >$CM
OSR only | Brox^155^ | Retrospective review | 2003 | 1997-2000 | USA/Canada | 505(US), 552(Canada) | Hospital | $OSR only
| Huber^4^ | Retrospective review | 2001 | 1994-1996 | USA | 16,450 | Hospital | $OSR only
| Patel^163^ | Markov CEA | 2000 | Not applicable | USA | Not applicable | | $OSR only

CM — Conservative Management, EVARh and OSRh = cost associated with initial hospitalization for EVAR and OSR respectively.

The costs reported within the studies reviewed also vary by whether they considered direct, indirect, variable, and/or fixed costs. As individual hospital accounting systems do not necessarily follow a standardized approach to allocating costs across departments, the costs reported within this systematic review reflect a variety of costing methodologies. Despite these qualifications, we found a general consensus in the relative costs of EVAR and OSR within each of these studies regardless of the time frame considered.

## Results

UKSAT measured and valued direct health service costs for use of UK National Health Service (NHS) resources for participants in their trial. The mean cost of treatment in the early-OSR group was significantly higher than that for ultrasonographic surveillance (£ = 4,978 vs. £3,924; difference = £1,064, CI 799–1,328).^147^ It is not clear how these costs would directly relate to U.S. settings. Trials conducted outside the U.S. do not reflect U.S. norms associated with resource valuation, utilization of health care resources, practice variation, and U.S. health care expertise. One cost-effectiveness report used UKSAT data and concluded that despite the negative conclusions of the UK trial, early OSR may be modestly cost effective for patients with small AAAs, particularly younger patients (<72 years of age).^148^ Given the higher cost associated with early OSR and the lack of effectiveness regarding survival and quality of life from the UKSAT and ADAM studies (published subsequent to the above cost-effectiveness analysis), it is difficult to accurately conclude that early OSR is cost-effective compared to surveillance with delayed OSR. Although they used different data bases, included different cost elements, were based in different countries with differing health care and payment systems, and focused on elective and ruptured AAAs, both studies of OSR cost-effectiveness came up with similar findings, an Incremental Cost Effectiveness Ratio (ICER) of about $11,000 per QALY.^142,^ ^155^

With regard to the main comparison of EVAR and OSR, our analyses begins with a discussion of the overall results of the 12 studies providing cost data comparing EVAR and OSR, and then a discussion of the studies reporting on the costs associated with either procedure. Studies include one RCT,^13^ one systematic review,^33^ seven retrospective reviews, and three Markov models,^17,^ ^149,^ ^150^ one of which is based on the results of one of the other studies.

Regardless of time frame, all studies comparing EVAR and OSR report higher costs associated with EVAR compared to OSR (Table 11 on page 79). Studies relying on Markov models to estimate long-term followup report that the relative cost of EVAR and OSR is very sensitive to the cost of the graft (production costs versus commercial pricing) as well as the need for followup care associated with monitoring, complications, and reinterventions.

Of the 15 studies reporting cost data, four reported on the direct variable costs,^64,^ ^147,^ ^151,^ ^152^ excluding the indirect costs that take into account overhead (e.g., utilities) and fixed costs (e.g., new hospital equipment, training). Six of the studies included both direct and indirect costs;^153^–^158^ the remaining five were unclear.^4,^ ^51,^ ^145,^ ^159^ Excluded studies are shown in Table 12 on page 80.

Table 12 Studies excluded from systematic review

Exclusion rationale | Authors (reference) | Study type | Publication year | Cohort year | Sample size | Timeframe | Main cost results
<50 in either arm | Aquino^66^ | Prospective | 2001 | 1997-1999 | 25, 26 | Hospital + 1 year followup | Not applicable
| Berman^67^ | Prospective | 2002 | 1999-2000 | 9, 11 | Hospital | $EVARh ~ $OSRh
| Birch^68^ | Retrospective review | 2000 | 1996-1999 | 31, 31 | Hospital, pred lifetime | $EVAR >$OSR
| Forbes^69^ | Retrospective review | 2002 | 1998 | 7, 31 | Hospital +1 year followup | $EVAR >$OSR
| Lottman^70^ | RCT | 2004 | 1996-1999 | 57, 19 | Preop, 1 and 3 months postop | Not applicable
| Rosenberg^71^ | Retrospective review | 2005 | 2002-2003 | 34, 54 | Hospital | $EVARh ~ $OSRh
No cost information | Drury^6^ | Systematic review | 2005 | Not applicable | Not applicable | Not applicable | Not applicable

EVARh and OSRh = cost associated with initial hospitalization for EVAR and OSR respectively

Summarizing or comparing the studies reporting on costs is complicated by the variety of approaches taken to calculate costs. Each study includes different elements and combines them differently. Table 13 on pages 81–87 displays what elements were addressed in each of the studies considered, as well as the degree to which the papers fully enumerated what was included in their cost analysis. For example, the vague descriptor “hospital care” included distinctly different subcategories of services from one hospital to another. The majority of the studies did not include pre- or post-operative costs and did not include surgeon fees within the cost of the hospitalization for the initial procedure nor in their total cost estimates. Studies from other countries are hard to translate into the U.S. context. Not only do hospital costs differ, but the basis for the costs is often different. For example, LOS has a different effect on costs in the context of DRGs; it is a cost to the hospital but not to the payer. Focusing on studies reporting hospitalization costs (as opposed to charges, which tend to be higher), EVAR hospitalization costs for the initial procedure ranged from a low of $16,700 reported by Dryjski et al.^156^ to a high of $23,000 in Bertges et al.^153^ Although the cost of the EVAR graft reported within Dryjski et al.^156^ was among the highest reported in all of the studies, a number of items were explicitly excluded from the cost analysis that led to a relatively low hospitalization cost estimate. These items are anesthesia, respiratory care, pharmacy, radiology, and laboratory tests. Bertges et al., on the other hand, included a very comprehensive itemized list of categories of care in their analyses and thus report higher hospitalization costs of $23,000.^153^

Table 13 Cost analyses and findings

| | EVAR-1 05^13^ | | Angle 04^151^ | | Bosch 01^154^ | | Clair 00^152^ | | Dryjski 03^156^ | | Hayter 05^157^ | | Lee 04^51^ | | Sternbergh 00^64^ | | EVAR2 05^145^ | | Prinssen 04^159^ | Bertges 03^153^ | Lester 01^158^ | Brox 03^155^ | | Forbes 98^147^ | | Huber 01^4^
| Type of cost data (source) | Hospital costs (UK National Health Service) | | Hospital costs (unspecified) | | Hospital costs (TSI) | | Hospital costs (TSI) | | Hospital costs (unspecified) | | Hospital costs (Medicare benefits schedule, MBS) | | Hospital charges (National Inpatient Sample—NIS) | | Hospital costs (unspecified) | | Hospital costs (UK National Health Services) | | Hospital costs | Hospital costs (% of charges) | Hospital costs (TSI) | Hospital costs (TSI) | | Hospital cost (UK National Health Service) | | Hospital charges
| Type of study | RCT | | Retrospective review | | Retrospective review | | Retrospective review | | Retrospective review | | Retrospective review | | Retrospective review | | Retrospective review | | RCT | | Prospective review | Retrospective review | Retrospective review | Retrospective review | | RCT | | Retrospective review
| Direct only or direct AND indirect | Unclear | | Direct only | | Direct and indirect | | Direct only | | Direct and indirect | | Direct and indirect | | Direct and indirect | | Direct only | | Unclear | | Direct and indirect | Direct and indirect | Direct and indirect | Direct and indirect | | Direct only | | Direct and indirect?
| Currency | UK pound | | U.S. dollar | | U.S. dollar, 1999 | | U.S. dollar | | U.S. dollar | | AU converted U.S. dollar, 2003/04 | | U.S. dollars, 2001 | | U.S. dollar | | UK pound | | U.S. dollar | U.S. dollar | U.S. dollar | U.S. dollar, 2000 | | UK pound | | U.S. dollars, 1996
| Cohort | 1999-2003, UK | | 2000-2001 | | 1997-1999 | | 1998 | | 2000 | | 1995-2004 | | 2001 | | 1996-1997 | | 1999-2003, UK | | 1994-2000 | 2000-2001 | 1994-1999 | 1997-2000 | | ? | | 1994-1996
| Treatment | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | CM | EVAR | EVAR | EVAR | OSR-USA | OSR-Canada | CM | OSR | OSR
GRAFTS USED | Ancure, Guidant (Menlo Park, CA) | - | | ✓“majority” | | ✓ | | - | | ✓ 91% | | - | | | | - | | - | | ✓ 97% | ✓ 86% | ✓
| AneuRx, Medtronic (Santa Rosa, CA) | ✓ 4% | | ✓“rest” | | - | | ✓ 100% | □ | ✓ 9% | | - | | | | ✓ 100% | | ✓ 6% | | - | ✓ 14% | -
| Excluder, Gore (Flagstaff, AZ) | ✓ 7% | | - | | ✓ | | - | | - | | ✓ 25% | | All available | | - | | ✓ 7% | | ✓ 3% | - | ✓ | Not applicable | | Not applicable | | Not applicable
| Talent, Medtronic (Minneapolis, MN; Santa Rosa, CA) | ✓ 33% | | - | | - | | - | | - | | ✓ 2% | | (National dataset,2001) | | - | | ✓ 21% | | - | - | -
| Vanguard, Boston Scientific (Wayne, NJ) | - | | - | | ✓ | | - | | - | | - | | | | - | | - | | - | - | ✓
| Zenith, Cook (Bloomington, IN; Denmark) | ✓ 51% | | - | | - | | - | | - | | ✓ 73% | | | | - | | ✓ 59% | | - | - | -
| Other commercial grafts | ✓ 5% | | - | | - | | - | | - | | - | | | | - | | ✓ 7% | | - | - | -
| Custom-made stents | - | | - | | ✓ 43% | | - | | - | | - | | | | - | | - | | - | - | -
| Straight, tube type | ✓ 10% | | ✓ 17% | 57% | ✓ 8% | | | | ? | | | 66% | ✓ | | ? | | ✓ 13% | | ✓ 17% | | ✓ 21%
| Bifurcated type | ✓ 90% | | ✓ 83% | 43% | ✓ 64% | | | | ✓ | | ✓ 100% | 34% | ✓ | | ? | | ✓ 87% | | ✓ 52% | | ✓ 79%
| Other | □ | | | | ✓ 27% | | | | | | □ | | | | | | | | ✓ 21% | | □
| Ancillary supplies included in graft costs | --- | | not specified | | not specified | | yes | | yes | | yes | | Not specified | | Not specified | | --- | | --- | no | Not specified | --- | | --- | | ---
| Initial ER evaluation | - | | - | | ? | | ✓ | | - | | - | | - | | ? | | - | | - | | ✓ | ? | | ? | | -
| Preop / preop diagnostics | - | | - | | ? | | - | | - | | ✓ | | - | | ✓ | | - | | - | | ? | ? | | ? | | -
| Total preop | - | | - | | ? | | - | | - | | $733 | $663 | - | | $1,100 | $644 | - | | - | | ? | ? | | ? | | -
| Commercial graft / prosthetic device | ✓ | | ✓ | | $7,000 | $600 | $8,976 | $597 | $12,974 | $750 | $7,765 | $363 | $10–$12,000 | | $10,200 | $653 | ✓ | | - | $13,191 | - | ✓ | | ? | | ?
| % hospital costs accounted for by graft | | | 58% | | 34% | 3% | | | 78% | 8% | 49% | 3% | | | 51% | 6% | | | - | 57%
| Operating room | ✓ | | ✓ | | ✓ | | ✓ | | ✓ | | ✓ | | ? | | | | | | | | ✓ | ✓ | | ? | | ?
| Surgeon fees | ? | | ? | | - | | - | | - | | ✓ | | ? | | - | | ? | | - | | - | - | | ? | | ?
| Nursing | ? | | ✓ | | ✓ | | ✓ | | ✓ | | ✓ | | ? | | ? | | ? | | - | | ✓ | ✓ | | ? | | ?
| Anesthesia | ? | | ? | | ✓ | | ✓ | | - | | ✓ | | ? | | ✓ | | ? | | - | | ✓ | ✓ | | ? | | ?
| Medical/surgical supplies | ? | | ✓ | | ✓ | | ✓ | | ? | | ✓ | | ? | | ✓ | | ? | | - | | ✓ | ✓ | | ? | | ?
| Respiratory services/ventilation | ? | | ✓ | | ? | | ? | | - | | ✓ | | ? | | ? | | ? | | - | | ? | ✓ | | ? | | ?
| Pharmacy | ? | | ✓ | | ? | | ✓ | | - | | ✓ | | ? | | ✓ | | ? | | - | | ✓ | ✓ | | ? | | ?
| Radiology | ? | | ✓ | | ✓ | | ✓ | | - | | ✓ | | ? | | ? | | ? | | - | | ✓ | ✓ | | ✓ | | ?
| Blood/transfusion | ✓ | | ? | | ? | | ✓ | | ? | | ? | | ? | | ✓ | | ✓ | | - | | ✓ | ✓ | | ? | | ?
| Laboratory | ? | | ✓ | | ? | | ✓ | | - | | ? | | ? | | ? | | ? | | - | | ✓ | ✓ | | ? | | ?
| Postop ICU | ✓ | | ✓ | | ✓ | | ✓ | | ✓ | | ✓ | | ? | | ✓ | | ✓ | | - | | ✓ | ✓ | | ? | | ?
| Postop ward | ✓ | | ✓ | | ✓ | | ? | | ✓ | | ✓ | | ? | | ✓ | | ✓ | | - | | ✓ | ✓ | | ✓ | | ?
| Post diagnostic | ? | | - | | ? | | ? | | ? | | ✓ | | ? | | ✓ | | ? | | - | | ✓ | ✓ | | ? | | ?
| Allied health, therapy, etc. | ? | | - | | ? | | ? | | ? | | ✓ | | ? | | ? | | ? | | - | | ✓ | ? | | ? | | ?
| “Procedure” | ✓ | | ✓ | | ✓ | | ? | | ? | | ✓ | | ? | | ✓ | | ✓ | | - | | ✓ | ✓ | | ✓ | | ?
| “Hospital,” “inpatient hospitalization” | ✓ | | ✓ | | ✓ | | ✓ | | ? | | ✓ | | ✓ | | ✓ | | ✓ | | - | | ✓ | ✓ | | ✓ | | ✓
| Patient costs (time, travel, morbidity). | - | | - | | - | | - | | - | | - | | - | | - | | - | | - | | - | - | | - | | -
| “Other” | ✓ | | ? | | ? | | ✓ | | ? | | ? | | - | | ? | | ✓ | | - | | ✓ | ? | | ✓ | | ?
| Total hospitalization | £10,819 | £9,204 | EVAR =1.74*OSR | | $20,716 | $18,484 | EVAR = OSR+$7205 | | $16,731 | $9,042 | $15,898 | $13,400 | $50,346 | $47,009 | $20,150 | $11,698 | £11,016 | £3,518 | | $23,042 | ✓ | $19,000 | $16,000 | £3,914 | £4,978 | $35,681
| U.S. dollars | | | | | | | | | | | | | | | | | $17,626 | $5,629
| Total preop + hospitalization | - | | - | | - | | - | | - | | $16,631 | $14,063 | - | | $21,250 | $12,342 | - | | - | | $11,842 | ? | | ? | | -
| Radiology: imaging followup | ✓ | | - | | - | | - | | - | | ✓ | | - | | - | | ✓ | | ✓ | | - | ? | | ? | | -
| Endoleak repair | ✓ | | - | | - | | - | | - | | ✓ | | - | | - | | ✓ | | ✓ | | - | ? | | ? | | -
| Conversion to OSR | ✓ | | - | | - | | - | | - | | None needed | | - | | - | | ✓ | | ✓ | | - | ? | | ? | | -
| “Adverse events” | ✓ | | - | | - | | - | | - | | ✓ | | - | | - | | ✓ | | ? | | - | ? | | ? | | -
| Patient costs (time, morbidity) | ✓ | | - | | - | | - | | - | | ✓ | | - | | - | | ✓ | | - | | - | ? | | ? | | -
| Total followup | £2,439 | £741 | - | | - | | - | | - | | $2,013 | $59 | - | | | | £2,616 | £1,465 | $9,729 (5 years) | | - | ? | | ? | | -
| GRAND TOTAL | £13,258-4 years | £9,945-4 years | - | | - | | - | | - | | $18,644 at 2 years | $14,122 at 2 years | - | | | | £13,632-4 years | £4,983-4 years | | | - | ? | | ? | | -

Key: explicitly included cost (□); explicitly excluded cost (-); cost not mentioned or inclusion/exclusion uncertain (?).

Studies reporting OSR hospitalization costs for the initial procedure ranged from a low of $9,000 reported by Dryjski et al.^156^ to a high of $18,500 in Bosch et al.^154^ This difference is again due in part to Dryjski's explicit exclusion of a number of categories of care as listed above.

Studies reporting hospital charges are generally higher than costs, ranging from $45,000 ^64^ to $50,000^51^ for EVAR hospitalizations and $31,000 ^64^ to $47,000^51^ for OSR hospitalizations. The Australian study is on the low end of the scale, reporting costs of approximately $16,000 and $13,400 for EVAR and OSR respectively.^157^

None of the studies reported on the cost of acquiring new equipment or the training required by surgeons to perform EVAR. Both of these items can be quite costly.

### EVAR Prosthesis

Since the cohort year also represents the year that the grafts were used, it represents the stage of the technology and to some extent the learning curve associated with the procedure. The majority of the EVAR grafts reported on in these studies received FDA approval in 1999.^67^ The cost of some of these grafts may have been discounted or paid for based on production costs at the time the studies were underway. Once grafts became commercially available, they became more expensive. As the driving force behind the majority of the cost of EVAR is the cost of the graft, associated supplies/equipment, and the degree of complications associated with followup, the cohort year relative to the year the grafts became commercially available is important.

Cost estimates for the EVAR graft range from a low of $7,000 reported for a 1997-1999 patient cohort^154^ to $13,000 reported for a 2000 patient cohort.^156^ The graft accounts for a range of 34 percent to 78 percent of the total hospitalization costs reported in these two studies respectively, with the differences in percentages largely a reflection of how comprehensively the authors itemized costs. Bosch et al. relied on graft costs reported in the literature near the time of commercialization and estimated a relatively low price for the graft relative to the cost of the hospitalization, thus contributing to underestimating the total hospitalization costs for EVAR, underestimating the difference in the cost of EVAR relative to OSR, and underestimating the percent of total hospitalization costs attributable to the graft.^154^ In contrast, Dryjski et al. underestimated the cost of the hospitalization relative to the graft by excluding a number of categories of necessary hospital services from the cost estimate.^156^

### Reimbursement Issues

The adequacy of Medicare reimbursement for either procedure varies by type of hospital, geographic region, and type of grafts used primarily for EVAR. Several studies report that from a hospital's perspective, reimbursement may not be sufficient to cover the cost of EVAR hospitalization, primarily because the DRG rates were set before EVAR procedure was introduced, thus not taking into account the cost of the prosthesis (graft). Studies published in the late 1990s rely on production costs associated with grafts. Once grafts obtained FDA approval and became commercially available, grafts essentially doubled in price, making it more difficult for hospitals to break even based on Medicare reimbursement rates for AAA repair. As Medicare reimbursement rates for AAA repair do not differentiate between EVAR and OSR, they do not reflect the high cost of the EVAR grafts or differences in length of stay. Hospitals may thus be trading off savings from reduced length of stay against the cost of the EVAR prosthesis.

### Measures of Effectiveness (Table 14 on pages 88–89)

Measures of effectiveness include the LOS associated with the initial hospitalization, ICU time, mortality (in-hospital, 30 day) and morbidity, complication, and reintervention rates. EVAR has a shorter LOS associated with the initial hospitalization, range 2.0 days,^151^ to 10 days^13^ includes preoperative assessments) compared to OSR, range 7.3 days^151^ to 15.7 days.^13^ The longer length of hospital and ICU length of stay are based on the randomized trials that were conducted in Europe and thus may not be comparable to U.S. settings. Less ICU time is associated with EVAR's initial hospitalization, range 0.6 days^152^ to 1.4 days,^156^ compared to OSR, range 2 days^64^ to 3.5 days.^151^ Thus, EVAR is associated with less resource use in terms of a patient's time spent in the hospital as well as use of the ICU. Because hospital beds are expensive and essentially define the hospital's capacity/ability to serve patients, from the hospital's perspective, EVAR may represent a more efficient use of hospital resources than OSR.

Table 14 Short-term mortality, hospital, and intensive care unit (ICU) length of stay

| Sternbergh 00^64^ | | Clair 00^152^ | | Angle 04^151^ | | Hayter 05^157^ | | Lester 01^158^ | Bosch 01^154^ | | Dryjski 03^156^ | | Bertges 03^153^ | EVAR1 05^13^ | | EVAR2 05^145^ | | Brox 03^155^ | | Bosch 02^149^ | | Huber 01^4^ | Lee 04^51^ | | Michaels 05^17^ | | | Schermerhorn 00^148^ | | UKSAT^147^ | | Patel 99^150^ | | Prinssen 04^159^
| EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | OSR | EVAR | EVAR | OSR | EVAR | OSR | EVAR | EVAR | OSR | EVAR | AS | OSR-U.S. | OSR-Canada | EVAR | OSR | OSR | EVAR | OSR | RC1-EVAR | RC1-OSR | RC2-Nothing | Early Repair | AS | AS | OSR | EVAR | OSR | EVAR Only
Total N per treatment arm | 131 | 49 | 45 | 94 | 55 | 64 | 55 | 140 | 91 | 181 | 273 | 73 | 57 | 221 | 543 | 539 | 166 | 172 | 2.97* | 176 | | | 16450 | 2565 | 4607 | | | | | | 527 | 563 | | | 77
30-day mortality, n | NR | NR | see notes | | 2 | 1 | 1 | 2 | NR | NR | NR | NR | NR | NR | 9/532 | 25/518 | 13/150 | 1/47 | NR | NR | NR | NR | | NR | NR | NR | NR | | NR | NR | | | 4.8* | 1.2* | NR
30-day mortality, % | | | | | 3.6 | 1.5 | 1.8 | 1.4 | | | | | | | 1.7 | 4.8 | 8.7 | 2.1 | | | | | | | | | | | | | 7.1% | 5.8%
In-hospital mortality, n | NR | NR | 0 | 1 | NR | NR | NR | NR | 1 | 2 | 8 | 3 | 0 | NR | NR | NR | NR | NR | | | NR | NR | 691 (est) | 33 | 176 | 1.85* | 5.8* | | 5.8 | 7.2 | | | | | 0
In-hospital mortality, % | NR | NR | 0 | 1.0% | | | | | 1% | 1.1% | 2.9% | 4 | | | | | | | 5.2% | 5/5% | | | 4.2 | 1.3 | 3.8 | | | | | | 7.2% | 5.8% | 4.8 | 1.2
Hospital LOS, days (mean) | 3.9 | 8 | 3.2 | 9.7 | 1.96 (1 median) | 7.3 (6 median) | 6* | 10* | 3.5 | Postop LOS only | | 4.9 | 12.6 | 2.4 | 10.3 | 15.7 | NR | NR | NR | NR | NR | NR | 10 (8 median) | 3.6 (2 median) | 8.8 (7 median) | NR | NR | | NR | NR | NR | NR | NR | NR | NR
Hospital LOS, range or SD | 3.6* | 5.8* | 1.4* | 4.8* | 1.5* | 8.3* | 4 to 24 | 6 to 46 | 2.3* | | | 13.4* | 14.8* | | 17.8* | 16.9* | | | | | | | 8.1* | 5.9* | 7.8*
ICU LOS, days (mean) | 1.1 | 2 | 0.06 | 2.97 | 0.09 | 3.5 | 0* | 1* | | 1.2* (1 median) | 2.3* (1 median) | 1.4 | 5 | NR | 0.7 | 2.4 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | | NR | NR | NR | NR | NR | NR | NR
ICU LOS, range or SD | 2.0* | 2.3* | 0.25* | 3.02* | 0.29* | 7.36* | 0 to 3 | 1 to 19 | | 0.4** 1 to 2 | 2.1** 1 to 12 | 7.1* | 6.1* | | 3.8* | 5.9*
Notes: | *SD | | *SD unless specifically reported as 30-day mortality is assumed to be "in-hospital | | *SD | | *Median | | *SD | * Includes only patients staying 1 day or longer *SD | | *SD | | | *SD | | | | * sample size for elective surgeries only | | Markov decision model | | *SD | *SD | | Markov decision model *Probabilities, presumed postoperative, from RCTs | | | Markov model | | | | *Probability

AS = Active Surveillance

Short-term benefits associated with EVAR include reduced LOS, reduced use of ICU, reduced operative, and 30-day mortality and morbidity. However, results of two RCT comparing EVAR with OSR have provided additional midterm outcome data after 2–4 years of followup. The results from these studies (which were not conducted in the U.S.) indicate that compared to OSR, EVAR reduces AAA related mortality by 3 percent. However, after 2 years there was no difference in overall survival. Differences in health related quality of life were small, may not be clinically noticeable, and disappeared after 3 months. EVAR costs were higher than OSR and were associated with more complications, need for reinterventions, and continued monitoring.

### Cost Effectiveness Analyses Using Markov Methodologies (Table 15 on pages 90–92)

Table 15 summarizes three studies that utilized Markov methodologies to analyze differences in the cost and effectiveness of EVAR and OSR over a patient's lifetime^17,^ ^149,^ ^150^ and two studies that compared OSR to conservative treatment. All three of the former found that EVAR was more expensive. Two of the studies were conducted in the U.S. and report that a higher quality of life was associated with EVAR and that the ICERs were $9,905 per QALY and $22,826 per QALY respectively.^149,^ ^150^ While Bosh, Patel, and Michaels use differing baseline operative mortality rates and QOL measures, they all use 70 year olds with aneurysms between 5 and 6 cm as their baseline reference case. The Patel study used assumptions of effectiveness based on case series data. They conclude that the benefits were worth the cost with the qualification that their results were highly dependent on their assumptions regarding mortality and morbidity. Patel et al. reported that EVAR may be more cost effective than OSR if operative mortality rates were <1.2 percent and the surgical mortality rates were >1.7 percent.^150^ However, if the combined mortality and long term morbidity rate of open surgery decreased from 9.1 percent to 4.7 percent, the authors concluded that EVAR may not be cost effective. Bosch et al. also used case series data as the basis for their model; they report the sensitivity of their conclusions to EVAR graft performance in terms of long term failure and rupture rates.^149^ They fail, however, to explicitly account for the cost of the EVAR prosthesis by using Medicare reimbursement rates for DRG codes 110 and 111 (AAA repair with and without complications, respectively) to estimate the cost of the initial AAA repair. These DRG codes do not distinguish differences in the cost of AAA repair by procedure (i.e., by EVAR and OSR), and do not include the cost of the EVR prosthesis. Thus, Bosch et al. underestimate the cost of the EVAR initial hospitalization costs relative to OSR and report a conservative estimate of the costs in the cost effectiveness ratio. On the other hand, Bosch includes patients' time lost from work in terms of lost wages in the costs associated with each procedure. As they also estimate the impact of the procedures on the patients' quality of life and include this in the denominator of the cost effectiveness ratio, they have essentially double counted the impact of AAA repair from the patient's perspective.

Table 15 Markov models

Source of Costs | Bosch 2002^149^ | | Patel 1999^150^ | | Michaels 2005^17^ | | Schermerhorn 2000^148^ | | Patel 2000^163^
Direct only or direct AND indirect currency | Hospital costs, Medicare reimbursement for DRGs 110 & 111 physician CPT codes | | Hospital cost accounting system, Medicare reimbursement rates for physician CPT codes | | National Health Service (NHS), Sheffield Teaching Hospitals, NHS Trust | | Hospital costs (UK NHS), UKSAT | | Hospital cost accounting system, Medicare reimbursement rates, physician CPT codes
| Direct and indirect U.S. dollar, 2000 | | Direct and indirect U.S. dollar, 1997 | | Unclear UK £, 2003-2004 | | Direct UK £ * 1.6 = U.S. $ 1996-97 | | Unclear U.S. dollar, 1997
| EVAR | OSR | EVAR | OSR | RC1-EVAR | RC2-Surveillance | OSR | CM | OSR | CM
Reference case | 70 years old | | 70 years old | | 70 years old | 80 years old | 60–76 years old | | 72 years old
AAA diameter | 5–6 cm | | 5 cm | | 5.5 cm | 6.5 cm | 4–5.5 cm | | ruptured AAAs
Risk group (fit or unfit for OSR) | Fit for either procedure | | Fit for either procedure | | Fit for either | Unfit for OSR | Fit for OSR | | Ruptured AAAs
Time horizon | lifetime | | lifetime | | 10 years | | 6 years (UK trial) & lifetime | | lifetime
Discount rate | 3% | | 3% | | 3.50% | | 3% | | 3%
Consumer Price Index (CPI) for inflation | CPI medical care | | CPI medical care | | ? | | ? | | CPI medical care
Baseline operative mortality rate | 3% | 4% | 1.20% | 4.80% | EVAR: 1–85%, OSR: 5–80% | Range 5–80% | 5.8% elective | | 50%
Quality of Life (QOL) scores | -10% for 30 days | -30% for 60 days | QALY - 11 days | QALY - 47 days | QOL=0.8 each arm; EVAR: QALY - 30 days; OSR: QALY - 14 days | | QOL = 0.86 for each arm | | QALY - 52 days
QOL adjustment for complications (Y/N) | Yes | | Yes | | ? | | Yes | | Yes
Software | DATA 3.5 (TreeAge) | | SMLTREE v2.9 | | TreeAge Pro | | DATA 3.0 (TreeAge) | | SMLTREE v2.9
Probabilistic sensitivity analyses (SA) (Y/N) | No. one & multiple way SA | | No. one & multiple way SA | | Yes | | No. one way SA | | No. one & multiple way SA
Initial ER evaluation | - | | - | | ? | | - | | ✓ | ✓
Preop / preop diagnostics | - | | - | | ? | | - | | ✓ | ✓
Total preop | - | | - | | ? | | - | | OSR = CM
Graft / prosthetic device | - | - | $8,000 | $650 | ? | ? | ? | | $650 | $0
Type of graft / prosthetic device | - | - | Tube 10% bifurc 90% | ? | ? | ? | ? | ? | ? | ?
% TC accounted for by graft | | | 40% | 4% | ? | ? | ?
Operating room | ? | | ✓ | | ? | ? | ✓ | | ✓
Surgeon fees | ✓ | | ✓ | | ? | ? | ? | | ✓
Nursing | ? | | ? | | ? | ? | ? | | ?
Anesthesia | ? | | ✓ | | ? | ? | ? | | ✓
Medical/surgical supplies | ? | | ✓ | | ? | ? | ? | | ?
Respiratory services/ ventilation | ? | | ? | | ? | ? | ? | | ?
Pharmacy | ? | | ? | | ? | ? | ? | | ?
Radiology | ? | | ✓ | | ? | ? | ✓ | | ?
Blood/transfusion | ? | | ✓ | | ? | ? | ? | | ✓
Laboratory | ? | | ✓ | | ? | ? | ? | | ?
Postop ICU | ? | | ✓ | | ? | ? | ? | | ✓
Postop ward | ? | | ✓ | | ? | ? | ? | | ✓
Post diagnostic | ? | | ✓ | | ? | ? | ? | | ?
“Procedure” | ✓ | | ✓ | | ? | ? | ✓ | | ?
“Hospital,” “inpatient hospitalization” | ✓ | | ✓ | | ? | ? | ? | | ?
Patient costs (time, travel, morbidity | ✓ | | ✓ | | ? | ? | ? | | ✓
Other | ? | | ? | | ? | ? | ? | | ?
Total hospitalization | $19,642 | $23,484 | $20,083 | $16,016 | £? | £? | ? | | $28,356 | $0
Total preop + hospitalization | - | - | - | - | | | ? | | ? | ?
Imaging followup | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ? | | ✓
Total followup | ✓ | ✓ | ✓ | ✓ | | | ? | | ?
GRAND TOTAL | $39,785 lifetime | $37,606 lifetime | $28,901 lifetime | $19,314 lifetime | ? | ? | $8,000 lifetime | $6,490 lifetime | $36,606 lifetime | $580 lifetime
Net cost | $2,179 more for EVAR | | $9,587 more for EVAR | | 11,449 more for EVAR | 14,077 more for EVAR | $1,510 more for early surgery* | | $36,026 more for OSR
Net benefit | QALYs >0.22 for EVAR | | QALYs >0.42 for EVAR | | QALYs >0.1 for EVAR | QALYs >1.64 for EVAR | QALYs >0.14 for early surgery | | QALYs >3.35 for OSR
Incremental Cost Effectiveness Ratio (ICER) | $9,905/QALY using Medicare reimbursement rates | | $22,826 / QALY | | £100,000 / QALY | £8,579 / QALY | $10,800 / QALY | | $10,754 / QALY

Cost calculation based only on simple conversion from British pounds to U.S. dollars using £1.6 = $1

Although Bosch and Patel varied their analytical assumptions and conducted sensitivity analyses, they did not vary their assumptions simultaneously by employing probabilistic sensitivity analyses to fully test the robustness of their findings as recommended by the U.S. Panel on Cost Effectiveness in Health and Medicine.^160^–^162^

In a more recent, rigorous approach to Markov modeling, Michaels et al.^17^ used data from the EVAR trials and concluded that EVAR was NOT cost effective, in that the extra cost was not worth the gain in QALYs.^17^ Their ICER was £110,000 per QALY, which is well above accepted norms for cost effective procedures.^65,^ ^160^ Michaels et al.^17^ found that the cost effectiveness of EVAR and OSR is sensitive to assumptions regarding lower early morbidity for EVAR, higher operative mortality rate for OSR, higher need for followup care for EVAR, higher reintervention/ complication rates for EVAR, e.g., 25–30 percent for EVAR versus 0 percent for OSR, and higher costs associated with care provided to EVAR patients, regardless of time frame.

Michaels et al. point out that there is a time dependent effect.^17^ Studies conducted within a relatively short timeframe fail to adequately address the long-term benefits, harm, or costs associated with EVAR. Decreased operative mortality rates associated with EVAR may be offset by higher complication rates later in life. If followup costs associated with complications and reinterventions for EVAR are ignored, then EVAR's low operative mortality rates favor EVAR and may lead to the premature conclusion that EVAR is a cost effective alternative to OSR. This assumption is particularly relevant given the midterm results from RCTs demonstrating that compared with OSR, EVAR offered no advantage in all-cause mortality or health related quality of life and led to a greater number of complications and reinterventions.

In terms of the cost effectiveness of the two procedures, Michaels et al. found that OSR dominates if operative mortality rates are less than 3 percent.^17^ OSR is preferred if EVAR's cost/QALY is greater than $30,000 and if operative mortality rates for OSR are between 3 percent and 11 percent. EVAR dominates if operative mortality rates are greater than 40 percent. If EVAR costs are similar to OSR, and/or if EVAR reintervention rates are cut by 50 percent, then EVAR is preferred over OSR. If operative mortality rates are between 11 percent and 40 percent, Michaels et al. report that the outcome of whether EVAR is a cost-effective alternative to OSR is uncertain.^17^ Again, this cost effectiveness analysis did not include the midterm results from RCT.

Although Michaels takes the most rigorous approach employing probabilistic sensitivity analyses, they do not explicitly state their assumptions regarding what cost categories they considered for the initial procedure, nor for the cost of the EVAR prosthesis. The authors state that this new technology comes at a considerable price, yet no explicit monetary value was reported, nor was any sensitivity analyses on the cost of the graft and its effect on the cost effectiveness of EVAR relative to OSR conducted.

Michaels also reported that EVAR was cost effective compared to no intervention in individuals with large AAA who were judged medically unfit for OSR.^17^ However, they did not use results from EVAR-2 that directly compared EVAR with no intervention.^145^ The findings from this RCT demonstrated that EVAR had a considerable 30-day operative mortality in patients already medically unfit for OSR. EVAR did not improve survival compared to no intervention, had little effect on health-related quality of life, and was associated with a need for continued surveillance and reinterventions, at substantially increased cost. Therefore, the authors of EVAR-2 concluded that they saw no reason to pursue cost-effectiveness modeling.

As shown in Table 15, each of these cost-effectiveness models used different levels of specificity when describing how the costs of treatment were calculated. The Michaels study provided almost no guidance about just what went into their calculations.

None of these Markov studies analyzing the cost effectiveness of AAA repair included the less favorable midterm results regarding quality of life, survival, complications, or need for reintervention described above from recently reported RCTs of EVAR versus OSR. Furthermore, as no RCT studies have been completed within the U.S., the relevance of the cost data incorporated within these Markov studies from other countries is questionable.

Although none of the studies give confidence intervals around the cost effectiveness ratios, the use of probabilistic sensitivity analyses (PSA) and the percent of simulations falling below the reference threshold addresses this issue. However, for those studies not using PSA, because of the large observed variability in operative mortality, EVAR complication rates and the need for reintervention, confidence intervals would help clarify the significance of the point estimate, and the comparability of the reported cost effectiveness ratios. For all of the reasons mentioned above, the cost effectiveness of EVAR versus OSR remains unclear, particularly for specific patient cohorts defined by age, aneurysm size, and comorbidity.