# Methods

## Topic Assessment and Refinement and Literature Review

We began the review process conferencing with the Agency for Healthcare Research and Quality (AHRQ) and the nominee partner (AHIP) to clarify the project scope and background information. Clinical experts representing areas of vascular surgery, internal medicine, AAA epidemiology, diagnosis and treatment, and systematic review methodology served as members of a technical expert panel (TEP) (Appendix A *.) TEP comments and suggestions clarified the conceptual framework and refined study questions used for the project. Based on our initial conference calls, we developed a comprehensive work plan that covered an assessment and refinement of study questions and proposed literature search and review, inclusion/exclusion criteria, and methods for evaluating the quality of studies and reporting the evidence.

* Appendixes and Evidence Tables for this report are provided electronically at http://www.ahrq.gov/clinic/tp/aaareptp.htm

## Analytic Framework

An analytic framework was developed that assessed the key questions. The framework describes the logic chain that should be supported by evidence linking management options for AAA to improved outcomes. It takes the perspective of adults presenting with an asymptomatic AAA based on AAA size (small [<5.5 cm] vs. large [≥5.5 cm]) and patient operative risk (medically fit for surgery vs. medically unfit for surgery).

Question 1. What are the comparative effectiveness and adverse effects of treatment options of AAA including active surveillance, open repair, and endovascular repair?

Periodic surveillance, typically with abdominal ultrasound, has been considered reasonable for those with abdominal aortas measuring 3.0–3.9 cm because their risk of rupture is considered very low. For AAA 4.0–5.4 cm in diameter (small AAA) the question existed of whether immediate OSR, compared to ultrasound surveillance with delayed OSR, improves AAA-related mortality and all-cause mortality. For individuals with an AAA >5.5 cm, immediate OSR has been recommended, provided the patient is considered medically fit for OSR.^34^

In 1997, prior to widespread adoption of EVAR, there were an estimated 37,000 OSRs of intact AAA in the United States.^35^ During OSR, a vascular graft, comprised of a non-textile synthetic material or a woven synthetic textile that is usually sealed with collagen, gelatin, or albumin is sutured into the aorta. The proximal anastomosis is an end-to-end type and the distal anastomosis is located on the aortic bifuracation, the iliac bifurcations, or the common femoral arteries. Results from several long-term followup studies of individuals undergoing elective OSR for AAA have indicated that the risk of late complications, including secondary rupture, is quite low. In the absence of symptoms, additional evaluation of patients who received OSR is not typically performed.

However, in-hospital mortality rate for repair of intact AAA found in the National Inpatient Sample of community hospitals was 4.2 percent.^4^ In-hospital plus 30-day mortality associated with AAA repairs in the elderly fee-for-service Medicare population was estimated to be 5.6 percent in 1999. Because of perioperative mortality and morbidity (which are likely higher in older/sicker patients), individuals who were considered medically unfit for OSR due to comorbidities and/or advanced age previously underwent no attempt to repair the aneurysm. However, the risk of rupture can be as high as 25 percent per year for AAA with diameters greater than 6 cm.^36^

EVAR consists of the placement of a graft across the aneurysm and fixation to the normal aortic and iliac wall with stents at both ends. Endovascular access is via a transfemoral or transiliac artery approach with the aim of excluding the aneurysm by this graft. The theoretic benefit of EVAR versus OSR is based on the belief that EVAR has lower early morbidity, length of hospital stay, and mortality. Additionally, EVAR may provide long-term effective prevention of AAA rupture, equivalent or increased overall survival, and improved quality of life compared to OSR. These potential benefits of EVAR must be balanced with the need for periodic long-term followup, later-term device failures or complication, need for reinterventions, and costs.

The first report of endoluminal treatment of AAAs in a clinical setting was in 1990.^37^ By 2001 the estimated number of EVAR in the United States each year exceeded 12,000.^38^ An estimated 40–80 percent of AAA could be amenable to endovascular grafting based on aneurysm size, morphology, and patient surgical risk characteristics.^39,^ ^40^

EVAR has involved at least 16 different devices, but only four gained FDA approval and are currently in use in the United States: Cook Incorporated (Zenith); Gore (Excluder); Medtronic (AneuRx); and Endologix (Powerlink). A fifth device, Guidant (Ancure) is no longer available but was used in published reports that are included in this report. Others are, or will soon be, applying for FDA approval including (Talent, Quantum, ENOVUS (formerly Trivascular), and Anaconda).^41^ Each device has specific criteria and recommendations regarding the anatomic suitability of an individual patient for a particular graft type. However, one published accepted contraindication to EVAR is a proximal infranal neck either shorter than 15 mm or absent. Other anatomic features include excessive vascular tortuosity or angulation, calcification, or circumferential thrombus. None of these criteria are fixed and often vary by center, interventionalist, and device. There are numerous design and delivery issues unique to each device. The details, available on the FDA websites: (Gore Excluder: www.fda.gov/cdrh/mda/docs/P020004.html; Cook Zenith: www.fda.gov/cdrh/MDA/DOCS/p020018.html; Guidant Ancure: www.fda.gov/cdrh/mda/docs/p990017s030.html; Endologix PowerLink: www.fda.gov/cdrh/mda/docs/p040002.html, and Medtronic AneuRx: www.fda.gov/cdrh/pdf/p990020.html), are beyond the scope of this project. However, because certain aneurysm characteristics may be associated with additional patient factors, device selection, and clinical outcomes, it is difficult to accurately assess differential rates of outcomes among graft types.

Typically, EVAR devices are modular and allow modification (including selection of size and configuration) by the surgeon or radiologist at the time of placement based on patient, provider, and aneurysm criteria. The most common configurations of endovascular devices now used in the treatment for AAA are the aortobiiliac and aortouniilliac devices. Early developed aorto-tube grafts are no longer marketed in the United States. The endograft is radio-opaque with prespecified markers to aid positioning under fluoroscopic guidance and subsequent radiologic monitoring. It is composed of fabric or expended polytetrafluroethylene, and metal stents and comes loaded in a delivery system. Under fluoroscopic guidance, this introducer system is fed through the iliac arteries by means of catheters and guidewires until the endograft is positioned correctly at the top and bottom of the aneurysmal segment. Removal of the introducer system allows the fixing devices to attach with hooks, radial force/friction, column stiffness, or other anchors to the aortic wall and hold the graft in place, excluding blood flow from the aneurysm sac and removing pressure from the aneurysm wall.

Imaging guidelines for AAA repair with endovascular stent grafts have been published.^42^ These include preprocedural, intraprocedural, and postprocedural imaging and are more extensive than recommended for OSR. The details are beyond the scope of this report. However, two imaging modalities have been recommended no more than 6 months prior to the planned procedure in order to 1) detect or confirm, 2) measure AAA, or 3) evaluate the suitability of the patient for EVAR. Additionally, preoperative evaluation is required because during the procedure it may be determined that EVAR is not possible or complications may result, necessitating OSR.

Recommended preprocedure imaging modalities consist of Thin-Cut Helical/Spiral CT Arteriography (CTA) with multiplanar reconstruction and catheter angiography. The goals of intraprocedural imaging are: (1) to guide and document the appropriate placement of the endovascular stent graft and (2) to evaluate the effectiveness of the stent graft in excluding the AAA. Fluoroscopy and catheter angiography have been considered necessary and sufficient in the vast majority of cases. The goals of postprocedural imaging are to (1) confirm and redocument the appropriate placement status of the stent graft, (2) better assess the effectiveness of the stent graft in initially excluding the AAA (detecting flow in the sac), (3) follow the long-term fate and size of the AAA sac and ensure its stability, (4) detect stent graft failure, and (5) better characterize and follow patients with endoleaks. Current imaging modalities include plain films of the abdomen, CTA, and catheter angiography. The first two have been recommended every 6 months for at least 2 years and CTA annually thereafter (or more frequently if symptoms or device related problems develop). Catheter angiography is not recommended if CTA findings are satisfactory. Excellent technical results are initially characterized by a perfectly canalized blood flow and later by a completely retracted aneurysm wall around the endograft. EVAR use has increased, in part because it is postulated to be less invasive than open repair, results in reduced procedural morbidity, mortality, and hospital and other health care costs, while improving health related quality of life and providing equivalent long-term disease-specific and overall survival to OSR.

Additionally, EVAR may alter the threshold for intervention among individuals because EVAR may be considered an effective and relatively safe option compared to (1) surveillance among individuals with small (≥5.5 cm) AAA in whom the risk of rupture was previously considered too low to justify the morbidity of OSR and (2) no treatment for individuals with large AAA who are judged unfit for surgery due to advanced age or coexisting medical conditions and thus have a risk of rupture-related death that is relatively low compared to mortality from OSR.

EVAR has been associated with unique complications not associated with OSR. These can be related to the device, patient, AAA morphology, or interventionalist. Complications unique to EVAR include stent migration, stent wire fracture, metal fatigue, and endoleak. Because of the potential for these complications to arise and cause serious medical problems or require reintervention, long-term monitoring, following EVAR with CTA, is currently standard practice.

Endoleak is defined by the persistence of blood flow outside the lumen of the endoluminal graft but within the aneurysm sac as determined by an imaging study. An endoleak is evidence of incomplete exclusion of the aneurysm from the circulation. While causes and classifications vary, they may result from an incomplete seal between the endograft and the wall of the blood vessel, an inadequate connection between stent components, fabric defects, or porosity or retrograde blood flow from patent aortic side branches.^8^ Some endoleaks may resolve spontaneously. However, some persistent endoleaks are capable of repressurizing the aneurysm sac and have been associated with late rupture and need for subsequent interventions. Ruptures have been observed in the absence of endoleak. This concept of elevated pressure within the aneurysm sac has been called endotension. Table 1 provides a classification of endoleak.

Table 1 Classification of endoleak^43^

Type | Cause of Perigraft Flow
I | a) Inadequate seal at proximal end of endograft; b) Inadequate seal at distal end of endograft; c) Inadequate seal at iliac occluder plug
II | Flow from visceral vessel (lumbar, IMA, accessory renal, hypogastric) without attachment site connection
III | a) Flow from module disconnection; b) Flow from fabric disruption; Minor (<2mm); Major (≥2mm)
IV | Flow from porous fabric (<30 days after graft placement)
Endoleak of undefined origin | Flow visualized but source identified

### Literature Search and Review Strategy

A literature search was conducted using PubMed®, Cochrane Library, FDA, and other electronic websites from 1990 to October 2005, as well as handsearching of references from retrieved articles and contact with content experts. The following terms were included: abdominal aortic aneurysm, endovascular repair, surveillance, and surgery. Titles and abstracts of identified references were reviewed using standardized data abstraction sheets. The number of excluded studies and reasons for exclusion were noted. Studies meeting preliminary eligibility criteria were retrieved in full for further assessment and data extraction. (See Appendix B * for Exact Search Strings and Appendix C for Lists of Excluded References.) Data extraction forms included information related to study and patient characteristics, interventions, and outcomes.

### Study Eligibility and Extract Data

Studies were eligible if they were randomized controlled trials or natural history studies involving AAA, open repair, endovascular repair, or active surveillance and reported clinically relevant outcomes (Figures 1 and 3 on pages 27 and 29). We also included and updated a systematic review of evidence of EVAR vs. open repair for AAA published online and in manuscript form by the U.K. National Institute of Clinical Excellence (NICE). Data from nonrandomized studies and device-specific data available on the FDA website as submitted by manufacturers to the FDA were included to assess relevance and consistency to the United States. This included a report submitted by the Society for Vascular Surgery and published online in April 2006.^14^

Figure 1. Flow Chart: Question 1—RCTs

Figure 3. Flow Chart: Question 3—nonRCTs

### Outcomes

Outcomes were described as effectiveness (initial clinical success ≤30 days or during initial hospitalization), short-term (30 days to 6 months), midterm (6 months to 5 years), long term (>5 years), and adverse effects. These were based on recommendations for reporting of outcomes for open and EVAR by the Society for Vascular Surgery.^8^ The primary outcome was midterm all-cause mortality. Additional clinical outcomes included initial all-cause mortality, AAA mortality, AAA rupture, quality of life, and technical measures of EVAR and OSR success. Adverse events included treatment related mortality and morbidity (graft rupture, migration, and kinking) and need for additional interventions (including OSR). Incidences of endoleaks were also noted. Because data from RCT represent level one evidence, their results were emphasized and reported separately from reports using other study designs. Results from the United States that evaluated EVAR approved and available in the United States were highlighted for nonRCT data.

Quality of studies, reduction of bias, and strength of evidence. The methods of Schulz et al. were used to assess the quality of randomized controlled trials (RCT).^7^ We determined whether intention-to-treat analysis was utilized, whether results varied by intention-to-treat or per protocol analysis, and whether published RCT used EVAR devices similar to those approved and available in the United States. We evaluated whether effectiveness of interventions varied according to patient, aneurysm, or device characteristics including age, race, gender, EVAR device manufacturer and characteristics (name, tubular, mono or bi-iliac), aneurysm size (small [<5–5.5 cm] vs. large aneurysm) or medical fitness for OSR. Data from nonrandomized studies were included to assess relevance and consistency to practice in the United States. All data were extracted by trained data extractors onto standardized, piloted forms (Appendix D *).

Question 2. What is the relationship of volume, both hospital and physician, to the benefits and harms of endovascular procedures to repair AAA?

History of the relationship between hospital volume and operative mortality for OSR. Volume is believed to be a proxy for one or more structures or processes of care that influence outcomes. However, the structure and processes of care responsible for the volume-outcome relationship in cases of OSR of AAA have not been firmly established. Experience and greater availability of resources in higher volume hospitals could lead to better structure, patient selection, and pre-, intra-, and post-operative processes of care as well as more capable surgeons and support staff. The relationship between hospital volume and survival after OSR of AAA also might depend, in part, on surgeon volume and the type of surgeon (vascular, cardiothoracic, general). Some low-volume providers could perform operations only as necessary or in emergency situations that increase the risk, and a single death could greatly influence the mortality rate of low volume providers.

Conversely, hospitals that somehow achieve better outcomes or those that have a surgeon who specializes in vascular surgery could get more referrals. High volume itself might generate more referrals because information about volume may be more readily available to the community than outcome information. Some providers might be associated with a poor outcome and get fewer referrals. Thus, to some extent, outcome could drive volume rather than vice versa.^44,^ ^45^ Selective referrals could be augmented by recent policies of purchasers such as the Leapfrog Group who encouraged preferred use of hospitals in urban areas that perform more than 30 repairs of AAA per year in an effort to improve outcomes.^46^

Policymakers have already used studies of the volume-outcome relationship to set thresholds for preferential referral for OSR. The Leapfrog definition of ‘high’ volume was based on an investigation that was judged to be the single best report in the literature at the time.^47^ This investigation analyzed 3,419 repairs of unruptured AAA done in 116 Veterans Affairs (VA) hospitals (>99 percent male patients) from 1991-1993.^48^ Repairs of intact AAA were identified by Patient Management Category algorithms applied to ICD-9-CM codes recorded on discharge abstracts. The validity of this method of case identification wasn't reported. Unadjusted in-hospital mortality was 4.2 ± 3.5 percent in hospitals that performed 32 or more repairs versus 6.7 ± 7.8 percent in hospitals performing fewer than 32 repairs. The basis for selecting 32 as a cutoff was not reported, although it was the mean hospital volume. However, 22 so-called low-volume hospitals had zero mortality in 267 patients. In addition, the published report does not clearly state whether the volume categories were per annum as defined by Leapfrog or over the entire 3-year period of study. Furthermore, many of the operations might have been performed by surgical residents in training. Given these limitations, this study is not adequate for defining a hospital volume threshold for the United States. Investigators only recently demonstrated that hospital volume measured in one time period is related to outcomes in a subsequent period of time.^49^ The Leapfrog criterion for a high volume hospital has been increased to 50 or more procedures per year.^50^ It is not clear whether this count includes endovascular procedures to repair of AAA or whether the data used to define this threshold represent a period of time before FDA approval and widespread use of endovascular devices.

Adoption of endovascular procedures to repair AAA. The FDA approved the first devices for EVAR in September 1999. A separate International Classification of Diseases procedure code for EVAR was issued in October 2000. By 2001 approximately 36 percent of the repairs of intact AAA were coded as EVAR procedures in the National Inpatient Sample of 986 non-federal community hospitals in 33 states.^51^ Those undergoing EVAR rather than OSR tended to be older males with higher prevalence of hypertension and ischemic heart disease and less renal insufficiency or peripheral artery disease.^52^ Between May 2001 and September 2003 approximately 38 percent of AAA repairs were coded as endovascular procedures in the VA medical centers. Discharge data from 234 accredited hospitals in Illinois indicated that EVAR was used in approximately 32 percent of all (unruptured and ruptured) AAA cases in 2002.^53^ The proportion of AAA repairs done by EVAR was less in women than men. In-hospital mortality for elective EVAR was 2.3 percent in this series of cases from 1995 to 2003, and higher in women than men (5.1 percent vs. 1.7 percent unadjusted for risk or length of stay).

Hospital discharge data representing non-federal hospitals in New York indicated that 40 percent of all repairs of intact AAA in 2001 were EVAR, increasing to more than 50 percent in 2002.^54^ There was a corresponding increase of more than 20 percent in the number of hospitals performing EVAR. Compared to patients undergoing OSR, patients having EVAR were older and more likely to have coronary artery disease, hypertension, hyperlipidemia, and diabetes mellitus. In 2002, 60 hospitals in New York performed EVAR. Nearly half did five or fewer procedures, while 12 hospitals did 30 or more. In-hospital mortality rates were 1.9 percent and 0.8 percent respectively. This small difference in mortality was not statistically significant given the relatively small number of hospitals. Furthermore, risk adjustment was not done because the database did not contain patient or physician identifiers, information about the severity of comorbidities, or information about the aneurysms that were repaired.

Rationale for a volume-outcome relationship for endovascular repair of AAA. There is some evidence of a learning curve for EVAR of AAA. One practice at a tertiary facility analyzed 277 consecutive cases treated from 1994 to 1998 and estimated that approximately 55 cases were required before their technical success rate leveled off at 88 percent.^55^ Custom-made endografts were used in two-thirds of these procedures prior to the availability of commercial bifurcated modular endografts for investigational use in 1997. The surgical team and patient selection criteria remained stable during the period of observation, although it is likely they were not trained to perform EVAR and learned as they were developing new procedures and devices. Thus, their experience should not be extrapolated to current EVAR practices where trained physicians use approved devices with less problematic designs. The same referral practice compared 30 procedures done as part of a clinical trial to 230 cases done after FDA approval of the device. Technical success was achieved in 97 percent and 98 percent of these cases. However, procedural complications such as endoleaks, contrast-induced azotemia, access site hematoma, and limb occlusions increased from 11 percent to 18 percent. The increase in complications was attributed not to poorer proficiency over time, but rather to a greater degree of anatomical and morphological difficulty of the cases being referred and treated after FDA approval.^56^

European registry data were grouped according to cumulative experience in 93 hospitals from 1994 to 2000. The EVAR procedures (n=2,863) were grouped as the first 11 performed at a center, cases 12–37, 38–91, and 92 and higher. Unadjusted mortality after 30 days was the same (3–4 percent) in all four groups.^57^ There were differences in smoking status, vascular morphology, and types of devices used in the four groups with initial patients appearing to have greater risk. Co-morbidity was not reported. The adjusted hazard of death during continued followup was lower in quartiles three and four (i.e., after 38 cases) compared to first quartile representing early experience. The adjusted hazard ratio for secondary interventions for endoleaks, migration, kinking, thrombosis, stenosis, and rupture was lower in all other quartiles compared to the most inexperienced case quartile. The amount of bias present in these comparisons due to differences in patient selection and censoring (initial cases followed much longer) is not clear. A more recent report based on this registry suggested that devices for earlier EVAR procedures might explain the influence of experience on midterm outcomes.^58^ This observation highlights the importance of analyzing data that represent current devices and clinical practices in the United States rather than foreign data on devices that are not being used in the United States.

One should not assume there would be a relationship between EVAR volume and outcome just because there is a learning curve. When development of a new technique is fairly complete, teachers can greatly facilitate learning by experience. Measures of hospital and physician volume typically used in studies are not cumulative counts beginning with initial experience. In fact, volume is often measured during a specified time period ignoring prior experience. Therefore, typical volume measures may reflect a provider's ability to maintain rather than learn skills and effective processes of care. The volume needed to maintain processes of care, skills, and optimal outcomes after a learning curve levels off is not known.

Several randomized controlled trials have required that a certain number of EVAR be done by investigators prior to enrolling patients, but the threshold definitions vary. The EVAR trials required investigator centers to perform at least 20 AAA repair procedures before enrolling patients, whereas investigator teams in the DREAM trial had to have done at least five procedures.^12,^ ^59^ The Veterans Administration Open Versus Endovascular Repair (OVER) trial requires a vascular surgeon or interventional radiologist who has performed at least 12 endovascular procedures.^60^ Thus, investigator experience required for participation in clinical trials has varied. The bases for these volume criteria were not reported.

Analytical issues. Outcome measures that are based on a smaller number of cases (i.e., low volume) exhibit greater random variation. One is less confident that the outcome measured for low volume providers represents their true or long-term performance. A minimum number of cases per provider is sometimes required to help assure the outcome measurements aren't too unreliable. Regression analyses that weight data points by their variance can help avoid placing undue emphasis on outcomes measured in low-volume providers. Regression analyses generally assume that the variation in outcome measures is homogeneous across all levels of a predictor, which is generally not true when volume is used to predict outcomes. Data transformation, such as taking the logarithm of outcome measures, might make this assumption more tenable. Furthermore, the influence of each hospital or physician on the estimated volume-outcome relationship estimated by regression analysis should be examined.

Patients treated at the same hospital or by the same surgeon may be more likely to have similar outcomes than if the patients were treated by different providers. Thus, outcomes might not be truly independent of each other as is assumed by regression analyses that use the patient as the unit of analysis. This so-called clustering with hospitals and physicians reduces variation in outcomes compared to what would be observed with truly independent measurements.

General estimating equations can be used to calculate confidence intervals and p-values that take clustering into account.^61^ This analytical approach is difficult when the outcome data are clustered within more than one variable, e.g., hospital and surgeon volume, and when the size of the clusters, i.e., volume, is correlated with the outcome. In addition, the resulting estimate of relative effects such as an odds ratio is an aggregate or population averaged estimate specific to the mix of clusters in the analysis. Alternatively, random-effects regression models that consider clusters, i.e., hospitals or surgeons, as random variables can account for clustering in the data. Small clusters (low-volume providers) can complicate this approach. Clustering within surgeons and hospitals could be analyzed by hierarchical random-effects models if surgeons don't operate at more than one hospital. If a surgeon(s) represents most of the volume at a hospital, the surgeon and hospital volume will be redundant measures, making it difficult to estimate their separate effects on outcomes. Thus, different methods of analysis of the same data might not produce the same estimate of the effects of volume on outcomes. The method of analysis is an important consideration when comparing studies. Multiple methods of analysis could be employed to see if the results are sensitive to the method of analysis.

The adequacy of risk adjustment is questionable in retrospective studies of databases that did not prospectively collect data on known risk factors. Known risk factors for operative mortality for AAA repairs include the urgency of the operation, presence and severity of renal dysfunction, ischemic heart disease and its treatment with beta-adrenergic blockers and statins, heart failure and chronic obstructive pulmonary disease, advanced age, being female, and several characteristics of the aneurysm such as its diameter and juxtarenal position.^52,^ ^62^ Unmeasured risk factors could be particularly important for low-volume providers. One unrecognized high risk case can greatly affect the outcomes, and if the variable that made the case high risk wasn't measured, the increased risk would not be controlled. Omission of influential covariates can bias estimates of volume-outcome relationships even if they are balanced across groups. Thus, it is important to examine the risk factors that were taken into consideration in analyses.

All studies of the relationship between provider volumes and outcomes used regression models to analyze the data. Therefore, it is important to know how well the model fits the data and how well the model discriminated the outcomes, such as death or survival. A model with poor discrimination suggests that key risk factors were not measured, hence controlled, in the analysis. The c-statistic is commonly used to examine model discrimination. A c-statistic equal to 1 indicates perfect discrimination whereas a value of 0.5 indicates the model was no better than random predictions of outcomes.

### Search Strategy for Pertinent Publications

The MEDLINE® database was searched for publications about volume-outcome relationships for procedures to repair AAA that were published after 1990 when endovascular procedures for repair of AAA became available, at least to investigators. Key words included abdominal aortic aneurysm, volume, outcome, and process assessment health care. Reference lists were searched for additional reports (Figure 2 on page 28).

Figure 2. Flow Chart: Question 2—Volume

### Study Inclusion and Exclusion Criteria

Articles that met the following criteria were reviewed to summarize study methods and characterize volume-outcome relationships.

- The report had to be an original analysis of data representing repair of unruptured AAA in the endovascular era beginning in 1990.
- The report had to represent practices in the United States.
- The sample had to represent variation between hospitals or surgeons in a community or larger geographic area, thereby excluding single site cases series.
- The report had to present sample statistics (e.g., percentages, odds ratios) representing the relationship between a measure of hospital or physician volume and any good or bad outcome associated with AAA repair.
- The analysis had to attempt to make adjustments for known risk factors in an effort to reduce bias.

Health care systems, physician training, clinical care processes, and procedures to repair AAA have evolved, thus older and foreign data might not represent current practices or outcomes in the United States. Since health care practices including patient selection criteria, referral patterns, and types of devices sold outside the United States could differ from the U.S. in important ways, this review was restricted to studies within the U.S. This restriction corresponds with the presumed interests of U.S. insurance companies that requested this evidence review. Furthermore, inclusion of foreign studies would not address the limitations of U.S. studies, would create concern about extrapolating foreign results to the United States, and would not alter the conclusions of this review. More recent recommendations in the United States to seek out higher volume hospitals could be altering the volume-outcome relationships. In addition, adoption of EVAR in recent years most likely has altered the characteristics of cases being surgically repaired, and perhaps the volume-outcome relationship. This review focused on available data that represented practices and outcomes in the United States in the 1990s and beyond.

### Data Extraction

All published analyses regressed an outcome of AAA on retrospectively defined volume measures. A single unblinded reviewer abstracted information from each study to characterize (1) the study population including the time period and geographical region, (2) volume measures, (3) outcome measures, (4) regression model including covariates used for risk adjustment and handling of clustering of patients within hospitals or surgeons, and (5) adjusted and unadjusted estimates of volume effects.

### Data Analysis

The preponderance of evidence for relationships between the volume of procedures performed by hospitals and physicians to repair AAA and outcomes has been obtained by secondary regression analysis of administrative databases. Methodological differences make it difficult to compare results from the different studies. For example, investigators defined hospital and physician volume in a variety of ways, often using arbitrary categorizations with varying reference groups. Use of variables to control for pre-procedure risk (case-mix), physician training, and health care system attributes varied. Analytical methods varied as well. Therefore, we did not attempt to do a meta-analysis to combine estimates from different studies. This review was limited to tabulation of individual study characteristics and results.

Question 3: How do the characteristics of the aneurysm (size/location/shape) and the patient (age/gender) affect the benefits and harms of endovascular and open-surgical repair?

It is not known whether patient, aneurysm, provider, or device characteristics differentially affect treatment success rates. As discussed above, patient factors including age, gender, and comorbidities may not only affect the prevalence and size of AAA but also the risk of AAA rupture and/or operative/EVAR related complications. As noted in Question 1, AAA morphology including size, vascular angulation, size of the aortic neck, and/or involvement of renal or iliac vessels may alter the feasibility of repair options and influence outcomes.

### Literature Search Strategy and Eligibility Criteria

A literature search strategy was conducted similar to question 1 (Figures 1 and 3 on pages 27 and 29). Emphasis was placed on studies that provided comparative effectiveness of one treatment strategy versus another (especially RCT), conducted in the United States, used devices currently available in the United States, and provided information on clinical outcomes according to AAA size, location, shape, patient age, gender, or race. We updated a systematic review by NICE^63^ with emphasis on results from RCTs or studies conducted in the United States.

### Outcomes

Data regarding study, patient, and device characteristics, as well as outcomes, were extracted. Outcomes were described as effectiveness (initial clinical success ≤30 days or during initial hospitalization); short-term (30 days to 6 months), midterm (6 months to 5 years), and long-term (>5 years); and adverse effects based on recommendations for reporting of outcomes for open and EVAR by the Society for Vascular Surgery.^8^ The primary outcome was midterm all-cause mortality. Additional outcomes included initial all-cause mortality, AAA mortality, AAA rupture, quality of life, and technical measures of EVAR, and OSR success. Adverse events included treatment related mortality and morbidity including endoleaks, graft rupture, migration, kinking, and need for additional interventions, including OSR. Specific characteristics of AAA and patient included: 1) AAA size (small <5.5 cm; large ≥5.5 cm), shape (sacular vs. fusiform), extension (into iliacs); 2) patient age (<65 vs. ≥65), race (White, Black, Hispanic, other); gender; and 3) device manufacturer and type.

Quality of studies, reduction of bias, and strength of evidence. We used the methods of Schulz et al. to assess the quality of RCT.7 We attempted to assess whether the effectiveness of interventions varied according to patient, aneurysm, or device characteristics including age, race, gender, EVAR device manufacturer, aneurysm size (<5.5 cm vs. ≥5.5 cm), or aneurysm location. No study quality measures were used for manufacturer submitted data available on the FDA website. We described how patients, AAA, EVAR characteristics, and outcomes compare with those from RCT.

Question 4: What are the costs-benefits for each of the procedures?

From the perspective of cost, different audiences have different concerns. Traditional economic analysis focuses on the cost to the economy of delivering each element of service. However, policy makers may be more interested in the payments they must underwrite than in the economic cost of a procedure. These costs vary somewhat depending on the health care system. For example, in the United States, where Medicare pays for hospital care using a DRG payment approach, differences in the costs of the prosthesis/graft or even in lengths of stay are irrelevant for Medicare because they are all folded into the overall rate paid. However, those differences are very salient to hospitals that must bear them. Likewise in the United Kingdom, working under the National Health System, issues of hospital efficiency are quite important.

The analysis becomes even more complex if a differential survival rate exists across treatments. Unless the results can be expressed in terms like QALYs, which capture both quality of life and survival, the estimated benefit may be exaggerated by comparing quality of life only among survivors.

The classic approach would be to estimate the difference in outcomes across treatments and then divide that by the difference in costs. However, in the case of AAA repair, the outcomes seem to be generally equivalent over the long term. The real difference lies in the short term.

EVAR is considered less invasive and may result in shorter in-hospital and intensive care unit length of stay compared with open repair. However, there are additional costs associated with EVAR. These include the high costs the stent device (which has accounted for over 50 percent of the total in hospital EVAR costs in one analysis) diagnostic cost, primarily because of increased imaging costs with EVAR, and professional fees.^64^ Pre and intraprocedural imaging are more extensive with EVAR than open repair. Because of the concern related to EVAR complications or failures, long term radiologic monitoring is required. The complexities of and recommendations for conducting cost-effectiveness analyses comparing treatment options for AAA have been described.^22,^ ^65^

### Search Strategy Methods

We adopted the search strategy used by the AHRQ report on AAA screening.^22^ Our search was conducted within MEDLINE®. Key search terms included abdominal aortic aneurysm combined with economics, nursing economics, pharmaceutical economics, cost, pharmacoeconomics, cost analysis, cost allocation, cost-benefit analysis, cost control, cost savings, cost of illness, cost sharing, “deductibles and coinsurance,” medical savings accounts, health care costs, direct service costs, drug costs, employer health costs, hospital costs, health expenditures, capital expenditures, hospital economics, hospital charges, hospital costs, medical economics, or medical fees. We focused on studies reporting on the cost associated with either procedure, EVAR, OSR, or both. This strategy yielded 27 articles published between 2000 and 2005. Six of these studies were eliminated from the analyses as they contained less than 50 patients in either arm of the study (i.e., EVAR or OSR).^66^–^71^ Of the remaining 21 articles, 12 reported on a comparative analysis of EVAR and OSR, two reported on EVAR and Conservative Management (CM) (one of which also reported on EVAR and OSR), three on EVAR only, two on OSR and CM, and three on OSR only (Figure 4 on page 30).

Figure 4. Flow Chart: Question 4—Cost