# Introduction

## Overview

An abnormal bulging of the abdominal aorta, called an abdominal aortic aneurysm (AAA) is a potentially serious condition that can lead to death if it ruptures. An AAA is considered present when the maximum diameter of the aorta below the renal arteries (infrarenal AAA) expands to exceed 3.0 cm. In the United States rupture of AAA accounts for approximately 9,000 deaths annually.^1^ Another 30,000–40,000 patients undergo elective surgical repair of asymptomatic AAA to prevent rupture, with perioperative mortality ranging from 2–8 percent.^2,^ ^3^ Death due to AAA rupture or repair is the thirteenth leading cause of death in the U.S. and tenth among older men.^4,^ ^5^

The majority of AAAs remain asymptomatic for years, though the risk of rupture increases with AAA size. Immediate death can result and mortality remains between 40 and 60 percent, even when emergency care and repair are undertaken. Management options are primarily based on patient's life expectancy and AAA size and include no treatment, active surveillance and delayed repair, immediate open surgical repair (OSR), and endovascular repair (EVAR).

Recent recommendations for AAA screening in high-risk populations along with emerging endovascular methods for repair have led to increased interest in evaluating the effectiveness and adverse effects of treatment options for patients with AAA.

Question 1: What are the comparative effectiveness and adverse effects of treatment options of AAA including active surveillance, open repair, and endovascular repair?

Question 2: What is the relationship of volume, both hospital and physician, to the benefits and harms of endovascular procedures to repair AAA?

Question 3: How do the characteristics of the AAA (size/location/shape) and the patient (age/gender) affect the benefits and harms of EVAR and OSR?

Question 4: What are the costs-benefits for each of the procedures?

## Background

The prevalence of AAA found in population-based ultrasound screening studies ranges from 4.2–8.8 percent in men and 0.6–1.4 percent in women.^18^ Risk factors for AAA include age, history of regular smoking, family history of AAA, coronary artery disease, hypertension, hypercholesterolemia, and cerebrovascular disease. The overall prevalence of AAA greater than 3.0 cm in “never smokers” ranges from less than 0.2 percent in ages 50–54 to nearly 3 percent in ages 75–79. For “ever smokers” the prevalence ranges from approximately 1 percent to 7 percent across these age groups. Smoking status is also a risk factor for AAA mortality. Negative risk factors for AAA prevalence include female gender, diabetes, and black race.

In a study of 73,451 mostly male U.S. veterans ages 50–79 who did not have a history of AAA, 7.1 percent had an AAA defined as an infrarenal aortic diameter of ≥3.0 cm on ultrasound. More than 90 percent of AAA were considered small (<5.5 cm) and only 0.4 percent were ≥6.0 cm. With each 1 cm decrease in diameter, the number of AAA of that diameter or larger more than doubled.^19^ Most aneurysms noted at autopsy were small and asymptomatic and therefore did not require intervention during the patient's lifetime. However, the natural history of AAA is progressive enlargement. Non-invasive prevention of growth and rupture is primarily limited to smoking cessation and blood pressure control, though the use of aneurysmal pharmacotherapy has recently received attention.^20^ Because as many as one in three AAA eventually rupture if left untreated^18^ and only 10 to 25 percent of individuals with ruptured AAAs survive through repair, diagnostic and treatment goals are to identify individuals with AAA and target effective treatments possessing low interventional morbidity towards individuals at high risk of rupture.

A recent report from the U.S. Preventive Services Task Force (USPSTF) addressed screening for AAA.^18^ The review identified four good or fair quality population-based AAA screening trials; all conducted outside of the U.S. All trials had ORs favoring an association between an invitation to attend screening and a reduction in AAA-related deaths. Pooled analysis of trials showed a reduction for men in AAA-related mortality (OR, 0.57 [CI 0.45 to 0.74]). The 5-year outcomes of AAA screening by smoking history in a cohort of 100,000 men 65–74 years of age demonstrated that 155 AAA deaths could be prevented by screening and elective OSR 138 (89 percent) in “ever smokers.” Meta-analysis of the trials demonstrated a nonsignificant reduction in all-cause mortality (OR, 0.98 [95 percent CI 0.95, 1.02]). The evidence report and the USPSTF concluded that “population screening for AAA in men ages 65–74 years appears to reduce AAA-related mortality. Treatment is associated with significant risks for operative deaths and complications. These risks, however, may be acceptable to men with AAAs greater than 5.5 cm.”^18,^ ^21^ Additionally, the USPSTF review of four relevant cost-effectiveness studies of AAA screening yielded an estimated cost-effectiveness ratio of population-based screening compared with no screening that was in the range of other cost effective preventive services.^22^ Recommendations for selected screening are likely to lead to increased AAA detection and intervention, particularly of the more prevalent small AAA. Management of AAA will therefore take on increased importance in the future.

The total volume of elective AAA repairs has increased for both OSR and EVAR.^23^ Vascular surgeons who repair AAA utilizing both endovascular and open techniques have experienced an increase in aneurysm referrals, while those who have not adopted endovascular skills have seen a decline.^24^ Practitioners in interventional radiology, cardiovascular surgery, general surgery, and peripheral vascular surgery are receiving training and purchasing the equipment specifically required to perform AAA endografting. These can include attending 1–3 month training courses at a cost of $30,000 and purchasing portable fluoroscopy units that cost approximately $250,000.^24^

Because the risk of rupture is strongly related to AAA size, management options are generally based on AAA size (small <5.5 cm vs. large ≥5.5 cm) and patient's operative risk (medically fit for OSR versus medically unfit) determined by age and comorbidities. OSR has been considered the gold-standard for prevention of AAA rupture and death. However, it has the mortality risk of major vascular surgery with perioperative complications of about 32 percent including myocardial ischemia, respiratory failure, renal failure, ischemic colitis, spinal cord ischemia and prosthetic graft infection, as well as the cost of this procedure.^22^ Therefore, management options that would be equally effective in preventing AAA rupture and prolonging survival, with lower morbidity and similar or reduced health care costs, have been sought.

There are no established criteria for determining acceptable medical fitness for OSR. Because risk factors for AAA include smoking, advanced age, and hypertension, individuals considered candidates for OSR frequently are elderly and have multiple comorbidities including cardiac, pulmonary, or renal disease. Decisions about whether a patient is an acceptable OSR or EVAR candidate are determined by the perioperative team and incorporate the severity as well as the presence of comorbidities, AAA morphology, the individual surgeon/medical center threshold for acceptable medical fitness and assessment of whether outcomes vary according to gender, AAA, or device characteristics.

As reviewed by others,^25^–^27^ several studies have observed that, on average, in-hospital mortality was inversely associated with the number (volume) of AAA OSR procedures done by hospitals. The mortality appeared to be particularly high for very low volume providers decreasing and eventually leveling off as volume increased. Despite substantial improvement in survival, volume continued to be inversely associated with short-term mortality. In-hospital case fatality rates for OSR in Michigan were reduced from 13.6 percent in 1980 to 5.6 percent in 1990.^28^ In California, the in-hospital mortality rate decreased from 11.9 percent to 4.5 percent from 1982 to 1994.^29^ Nevertheless, the volume of procedures done in hospitals continued to be inversely associated with mortality in these studies as was originally observed by Luft et al, who analyzed hospital discharge data from 1974-1975.^30^

Given repeated findings of a relationship between volume and mortality for OSR, one might hypothesize that a volume-outcome relationship exists for EVAR as well. Like OSR, EVAR is a technically demanding procedure with inherent risks. However, volume-outcome relationships vary by type of procedure and are not found for all procedures.^30,^ ^31^ Patient selection criteria, technology, operator skills, and processes of care for endovascular repair differ from open surgical procedures and continue to evolve. Different types of physicians, including interventional radiologists with different training and experience, may be involved in endovascular repairs. As demonstrated elsewhere in this report, short-term mortality is less with EVAR compared to OSR.^6,^ ^32,^ ^33^ Indeed, the 30-day mortality after EVAR now might be less than 2 percent, making it more difficult to detect relationships to hospital or operator volume.

Discussions about cost effectiveness usually begin with a belief that a given approach confers a benefit. The question then is how the cost of achieving that benefit compares to other effects that a similar investment could pay for. Some of the benefits of EVAR appear to occur early in the care process, e.g., fewer complications, reduced hospital length of stay (LOS), etc. Hence they have value primarily where early return to work is crucial. These outcome measures are typically presented as the cost per quality adjusted life year (QALY).

The costs of AAA repair include preoperative costs, hospitalization costs associated with the initial procedure, the costs of the EVAR prosthesis (i.e., graft), and subsequent post operative surveillance, interventions, hospitalizations, and drug treatment. EVAR requires longer term and more intensive monitoring than open repair. OSR of AAA incurs the costs of the surgical team as well as perioperative hospital care. OSR is considered to have greater and more severe early morbidity than EVAR. OSR could result in a longer and more costly length of hospital stay and subsequent greater duration of impaired functional status and quality of life. However, late complications, including rupture, have been rare after open repair. Thus, radiologic, laboratory, and clinician evaluation and costs beyond the perioperative period (approximately 3 months) in the absence of symptoms are minimal.

The main questions in the elective management of AAA are: (1) at what diameter to offer elective repair and (2) do EVAR devices provide a safe and effective treatment option. Additional questions relate to whether outcomes are associated with surgical or medical center volume or OSR or EVAR performed and the relative cost and cost-effectiveness of various options.