# Appendix E: Evidence Tables and Figures

Table E1 Characteristics of elective early/immediate repair versus surveillance of abdominal aortic aneurysm (AAA) randomized controlled trials

Study (Year) / Country Repair Groups (# Randomized) | Mean Study Followup | Methodologic Characteristics | Description of Subjects
ADAM (2004)^1^ / United States | 4.9 years | Randomization: adequate (Schultz) | 1,136 subjects fit for elective surgery were randomized (5,038 considered for randomization, 46% excluded due to AAA larger than 5.4 or severe comorbidities, 23% refused). Subjects were ages 50 to 79 years old, with AAA 4.0 to 5.4 cm. Patients mean age was 68; male 99%; white race 94%; mean AAA diameter 4.7 cm; family history of AAA was 13%; hypertension 56%; diabetes 10%; history of cardiac disease 42%; tobacco use, ever smoked 94%; tobacco use, current smoking 39%.
1. Surveillance (n = 567) | | Criteria for surveillance: ultrasonography or computed tomography every 6 months
2. Immediate surgery (n = 569) | | Criteria for surgery in open group: AAA that became symptomatic or reached ≥5.5 cm
| | Type of graft used: not defined
| | Intention-to-treat analysis: yes (patients were not excluded after randomization)
UK Small Aneurysm Trial (1998)^2^ / United Kingdom | 4.6 years | Randomization: adequate (Schultz) | 1,090 subjects with asymptomatic AAA (non-tender) and were fit for elective surgery were randomized (1,276 eligible for randomization, 15% refused). Subjects were ages 60 to 76 years old, with AAA 4.0 to 5.5 cm. Patients mean age was 69; male 83%; mean AAA diameter 4.6 cm; BMI 25; hypertension 38%; diabetes 3%; ischemic heart disease 40%; tobacco use, ever smoked 94%; tobacco use, current smoking 37%.
1. Surveillance (n = 527) | | Criteria for surveillance: ultrasonography or computed tomography for AAA 4.0 to 4.9 every 6 months, for AAA 5.0 to 5.5 every 3 months
2. Early surgery (n = 563) | | Criteria for surgery in open group: AAA that became symptomatic or reached ≥5.5 cm
| | Type of graft used: prosthetic inlay (92%).
| | Intention-to-treat analysis: yes
Canadian Trial | | No details, trial ended prematurely due to inadequate recruitment | 107 subjects were randomized

Table E2 Cumulative survival according to treatment arm for surveillance versus elective early/immediate repair of abdominal aortic aneurysm (AAA) randomized controlled trials

Group | | Year 0.5 | Year 1 | Year 2 | Year 3 | Year 4 | Year 5 | Year 6 | Year 7 | Year 8
ADAM (extracted from graph, estimated by product-limit method)
Surveillance (n=567) | Survival | | 99% | 95% | 91% | 87% | 82% | 75% | 72% | 69%
| Number at risk | | 552 | 530 | 513 | 393 | 274 | 183 | 76 | -
Immediate repair (n=569) | Survival | | 96% | 93% | 88% | 83% | 78% | 73% | 66% | 61%
| Number at risk | | 545 | 526 | 502 | 383 | 264 | 172 | 67 | -
UK Small Aneurysm Trial (extracted from graph, estimated by Kaplan-Meier method)
Survival up to time of surgery
Surveillance (n=527) | Survival | 99% | 95% | 90% | 84% | 76% | 70%
| Number at risk | 484 | 409 | 292 | 197 | 77 | 29
Immediate repair (n=563) | Survival | 99% | 90% | 86% | 78% | 63% | -
| Number at risk | 91 | 54 | 38 | 32 | 14 | 9
Surveillance (n=527) | Survival | | 90% | 84% | 79% | 70% | 68%
| Number at risk | | 241 | 182 | 117 | 60 | 28
Immediate repair (n=563) | Survival | | 91% | 87% | 83% | 77% | 73%
| Number at risk | | 471 | 448 | 385 | 263 | 149

Table E3 Outcomes and complications for the ADAM, an early/immediate elective repair versus surveillance of abdominal aortic aneurysm (AAA) randomized controlled trial

Outcome | Early/Immediate Repair, n / N (%) | Surveillance Events, n / N (%)
Rupture, repair, and hospitalization outcomes
Repair of AAA, ruptured and unruptured | 527 / 569 (92.6) | 349 / 567 (61.6)
Rupture of AAA | 2 / 569 (<1) | 11 / 567 (1.9)
Other AAA hospitalizations, no. | 255 | 129
Complications of repair or unruptured AAA: mean followup 4.9 years
Operative death within 30 days | 11 / 526 (2.1) | 6 / 340 (1.8)
Operative death within 30 days or hospitalization | 14 / 526 (2.7) | 7 / 340 (2.1)
Number of patients with any complication | 275 / 526 (52.3) | 193 / 340 (56.8)
Rehospitalization for complications | 108 / 526 (20.5) | 56 / 340 (16.5)
Late graft failure | 2 / 526 (0.4) | 1 / 340 (0.3)
Reoperation required | 9 / 526 (1.7) | 4 / 340 (1.2)

Table E4 Health-related quality of life measures for elective early/immediate repair versus surveillance of abdominal aortic aneurysm (AAA) randomized controlled trials

Outcome | Surveillance (n=480), Baseline Mean (SD) | Surveillance (n=399), Mean Score Change 12 Months After Randomization (SD) (p vs. baseline) | Early Surgery (n=512), Baseline Mean (SD) | Early Surgery (n=391), Mean Score Change 12 Months After Randomization (SD) (p vs. baseline) | Early Surgery vs. Surveillance, Mean Change in Scores from Baseline Weighted Mean Difference [95%CI]
UK Small Aneurysm Trial
Short Form 20 Health Survey (SF-20) (subscales 0–100, higher score indicates better quality of life)
Physical functioning | 66.5 (29.3) | -6.2 (25.5)* (<0.05) | 64.2 (30.7) | -3.5 (27.2)* (<0.05) | 2.70 [-0.98 to 6.38]
Role functioning | 76.7 (37.6) | -4.9 (39.7)* (<0.05) | 71.9 (39.5) | -3.9 (36.3)* | 1.00 [-4.30 to 6.30]
Social functioning | 89.8 (20.4) | -2.2 (20.4)* (<0.05) | 89.2 (20.8) | -1.0 (21.2)* | 1.20 [-1.70 to 4.10]
Mental health | 79.5 (17.0) | 0.0 (15.3)* | 80.2 (17.2) | 0.0 (18.2)* | 0.00 [-2.35 to 2.35]
Health perceptions | 62.4 (24.6) | -1.0 (22.4)* | 62.4 (24.3) | 5.7 (24.2)* | 6.70 [3.45 to 9.95]
Bodily pain | 64.3 (32.1) | -4.7 (36.7)* (<0.05) | 64.1 (31.5) | -1.0 (35.3)* | 3.70 [-1.32 to 8.72]

* estimated from confidence intervals

Table E4a Health-related quality of life measures for elective early/immediate repair versus surveillance of abdominal aortic aneurysm (AAA) randomized controlled trials

Time Interval, Years After Randomization | Surveillance, %* Vigorous (# Patients) | Surveillance, %* Moderate (# Patients) | Surveillance, %* Mild (# Patients) | Surveillance, %* Sedentary (# Patients) | Early Repair, %* Vigorous (# Patients) | Early Repair, %* Moderate (# Patients) | Early Repair, %* Mild (# Patients) | Early Repair, %* Sedentary (# Patients)
ADAM Trial, Maximum activity, Surveillance (SURV) vs. Early Repair (ER)
Baseline
SURV n=566 | 14 | 50 | 34 | 2 | 11 | 50 | 36 | 3
ER n=568
1 year
SURV n=521 | 11 | 44 | 37 | 8 | 12 | 43 | 39 | 6
ER n=492
2 years
SURV n=483 | 13 | 42 | 34 | 11 | 10 | 41 | 41 | 8
ER n=458
3 years
SURV n=446 | 8 | 39 | 44 | 9 | 8 | 39 | 44 | 9
ER n=423
4 years
SURV n=333 | 5 | 41 | 42 | 12 | 7 | 38 | 45 | 12
ER n=317
5 years
SURV n=223 | 8 | 39 | 43 | 10 | 5 | 35 | 47 | 13
ER n=208
6 years
SURV n=149 | 4 | 36 | 43 | 17 | 2 | 30 | 44 | 24
ER n=132
7 years
SURV n=60 | 2 | 34 | 47 | 17 | 3 | 20 | 54 | 23
ER n=55
7.5 years ** | 11 | 26 | 52 | 11 | 4 | 25 | 50 | 21
Maximum activity level did not differ significantly between treatment groups at repeated measure analysis. There was a significant interaction between treatment and followup time (p <0.02) indicating that worsening of maximum activity was greater in the early repair group.

* estimated from graph

** final assessment

Table E5 Characteristics of endovascular repair (EVAR) versus OSR of abdominal aortic aneurysm (AAA) randomized controlled trials

Study (Year) / Country Repair Groups (# Randomized) | Study Outcome Interval | Methodologic Characteristics | Inclusion Criteria and Description of Subjects
DREAM (2004)^3^ / Netherlands and Belgium | 30 days and 2 years | Randomization: adequate (Schultz)^4^ - computer-generated permuted block sequence | 351 subjects anatomically suitable (non-symptomatic infrarenal AAA ≥5.0 cm) for EVAR were randomized. 345 (98%) intention-to-treat (ITT) subjects were included in analyses. 4 declined and 2 died prior to AAA repair.
1. EVAR (n = 173) | | Experience: Surgeons and radiologists at each center were required to have performed ≥20 EVAR procedures (fewer than 20 required presence of experienced proctor) complying with guidelines issued by Endovascular Safety Committee of the Dutch Society for Vascular Surgery and Dutch Society for Radiology | Patients had adequate infrarenal neck and other aortoiliac anatomical configuration suitable for EVAR and a life expectancy ≥2 years
2. Open repair (n = 178) | | Intention-to-treat analysis: yes | Exclusion criteria included juxtarenal or suprarenal AAA, inflammatory AAA (more than wall thickening), bilateral retroperitoneal incision required, sacrifice of both hypogastric arties, various anatomical variations (i.e., horseshoe-kidney, arteries requiring reimplantation), patient unsuitable for laparotomy
| | Sponsor's role in study: none | Characteristics: 92% men; mean age 70; AAA diameter ≥5.0 cm (mean 6.0), range was 5.4 to 6.5 cm; BMI 26.4; diabetes 10%; hypertension 56%; cardiac disease 44%; carotid artery disease 14%; hyperlipidemia 50%; tobacco use 59%
| | Grafts used: Zenith 33%; Talent 27%; Excluder 22%; Others 18%
EVAR-1 (2005)^5^ / United Kingdom (34 hospitals) | 30 days and 4 years | Randomization: adequate (Schultz)^4^ - 50:50 ratio randomly permuted block sizes constructed by STATA package | 1,082 subjects, ≥60 years age, with an AAA ≥5.5 cm judged anatomically suitable for EVAR were randomized. 1,047 (97%) ITT subjects were included in the analyses. 8 declined, 3 postponed surgery and 24 died prior to AAA repair.
1. EVAR (n = 543) | | Experience: Each participating center must have performed ≥20 EVAR procedures according to the UK registry for endovascular treatment of aneurysms (RETA) | Recommended guidelines for patient fitness for open repair and suitability for EVAR-1 or 2 were defined as: no MI ≤3 months, onset of angina ≤3 months, unstable angina at night/at rest, severe valve disease, significant arrhythmia, or uncontrolled CHF
2. Open repair (n = 539) | | Intention-to-treat analysis: yes | Open repair would not be recommended for subjects with the following: unable to walk flight of stairs without shortness of breath; FEV_1_ <1.0 L; PO_2_ < 8.0 KPa; PCO_2_ >6.5 KPa; creatinine 200μmol/L
| | Sponsor's role in study: none | Characteristics: 91% men; mean age 74; AAA diameter ≥5.5 cm (mean 6.5); BMI 26.4; diabetes 10%; history of cardiac disease 43%; current smokers 21%; ever smoked 91%; aspirin use 53%; statin use 33%
| | Grafts used: Zenith 51%; Talent 33%; Others 16%. Participating centers were free to choose which commercial or in-house devices to use. Use of commercially available devices having undergone certain safety checks was favored. 90% were tubular or bifurcated and the remainder were aortouniiliac
Cuypers (2001)^6^ / Netherlands | 30 days | Randomization: treatment allocation concealment unclear. A 3:1 ratio for EVAR and OSR was used to increase the experience of the team involved with EVAR and it was also expected that this randomization scheme would increase enrollment to the trial with the greater probability of being allocated to EVAR. | 76 subjects with anatomically suitable AAA >5.0 cm for EVAR were randomized.
1. EVAR (n = 57) | | Experience: Unclear/not discussed | Exclusion criteria included subjects with adverse aneurysm morphology for EVAR, a contrast allergy and/or medical conditions precluding open surgery.
2. Open repair (n = 19) | | Intention-to-treat analysis: yes | Characteristics: 92% men; mean age 69 (range 52–82); AAA mean 5.5, (mean for EVAR was 5.6 (range 5.2 to 8.4) and 5.2 for OSR (range 4.0 to 6.1)); diabetes 16%; hypertension 43%; coronary artery disease 46%; history of myocardial infarction 33%; previous CABG 24%; previous PTCA 12%; COPD 28%.
Note: Study's objective was to compare cardiac response between EVAR and OR. Cardiac complications were assessed at 1 hour, day 1, day 7, and day 30 after procedure. | | Sponsor's role in study: unclear
Outcome assessor was blinded to treatment allocation. | | Grafts used: AneuRx (Medtronic)
OVER (Frank Lederle, Personal communication) United States (40 centers) | Up to 8 years | Randomization: adequate (Schultz)^4^ - computer generated random numbers | Male and female patients (n=1,260 estimated to be needed) with abdominal aortic aneurysms will be eligible for enrollment if they meet each of the following inclusion criteria: 1) AAA ≥5.0 cm or 2) an iliac aneurysm (associated with an AAA) with a maximum external diameter in any plane of ≥3.0 cm or AAA ≥4.5 cm, if the AAA: a) has increased by 0.7 cm in diameter in 6 months or 1.0 cm in 12 months, as measured from two imaging studies (ultrasound, CT scan, or MRI) within the appropriate interval, the later one within 6 months of randomization, b) is saccular (i.e., a portion of the circumference of the aorta at the level of the aneurysm is considered normal based on CT scan or MRI), or c) is associated with distal embolism.
1. EVAR | | Experience: participating investigators must have expertise in open surgery and EVAR and be approved by a study review committee | Patients with any of the following will be excluded from the study: 1) previous abdominal aortic surgery; 2) evidence, by imaging test, of AAA rupture; 3) AAA repair is not elective (i.e., urgent or emergent operation, usually due to suspected rupture); or 4) inability or unwillingness to give informed consent or follow study protocol
2. Open repair | | Intention-to-treat analysis: yes
| | Sponsor's role in study: solely funded by the Department of Veterans Affairs Cooperative Studies Program
| | Grafts used: FDA-approved EVAR systems, including ANCURE (Guidant) and AneuRx (Medtronic). Choice of graft to be used will be made prior to randomization by the individual investigator based on that physician's assessment of what graft would be optimal for that patient.
ACE | Up to 5 years | Randomization: unclear | Male and female patients (n=600 estimated to be needed) >50 years of age with abdominal aortic aneurysms ≥5.0 cm with the meeting the following anatomical criteria: 1) healthy upper aneurysmal neck ≥1.5 cm; 2) end of the aneurysmal process ≥1.5 cm proximal to one of the common iliac bifurcation; 3) no significant superior mesenteric artery stenosis; 4) an angle less or equal to 80% of the iliac arteries and aneurysmal neck; or 5) external iliac arteries greater than 6 mm in diameter
France (32 centers to date) Randomization started 01/2003 | | Experience: Surgeons and radiologists at each center were required to have performed ≥10 EVARs | Patients with severely angulated, heavy calcified, thombotic or aneurysmal upper neck and with aneurysms involving both hypogastric arteries will be excluded
1. EVAR | | Intention-to-treat analysis: yes
2. Open repair | | Sponsor's role in study: unclear (sponsored by the Programme Hopitalier de Recherche Clinique, section of the Ministry of Health)
| | Grafts used: commercially available devices having undergone certain safety checks were favored

Table E6 Kaplan-Meier estimates of mortality and complications or severe events according to treatment arm for endovascular repair (EVAR) versus OSR of abdominal aortic aneurysm (AAA) randomized controlled trials

Group | | Year 1 | Year 2 | Year 3 | Year 4
1. All-cause mortality
EVAR-1 (extracted from graph)
EVAR (n=543) | Proportion dying | 8% | 15% | 22% | 26%
| Number at risk | 503 | 316 | 187 | 94
OSR (n=539) | Proportion dying | 10% | 16% | 22% | 29%
| Number at risk | 484 | 314 | 195 | 88
DREAM (extracted from graph)
EVAR (n=171) | Proportion dying | 3.5% | 10.3% | NR | NR
| Number at risk | 163 | 98
OSR (n=174) | Proportion dying | 7% | 10.4% | NR | NR
| Number at risk | 160 | 97
2. Aneurysm-related mortality
EVAR-1(extracted from graph): (defined as death within 30 days of any surgery for AAA unless overruled by post-mortem findings or if a separate procedure (unrelated to the aneurysm) took place between aneurysm and death and was attributed as the death. Death with underlying cause attributed to ICD10 codes 1713–19 were also classified as aneurysm-related)
EVAR (n=543) | Proportion dying | 2% | 3% | 4% | 4%
| Number at risk | 503 | 316 | 187 | 94
OSR (n=539) | Proportion dying | 6% | 6% | 7% | 7%
| Number at risk | 484 | 314 | 195 | 88
3. Complications / severe events
EVAR-1(extracted from graph): Complications (C): Included primarily graft ruptures, graft infections, endoleaks (EVAR specific), graft thrombosis, other surgery required, re-exploration of open repair
EVAR (n=543) | Proportion with C | 25% | 30% | 36% | 41%
| Number at risk | 386 | 235 | 134 | 67
OSR (n=539) | Proportion with C | 5% | 5% | 7% | 9%
| Number at risk | 466 | 301 | 182 | 82
DREAM(extracted from graph): Severe events (SE): not defined, classified and graded according to the reporting standards of the Ad Hoc Committee for Standardized Reporting Practices in Vascular Surgery/International Society for Cardiovascular Surgery
EVAR (n=171) | Proportion with SE | 12% | 16.9% | NR | NR
| Number at risk | 151 | 91
OSR (n=174) | Proportion with SE | 15% | 19.4% | NR | NR
| Number at risk | 146 | 89

Table E7 Characteristics of the EVAR 2 Trial (n=338), endovascular repair (EVAR) versus no intervention of abdominal aortic aneurysm (AAA)

Study (Year) / Country Repair Groups (# Randomized) | Study Outcome Interval | Methodologic Characteristics | Inclusion Criteria and Description of Subjects
EVAR-2 (2005)^7^ / United Kingdom (31 hospitals) | 30 days | Randomization: adequate (Schultz).^4^ 50:50 ratio randomly permuted block sizes constructed by STATA package | 338 subjects, (60 years age, with AAA diameter ≥5.5 cm considered unfit (determined locally by surgeon, radiologist, anesthesiologist, and cardiologist) for major surgery were randomized. Recommended guidelines for patient unfitness for open repair and unsuitability for EVAR 1 were defined as: MI ≤3 months; onset angina ≤3 months; unstable angina at night/at rest; severe valve disease; significant arrhythmia; uncontrolled CHF. In addition, open repair (EVAR 1) would not be recommended for subjects with the following: unable to walk flight of stairs without shortness of breath; FEV_1_ <1.0 L; PO_2_ <8.0 KPa; PCO_2_ >6.5 KPa; creatinine 200μmol/L. In the EVAR group 1 subject declined, 1 was deemed unsuitable and 14 died prior to AAA repair. No subjects were lost to followup. In the No Intervention group, 1 subject was lost to followup.
1. EVAR (n = 166) | | Experience: Each participating center must have performed ≥20 EVAR procedures according to the UK registry for endovascular treatment of aneurysms (RETA) | Characteristics: 85% men; mean age 76.4; AAA diameter mean 6.3 [IQR* 6 to 7.4]; AAA tender at randomization 4%; BMI 26.3; diabetes 14%; history of cardiac disease 69%; current smokers 17%; ever smoked 93%; aspirin use 56%; statin use 39%
2. No Intervention (n = 172) | | Intention-to-treat analysis: yes
| | Sponsor's role in study: none
| | Grafts used: Zenith 59%; Talent 21%; Excluder 7%; AneuRx 6%; Others 7%. Participating centers were free to choose which commercial or in-house devices to use. Use of commercially available devices having undergone certain safety checks was favored. 87% bifurcated systems.

* IQR = Interquartile range

Table E8 Complications for EVAR-2 trial (n=338), endovascular repair (EVAR) versus no intervention of abdominal aortic aneurysm (AAA)

Outcome | Events, n / N | %
Number of patients with postoperative complications
All subjects having a successful EVAR* | 58 / 178 | 32.6
Endoleak, type 1 | 10 / 178 | 5.6
Endoleak, type 2 | 17 / 178 | 9.6
Endoleak, type 3 | 5 / 178 | 2.8
Graft rupture | 1 / 178 | < 1
Graft migration | 2 / 178 | 1.1
Graft thrombosis | 7 / 178 | 3.9
Other surgery required | 8 / 178 | 4.5
Number of patients with reintervention
All subjects having a successful EVAR* | 32 / 178 | 18.0
Endoleak, type 1 | 8 / 178 | 4.5
Endoleak, type 2 | 3 / 178 | 1.7
Endoleak, type 3 | 3 / 178 | 1.7
Graft rupture | 1 / 178 | < 1
Graft migration | 0 | 0
Graft thrombosis | 5 / 178 | 2.8
Other surgery required | 8 / 178 | 4.5

* Includes 12 subjects randomized to no intervention

Table E9 Health-related quality of life measures for the EVAR-2 trial (n=338), endovascular (EVAR) versus no intervention of abdominal aortic aneurysm (AAA)

Outcome | EVAR, Mean (SD) (number of patients) | No Intervention, Mean (SD) (number of patients) | Weighted Mean Difference [95% CI] | Difference Adjusted for Baseline Score, Mean (SE) (number of patients)
EQ5D weighted index score (higher score indicates better quality of life)
Baseline | 0.58 (0.31) 164 | 0.63 (0.28) 171 | -0.05 (SE 0.03) Crude difference | EVAR-2^1^
0–3 months | 0.57 (0.28) (48) | 0.56 (0.29) (92) | 0.01 [-0.09 to 0.11] | 0.03 (0.05) (139) (p = 0.51)
3–12 months | 0.64 (0.28) (122) | 0.60 (0.26) (120) | 0.04 [-0.03 to 0.11] | 0.06 (0.03) (241) (p = 0.06)
12–24 months | 0.65 (0.24) (88) | 0.60 (0.30) (68) | 0.05 [-0.04 to 0.14] | 0.04 (0.04) (156) (p = 0.30)
SF-36: Physical component summary (higher score indicates better quality of life)
Baseline | 35.47 (6.63) (160) | 35.12 (6.23) (171) | 0.35 (SE 0.71) Crude difference | EVAR-2^7^
0–3 months | 33.96 (5.13) (46) | 35.60 (5.70) (89) | -1.64 [-3.54 to 0.26] | -1.86 (0.88) (134) p = 0.04
3–12 months | 34.33 (6.10) (116) | 35.12 (6.42) (111) | -0.79 [-2.42 to 0.84] | -1.11 (0.77) (224) p = 0.15
12–24 months | 34.54 (5.89) (71) | 36.01 (6.92) (60) | -1.47 [-3.69 to 0.75] | -0.64 (1.04) (130) p = 0.54
SF-36: Mental component summary (higher score indicates better quality of life)
Baseline | 45.13 (7.92) (160) | 46.31 (6.97) (171) | -1.18 (SE 0.82) Crude difference | EVAR-2^7^
0–3 months | 45.76 (8.65) (46) | 44.03 (7.78) (89) | 1.73 [-1.25 to 4.71] | 2.30 (1.38) (134) (p = 0.10)
3–12 months | 44.76 (7.21) (116) | 44.84 (7.85) (111) | -0.08 [-2.04 to 1.88] | 0.94 (0.95) (224) (p = 0.32)
12–24 months | 45.36 (7.20) (71) | 44.67 (7.93) (60) | 0.69 [-1.92 to 3.30] | 0.50 (1.29) (130) (p = 0.70)

Table E10 Postoperative 30-day mortality for endovascular (EVAR) versus open surgical repair (OSR) of abdominal aortic aneurysm (AAA) nonrandomized controlled trials, and registries

Trials | EVAR Events, n / N (%) | OSR Events, n / N (%) | Risk Difference, % [95% CI] | Relative Risk [95% CI]
Anderson/SPARCS*^8^ | 19 / 1706 (1.1) | 121 / 3063 (4.0) | -3 [-4 to -2] | 0.28 [0.17 to 0.46]
Becquemin^9^ | 2 / 73 (2.7) | 2 / 107 (1.9) | 1 [-4 to 5] | 1.47 [0.21 to 10.17]
Bertrand^10^ | 6 / 193 (3.1) | 12 / 193 (6.2) | -3 [-7 to 1] | 0.50 [0.19 to 1.31]
Bolke^11^ | 0 / 20 | 1 / 20 (5.0) | -5 [-18 to 8] | 0.33 [0.01 to 7.72]
Criado^12^ | 1 / 240 (< 1) | 0 / 126 | 0 [-1 to 2] | 1.58 [0.06 to 38.53]
Elkouri^13^ | 0 / 94 | 3 / 261 (1.1) | -1 [-3 to 1] | 0.39 [0.02 to 7.56]
Garcia-Madrid^14^ | 2 / 53 (3.8) | 2 / 30 (6.7) | -3 [-13 to 7] | 0.57 [0.08 to 3.82]
Greenberg^15^ | 1 / 200 (<1) | 2 / 80 (2.5) | -2 [-6 to 2] | 0.20 [0.02 to 2.17]
Hansman^16^ | 1 / 50 (2.0) | 0 / 50 | 2 [-3 to 7] | 3.00 [0.13 to 71.92]
Jordan^17^ | 6 / 259 (2.3) | 12 / 145 (8.3) | -6 [-11 to -1] | 0.28 [0.11 to 0.73]
Lee**^18^ | 33 / 2565 (1.3) | 176 / 4607 (3.8) | -3 [-3 to -2] | 0.34 [0.23 to 0.49]
LIFELINE Registry†^19^ | 45 / 2664 (1.7) | 4 / 334 (1.2) | 0 [-1 to 2] | 1.41 [0.51 to 3.90]
Teufelsbauer^20^ | 7 / 275 (2.5) | 23 / 481 (4.8) | -2 [-5 to 0] | 0.53 [0.23 to 1.22]
Zeebregts^21^ | 1 / 92 (1.1) | 15 / 194 (7.7) | -7 [-11 to -2] | 0.14 [0.02 to 1.05]
Totals | 124 / 8484 (1.5) | 383 / 9691 (3.8) | -2 [-3 to -2] | 0.37 [0.29 to 0.47]

* Data from discharge dataset: New York State-Statewide Planning and Research Cooperative System (SPARCS)

** Data from National Inpatient Sample (NIS) database, representing 20% of all-payer stratified sample of nonfederal U.S. hospitals

† Clinical data from four Investigational Device Exemption clinical trials including Carpenter^22^ (Matsamura^23^ and Moore^24^ studies)

Table E11 Mortality following EVAR: Data from nonrandomized clinical trials (non-device specific), case series, and comparative studies

Author (Reference) | Number of Patients | | | | Followup (Months)
| Undergoing EVAR | Number of Deaths (%) | 30-Day Deaths* (%) | AAA-Related Deaths (%) | Mean (Range)
Resch 2002^25^ | 164 | NR | 7 (4.3) | NR | 39 (NR)
Haulon 2003^26^ | 96 | 13 (13.5) | 2 (2.1) | 0 | 27 (3 to 66)
Burks 2002^27^ | 95 | 2 (2.1) | 2 (2.1) | 0 | 25 (6 to 44)
Cartes 2002^28^ | 72 | 1 (1.4) | 1 (1.4) | 1 (1.4) | 22 (1 to 46)
Alric 2002^29^ | 88 | 24 (27.3) | 3 (3.4) | 6 (6.8) | 21 (6 to 68)
Flora 2003^30^ | 108 | 11 (10.2) | 9 (8.3) | 2 (peri-op) + 2 after OSR | 20
García-Madrid** 2004^14^ | 53 | 5 (9.4) | 2 (3.8) | 0 | 19 Median
Zeebregts 2004**^21^ | 93 | 11 (11.8) at 2 years | 1 (1.1) | 0 | 19
Gilling-Smith 2000^31^ | 55 | 8 (14.5) | NR | 2 graft -related | 18 (3 to 36)
Ohki 2001^32^ | 239 | Unclear(53 of unrelated causes) | 20 (8.4) | Unclear(3 after second intervention) | 16 (<75)
Parlani 2002^33^ | 336 | NR | 4 (1.2) | 0 (peri-op) | 14 (1 to 46)
Faries 2002^34^ | 65 | 11 (16.9) | 0 | 0 | 13 (6 to 48)
Tutein Nolthenius 2001^35^ | 77 | 15 (19.5) | 4 (5.2) | 0 | 12 (>12)
Carpenter 2004^22^ | 227 | 15 (6.6) | 3 (1.3) | 1 | 11 (0 to 41)
Ricco 2003^36^ | 1012 | 47 (4.6) | 27 (2.7) | NR | 11 NR
Becquemin 2000**^9^ | 73 | 7 (9.6) | 2 (2.7) | 2 possibly graft-related | 7 (0 to 40)
May 2000^37^ | 266 | NR | NR | NR | 6(>6)
Blum 2001^38^ | 298 | 3 (1.0) | 2 (<1) | 2 (<1) | (2 to 50)
Albertini 2001^39^ | 185 | 12 (6.5) | 12 (6.5) | 6 (3.2) | NR
Bertrand 2001**^10^ | 193 | 6 (3.1) | 6 (3.1) | Unclear | Postoperative period
Bölke 2001**^11^ | 20 | 0 | 0 | 0 | NR
Elkouri 2004**^13^ | 94 | NR | 0 | NR | NR, postoperative mortality only
Ouriel 2003^40^ | 704 | 20% men | 11 (1.6) | 3.1% men | NR
| | 22% women at 24 months | | 1.8% women at 24 months
Teufelsbauer 2003**^20^ | 275 | NR | 7 (2.5) | NR | NR postoperative mortality only
Total | 4,888 | | 125 (2.6) | 0 to 6.8 | Postoperative to 39

* ≤30 days after procedure

** 30-day mortality versus control (open repair) in Appendix E, Table E10

NR = Not reported

Table E12 Mortality following EVAR: Data from registries and device-specific non-randomized clinical trials (NRCTs)

Author (Reference) | Number of Patients | | | | Followup (Months)
| Undergoing EVAR | Number of Deaths (%) | 30-Day Deaths* (%) | AAA-Related Deaths (%) | Mean (Range)
RETA database (n=1,000)
Thomas 2005^41^ | 1,000 | 11% year 1 (post-procedure) | 57 / 989 (5.8) | 6 deaths year 1 (post-procedure) | 36 (1 to 60)
| | 10% year 2
| | 7% year 3
| | 10% year 4
| | 8% year 5
Lifeline database (n=2,664): Pooled data from 4 NRCTs
Lifeline 2005†^19^ | 2,664 | 603 (22.6) up to 6 years | 45 (1.7) | 56 (2.1) | 34 (up to 80)
Powerlink | 192 | 20 (10.4) | 2 (1.0) | 1 (<1) | 22
Carpenter 2004^22^
Excluder | 235 | 33 (14.0) | 2 (1.0) | 0 from AAA rupture | 24
Matsumura^23^
Ancure (n=305) and EGS (n=268); Moore 2003^24^ | 573 | 73 / 319 (22.9) | 10 (1.7) | 0 / 319 | 5-year update (1 to 60)
| | Subjects selected for long-term followup** | Ancure 3/305 (1.0%)
| | | EGS 7/268 (2.6%)
AneuRx | 1,193 | 250 (21.0) | 22 (1.8) | 30 (2.5) | 6-year update
Zarins 2003^42^
Eurostar database (n=4,613): No mortality data in most recent publication^43^
Laheij 2002^44^ | 2,863 | 257 (9.0) | 85 (3.0) | 0 | NR
Laheij 2000^44^ | 2442, 245 unfit for surgery and 97 unfit for general anesthesia (GA) | 56 unfit for surgery and GA died during followup vs. 157 fit | 78 (3.2), 15 unfit for surgery (6%) and 4 unfit for GA (4%) | 1 rupture death (unclear if patient was fit or unfit) | 12
Data from discharge dataset: New York State-Statewide Planning and Research Cooperative System (SPARCS)
Anderson 2004†^8^ | 1,706 | NR | 19 (1.1) | NR
Data from National Inpatient Sample (NIS) database, representing 20% of all-payer stratified sample of non-federal U.S. hospitals
Lee 2004†^18^ | 2,565 | 33 (1.3) | 33 (1.3) | NR | Postoperative period
Data from University of Alabama-Birmingham vascular registry, “high” vs. “low” risk subjects
Jordan 2003†^17^ | 259 | NR | 6 (2.3) high | 0 | 28
| 130 high | | 0 low
| 129 low
AneuRx Clinical Trial (n=1,193): Data from 19 investigational centers
Zarins 2003^42^ | See Lifeline above for data on all subjects
Zenith Clinical Trial (n=200)
Greenberg 2004†^15^ | 200 | 7 (3.5) at 12 months | 1 (0.5) | 1 (0.5) at 12 months | NR
Talent Clinical Trial (n=471)
Criado 2001†^45^ | 471 | 8 / 462 (1.7) | 8 / 462 (1.7) | 1 reported | Postoperative period

* ≤30 days after procedure

** Based on implantation date; i.e., the earliest implantations were followed for 5 years.

† 30-day mortality versus control (open repair) in Appendix E, Table E-10

NR = Not reported

Table E13 Early (<30 days post-procedure) and delayed (>30 days post-procedure) aneurysm rupture following EVAR: Data from registries, nonrandomized studies, case series, and comparative studies

Author (Reference) | Number of Patients | | | Followup (Months)
| Undergoing EVAR | With Early Rupture (%) | With Delayed Rupture (%) | Mean | Range
RETA | 1,000 | 2 (0.2) | 6 deaths year 1 post-procedure (0.6) | At year 1 | NA
Thomas 2005^41^
LIFELINE 2005^19^ | 2,664 | 3 (0.1) | 15 (0.6) | 72* | NR
4 NRCTs (below)
Powerlink | 192 | 0 | 0 | 22 | NR
Carpenter 2004^22^
Excluder | 235 | 0 | 0 | 2-year update | 24
Matsumura 2003^23^
Ancure (n=305) and EGS (n=268) Moore 2003^24^ | 319 | 0 | 0 | 5-year update | 1 to 60
AneuRx | 1,193 | 3 (0.3 | 15 (1.3) | 6-year update | NR
Zarins 2003^42^
Eurostar | 2,863 | 1 / 2,442 (Laheij 2000) | 16 (0.6) | NR | NR
Laheij 2002^44^
Talent | 190 | NR | 0 | 13 | NR
Criado 2003^12^
Albertini 2001^39^ | 185 | 3 (1.6) | NR
Alric 2002^29^ | 88 | NR | 2 (2.2) | 21 | 6 to 68
Becquemin 2000^9^ | 73 | NR | 0 | 7 | 0 to 40
Blum 2001^38^ | 298 | 1 (0.3) | 4 (1.3) | 35 | 2 to 50
Burks 2002^27^ | 95 | NR | 0 | 25 | 6 to 44
Carpenter 2004^46^ | 227 | 2 (0.9) | NR
Cartes 2002^28^ | 72 | NR | 0 | 22 | 1 to 46
Elkouri 2003^47^ | 100 | NR | 1 (1) | 7 | 1 to 60
Faries 2002^34^ | 74 | 0 | 0 | 13 | 6 to 48
Flora 2003^30^ | 108 | NR | 0 | 20 | NR
Gilling-Smith 2000^31^ | 55 | NR | 1 (1.8) | 18 | 3 to 36
Moore 2003^24^ | 684 | NR | 0 | NR | 1 to 60
Tutein Nolthenius 2001^35^ | 77 | NR | 0 | 12 | >12
Ohki 2001^32^ | 239 | NR | 2 (0.8) | 16 | <75
Ouriel 2003^40^ | 704 | 1 (0.1) | 3 (0.4) | NR | NR
Parlani 2002^33^ | 336 | see Zannetti | 2 (0.6) | 14 | 1 to 46
Ricco 2003^36^ | 1,012 | 2 (0.1) | NR
Zannetti 2001^48^ | 240 | 1 (0.4) | NR
Total (%) | | 16 / 8,772 (0.2) | 52 / 9,720 (0.5) | 7 to 72

* Unclear, studies were to have a minimum of 5-year followup. Kaplan-Meier analyses were done at 6 years

NR = Not reported

Table E14 Primary (immediately following a failed EVAR or <30 days post-procedure) and delayed (secondary or >30 days post-procedure) conversion to OSR following EVAR: Data from registries, nonrandomized studies, case series, and comparative studies

Author (Reference) | Total Number of EVAR | Conversions | | Followup (Months)
| | Primary n (%) | Delayed n (%) | Mean | Range
RETA | 1,000 | 33 / 996 (3.3) | 23 (2.3) | 36 | 1 to 60
Thomas 2005^41^
Lifeline 2005^19^ | 2,664 | 68 (2.6) | 28 / 2524 (1.1) | 72* | NR
Powerlink | 192 | 3 (1.6) | 1 / 190 (0.5) | 22 | NR
Carpenter 2004^22^
Excluder | 235 | 0 | 3 (1.3) | 2-year update | 24
Matsumura 2003^23^
Ancure (n=305) and EGS (n=268); Moore 2003^24^ | 573 | 42 (7.3) 16 Ancure | 8 / 319 | 5-year update | 1 to 60
| | (5.2) 26 EGS (9.7) | (2.5)
AneuRx | 1,193 | 11 (0.9) | 38 (3.2) | 6-year update | NR
Zarins 2003^42^
Eurostar | 2,862 | 47 (1.6) | 41 (1.4) | 12 | 0 to 72
Vallabhaneni 2001^49^
Talent | 240 | NR | 5 (2.1) | 13 | NR
Criado 2003^12^
Albertini 2001^39^ | 185 | 2 (1.1) | NR
Alric 2002^29^ | 88 | 1 (1.1) | 3 (3.4) | 21 | 6 to 68
Becquemin 2000^9^ | 73 | NR | 3 (4.1) | 7 | 0 to 40
Bertrand 2001^10^ | 193 | 6 (3.1) | NR
Blum 2001^38^ | 298 | 5 (0.8) | 8 (2.7) | 35 | 2 to 50
Carpenter 2004^46^ | 227 | 3 (1.3) | 2 (0.9) | 11 | 0 to 41
Elkouri 2003^47^ | 100 | 3 (3.0) | 1 (1) | 7 | 1 to 60
Faries 2002^34^ | 65 | NR | 2 (3.1) | 13 | 6 to 48
Flora 2003^30^ | 108 | 11 (10.0) | 3 (2.8) | 20 | NR
2 groups (early vs. late) | 26 early / 82 late | 7 (27.0) / 4 (4.5)
Gilling-Smith 2000^31^ | 55 | NR | 1 (1.8) | 18 | 3 to 36
Hansman 2003^16^ | 50 | 0 | 1 (2) | NR | NR
May 2000^37^ | 266 | 17 (6.4) | NR
Tutein Nolthenius 2001^35^ | 77 | 2 (2.6) | NR
Ohki 2001^32^ | 239 | NR | 5 (2.1) | 16 | < 75
Ouriel 2003^40^ | 700 | 3 (0.4) | 29 (4.1) | 12 | NR
Parlani 2002^33^ | 336 | 6 (1.8) | 4 (1.2) | 14 | 1 to 46
Resch 2001^50^ | 164 | 8 (4.9) | 15 (9.1) | 39 | NR
2 groups (early vs. late) | 90 early / 68 late | 8 (8.9) / 0
Ricco 2003^36^ | 1,012 | 11 (1.1) | 4 (0.4) | 11 | NR
Zannetti 2001^48^ | 266 | 6 (2.3) | NR
Total | | 233 / 10,832 (2.2) | 178 / 10,141 (1.8) | 7 to 72

* Unclear, studies were to have a minimum of 5-year followup. Kaplan-Meier analyses were done at 6 years

NR = Not reported

Table E15 Secondary intervention following EVAR: Data from registries, nonrandomized studies, case series, and comparative studies

Author (Reference) | Total Number of EVAR | Secondary Interventions | | Followup (Months)
| | Number | % | Mean | Range
RETA | 996 | 110 (Short-term) | 11.0 | 36 | 1 to 60
Thomas 2005^41^
Lifeline 2005^19^ | 2,664 | 487 (415 early) | 18.3 | 72** | NR
Powerlink | 192 | 23 (6 early) | 12.0 | 22 | NR
Carpenter 2004^22^
Excluder | 235 | 31 | 13.2 | 2-year update | 24
Matsumura 2003^23^
Ancure (n=305) and EGS (n=268); | 319 | 212 | 37.0 | 5-year update | 1 to 60
Moore 2003^24^
AneuRx | 1,193 | NR | NR | 6-year update | NR
Zarins 2003^42^
Eurostar | 2,863 | 410 | 14.3 | NR | NR
Laheij 2002^44^
Talent | 240 | 9 | 3.8 | 13 | NR
Criado 2003^12^
Alric 2002^29^ | 88 | 6 | 6.8 | 21 | 6 to 68
Becquemin 2000^9^ | 73 | 16 | 21.9 | 7 | 0 to 40
Blum 2001^38^ | 298 | 24 | 8.1 | 35 | 2 to 50
Carpenter 2004^46^ | 227 | 17 | 7.5 | 11 | 0 to 41
Cartes 2002^28^ | 72 | 10 | 13.9 | 22 | 1 to 46
Elkouri 2003^47^ | 100 | 29 | 29.0 | 7 | 1 to 60
Faries 2002^34^ | 65 | 17 | 26 | 13 | 6 to 48
Flora 2003^30^ | 108 | 28 | 26.2 | 20 | NR
Gilling-Smith 2000^31^ | 55 | 11 | 20.0 | 18 | 3 to 36
Hansman 2003^16^ | 50 | 6 | 12.0 | NR | NR
Haulon 2003^26^ | 96 | 38 | 39.6 | 27 | 3 to 66
May 2000^37^ | 266 | 43 | 16.2 | 6 | > 6
Tutein Nolthenius 2001^35^ | 77 | 22 | 28.6 | 12 | > 12
Ohki 2001^32^ | 239 | 23 | 9.6 | 16 | < 75
Ouriel 2003^40^ | 704 | 173 | 24.7 | NR | NR
Parlani 2002^33^ | 336 | 19 | 5.7 | 14 | 1 to 46
Resch 2001^50^ | 164 | 91 | 55.5 | 39 | NR
Ricco 2003^36^ | 1,012 | 67 | 6.6 | 11 | NR
Total | 10,793 | 1,656 | 15.3 | 6 to 72

* Unclear, studies were to have a minimum of 5-year followup. Kaplan-Meier analyses were done at 6 years

NR = Not reported

Table E16 Incidence of any EVAR endoleaks: Data from registries, nonrandomized studies, case series, and comparative studies

Time Point | Author (Reference) | Number of Subjects | Number of Cases | %
<30 days | RETA | 1,000 | 146 | 14.6
| Thomas 2005^41^
<30 days | Lifeline 2002^51^ | 1,646 | 407 | 24.7
| Total | 2,646 | 553 | 20.9
At discharge | | 1,589 | 451 | 28.4
3 months | | 441 | 90 | 20.4
6 months | | 1,403 | 327 | 23.3
12 months | | 1,309 | 222 | 17.0
24 months | | 926 | 198 | 21.4
36 months | | 415 | 61 | 14.7
48 months | | 77 | 16 | 20.8
≤30 days | Powerlink | 110 | 25 | 22.7
6 months | Carpenter 2004^22^ | 101 | 13 | 12.9
12 months | | 128 | 18 | 14.1
24 months | | 78 | 5 | 6.8
≤30 days | Excluder | 180 | 39 | 21.7
12 months | Matsumura 2003^23^ | 156 | 27 | 17.3
24 months | | 119 | 24 | 20.2
Discharge | Ancure (n=305) and EGS (n=268); | 308* | 130 | 42.2
12 months | Moore 2003^24^ | 262* | 79 | 30.3
24 months | | 225* | 55 | 24.4
36 months | | 175* | 32 | 18.3
48 months | | 101* | 15 | 14.9
60 months | | 43* | 7 | 16.3
Predischarge | AneuRx | 1,103 | 306 | 27.7
≤30 days | Zarins 2003^42^ | 1,056 | 147 | 13.9
6 months | | 987 | 135 | 13.7
12 months | | 951 | 132 | 13.9
24 months | | 772 | 129 | 16.7
36 months | | 451 | 63 | 14.0
48 months | | 137 | 19 | 13.9

* Bifurcated only

Table E17 Incidence of EVAR type I endoleaks: Data from registries, nonrandomized studies, case series, and comparative studies

Time Point | Author (Reference) | Number of Subjects | Number of Cases | %
<30 days | RETA | 1,000 | 54 | 5.4
| Thomas 2005^41^
| Powerlink | 110 | 1 | 0.9
| Carpenter 2004^22^
| Excluder | 180 | 7 | 3.9
| Matsumura 2003^23^
| Ancure (n=305) and EGS (n=268); | 308 | 12 | 3.9
| Moore 2003^24^
| AneuRx | 215 | 2 | 0.9
| Howell 2000^52^
| AneuRx | 150 | 5 | 3.3
| Lee 2002^53^
| Talent | 190 | 11 | 5.8
| Criado 2003^12^
| Gilling-Smith 2000^31^ | 55 | 6 | 10.9
| Becquemin 2000^9^ | 73 | 8 | 11.0
| Parlani 2002^33^ | 336 | 3 | 1.2
| Total | 2,617 | 109 | 4.2
Up to 1 year | Powerlink | 128 | 0 | 0
| Carpenter 2004^22^
| Excluder | 156 | 2 | 1.3
| Matsumura 2003^23^
| Ancure (n=305) and EGS (n=268); | 262 | 9 | 3.4
| Moore 2003^24^
| AneuRx | 84 | 2 | 2.4
| Howell 2000^52^
| Talent | 159 | 7 | 4.4
| Criado 2003^12^
| Albertini 2001^39^ | 185 | 16 | 8.6
| Blum 2001^38^ | 298 | 6 | 2.0
| Carpenter 2004^46^ | 227 | 7 | 3.1
| Cartes 2002^28^ | 72 | 3 | 4.2
| Hansman 2003^16^ | 50 | 1 | 2.0
| Haulon 2003^26^ | 91 | 13 | 14.3
| Tutein Nolthenius 2001^35^ | 128 | 4 | 3.1
| Ouriel 2003^40^ | 704 | 18 | 2.6
| Total | 2,544 | 88 | 3.5
>1 year | Powerlink | 78 | 0 | 0
| Carpenter 2004^22^
| Excluder | 119 | 3 | 2.5
| Matsumura 2003^23^
| Ancure(n=305) and EGS (n=268); | 225 | 4 | 1.8
| Moore 2003^24^
| AneuRx | 132 | 6 | 4.5
| Howell 2000^52^
| AneuRx | 189 | 13 | 6.9
| Wolf 2002^54^
| AneuRx | 383 | 10 | 2.6
| Zarins 2003^42^
| Talent | 179 | 8 | 4.5
| Criado 2003^12^
| Alric 2002^29^ | 88 | 3 | 3.4
| Burks 2002^27^ | 95 | 0 | 0.0
| Faries 2002^34^ | 65 | 14 | 21.5
| Flora 2003^30^ | 108 | 12 | 11.1
| Fransen 2003^43^ | 4,613 | 375 | 8.1
| Haulon 2003^26^ | 77 | 2 | 2.6
| May 2000^37^ | 266 | 21 | 7.9
| Tutein Nolthenius 2001^35^ | 128 | 2 | 1.6
| Ohki 2001^32^ | 239 | 7 | 2.9
| Ouriel 2003^40^ | 700 | 25 | 3.6
| Resch 2001^50^ | 164 | 20 | 12.2
| Total | 7,848 | 525 | 6.7

Table E18 Incidence of EVAR type II and III endoleaks: Data from registries, non-randomized studies, case series and comparative studies

Time Point | Author (Reference) | Number of Subjects | Number of Cases | %
Type II endoleak
<30 days | RETA | 1,000 | 44 | 4.4
| Thomas 2005^41^
| Powerlink | 110 | 22 | 20
| Carpenter 2004^22^
| Excluder | 180 | 21 | 11.7
| Matsumura 2003^23^
| Ancure (n=305) and EGS (n=268); | 308 | 96 | 31.2
| Moore 2003^24^
| AneuRx | 215 | 3 | 1.4
| Howell 2000^52^
| AneuRx | 150 | 29 | 19.3
| Lee 2002^53^
| Talent | 190 | 16 | 8.4
| Criado 2003^12^
| Becquemin 2000^9^ | 73 | 9 | 12.3
| Burks 2002^27^ | 95 | 19 | 20.0
| Gilling-Smith 2000^31^ | 55 | 5 | 9.1
| Parlani 2002^33^ | 336 | 22 | 6.5
| Total | 2,712 | 286 | 10.5
Up to 1 year | Powerlink | 128 | 16 | 12.5
| Carpenter 2004^22^
| Excluder | 156 | 19 | 12.2
| Matsumura 2003^23^
| Ancure (n=305) and EGS (n=268); | 262 | 57 | 21.8
| Moore 2003^24^
| AneuRx | 84 | 8 | 9.5
| Howell 2000^52^
| AneuRx | 383 | 55 | 14.4
| Zarins 2003^42^
| Talent | 185 | 10 | 5.4
| Criado 2003^12^
| Blum 2001^38^ | 298 | 9 | 3.0
| Carpenter 2004^46^ | 227 | 18 | 7.9
| Cartes 2002^28^ | 30 | 1 | 3.3
| Hansman 2003^16^ | 50 | 7 | 14.0
| Haulon 2003^26^ | 91 | 9 | 9.9
| Ouriel 2003^40^ | 704 | 173 | 24.6
| Total | 2,598 | 382 | 14.7
>1 year | Eurostar | 4,613 | 485 | 10.5
| Fransen 2003^43^
| Powerlink | 78 | 3 | 4.1
| Carpenter 2004^22^
| Excluder | 119 | 16 | 13.4
| Matsumura 2003^23^
| Ancure (n=305) and EGS (n=268); | 225 | 38 | 16.9
| Moore 2003^24^
| AneuRx | 206 | 40 | 19.4
| Arko 2003^55^
| AneuRx | 573 | 61 | 10.6
| Zarins 2003^42^
| Alric 2002^29^ | 88 | 5 | 5.7
| Faries 2002^34^ | 65 | 3 | 4.6
| Flora 2003^30^ | 108 | 9 | 8.3
| Haulon 2003^26^ | 77 | 16 | 20.8
| May 2000^37^ | 383 | 4 | 1.0
| Tutein Nolthenius 2001^35^ | 128 | 8 | 6.3
| Ohki 2001^32^ | 239 | 13 | 5.4
| Resch 2001^50^ | 164 | 23 | 14.0
| Total | 7,066 | 724 | 10.2
Type III endoleak
<30 days | RETA database | 1000 | 15 | 1.5
| Thomas 2005^41^
| Powerlink | 110 | 0 | 0
| Carpenter 2004^22^
| Excluder | 180 | 0 | 0
| Matsumura 2003^23^
| Total | 1,290 | 15 | 1.2
Up to 1 year | Powerlink | 128 | 0 | 0
| Carpenter 2004^22^
| Excluder | 156 | 0 | 0
| Matsumura 2003^23^
| Total | 284 | 0 | 0
>1 year | Eurostar | 4,613 | 225 | 4.9
| Fransen 2003^43^
| Powerlink | 78 | 0 | 0
| Carpenter 2004^22^
| Excluder | 119 | 0 | 0
| Matsumura 2003^23^
| AneuRx | 383 | 8 | 2.1
| Zarins 2003^42^
| Alric 2002^29^ | 88 | 1 | 1.1
| Blum 2001^38^ | 298 | 5 | 1.7
| Tutein Nolthenius 2001^35^ | 77 | 4 | 2.3
| Ohki 2001^32^ | 239 | 1 | 0.4
| Ouriel 2003^40^ | 704 | 23 | 3.3
| Total | 6,599 | 267 | 4.0

Table E19 Incidence of common technical complications of EVAR: Data from registries, nonrandomized studies, case series, and comparative studies

Time Point | Author (Reference) | Number of Subjects | Number of Cases | %
Technical complications, any
In-hospital | RETA | 976 | 55 | 5.6
| Thomas 2005^41^
Stent migration
At discharge | Lifeline 2002^51^ | 1,589 | 9 | 0.6
<30 days | Eurostar | 2,862 | 39 | 1.4
| Villabhaneni 2001^49^
| Total | 4,451 | 40 | 0.90
3 months | Lifeline 2002^51^ | 441 | 2 | 0.4
6 months | | 1,403 | 11 | 0.8
<1 year | Lifeline 2002^51^ | 1,309 | 2 | 0.2
| Talent Criado 2003^12^ | 240 | 3 | 1.3
| Hansman 2003^16^ | 50 | 1 | 2.0
| Total | 1,599 | 6 | 0.4
>1 year | Lifeline 2002^51^ | 926 | 48 | 5.2
| Eurostar | 4,613 | 156 | 3.4
| Fransen 2003^43^
| AneuRx | 383 | 13 | 6.3
| Zarins 2003^42^
| Blum 2001^38^ | 298 | 5 | 1.7
| Flora 2003^30^ | 108 | 2 | 1.9
| Tutein Nolthenius 2001^35^ | 77 | 6 | 8.2
| Ouriel 2003^40^ | 704 | 51 | 7.2
| Resch 2001^50^ | 164 | 31 | 18.9
| Total | 7,027 | 312 | 4.4
36 months | Lifeline 2002^51^ | 415 | 30 | 7.2
48 months | | 77 | 7 | 9
Stent wire fracture
Up to 1 year | Powerlink | 192 | 0 | 0
| Carpenter 2004^22^
| Talent | 240 | 11 | 4.6
| Criado 2003^12^
| Carpenter 2004^46^ | 227 | 6 | 2.6
| Total | 659 | 17 | 2.6
Graft limb thrombosis
<30 days | Ancure (n=305) and EGS (n=268); | 573 | 17 | 3
| Moore 2003^24^
| AneuRx | 215 | 5 | 2.3
| Howell 2000^52^
| Burks 2002^27^ | 95 | 6 | 6.3
| Lee 2002^53^ | 150 | 1 | 0.7
| Parlani 2002^33^ | 336 | 4 | 1.2
| Total | 1,369 | 33 | 2.4
<1 year | AneuRx | 241 | 10 | 4.1
| Shames 2003^56^
| AneuRx | 149 | 1 | 0.7
| Zarins 2000^57^
| Albertini 2001^39^ | 135 | 2 | 1.5
| Alric 2002^29^ | 88 | 3 | 3.4
| Arko 2003^55^ | 200 | 1 | 0.5
| Ayerdi 2003^58^ | 96 | 2 | 2.1
| Becquemin 2000^9^ | 73 | 8 | 11.0
| Blum 2001^38^ | 298 | 4 | 1.3
| Carpenter 2004^46^ | 227 | 0 | 0.0
| Elkouri 2003^47^ | 100 | 4 | 4.0
| Hansman 2003^16^ | 50 | 2 | 4.0
| Total | 1,657 | 41 | 2.5
>1 year | Eurostar | 4613 | 152 | 3.3
| Fransen 2003^43^
| Powerlink | 192 | 4 | 2.1
| Carpenter 2004^22^
| Ancure (n=305) and EGS (n=268); | 573 | 31 | 5.4
| Moore 2003^24^
| Flora 2003^30^ | 108 | 2 | 1.9
| Haulon 2003^26^ | 96 | 8 | 8.3
| Tutein Nolthenius 2001^35^ | 77 | 3 | 2.3
| Ohki 2001^32^ | 239 | 7 | 2.9
| Ouriel 2003^40^ | 704 | 43 | 6.1
| Total | 6,602 | 250 | 3.8
Graft stenosis
<30 days | Eurostar | 2862 | 10 | 0.3
| Villabhaneni 2001^49^
<1 year | Powerlink | 192 | 3 | 1.6
| Carpenter 2004^22^
| Becquemin 2000^9^ | 73 | 4 | 5.5
| Elkouri 2003^47^ | 100 | 3 | 3.0
| Total | 365 | 10 | 2.7
>1 year | Eurostar | 4,613 | 66 | 1.4
| Fransen 2003^43^

Figure E1. ADAM trial: Mean SF-36 scores by treatment group

All scores are 0 to 100, with 100 representing better health. Asterisks for individual time points are for p <.05.

Reprinted from Journal of Vascular Surgery, Volume 38, Number 4, Lederle FA, GR Johnson, SE Wilson, CW Archer, DJ Ballard, FN Littooy, and LM Messina for the Aneurysm Detection and Management Veterans Affairs Cooperative Study, Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm pages 745–752 (2003), with permission from the Society for Vascular Surgery.

Figure E2. ADAM trial: Prevalence of impotence by treatment group

Overall, by repeated measures analysis, impotence was significantly increased after randomization in the immediate repair group (p <.03)

Reprinted from Journal of Vascular Surgery, Volume 38, Number 4, Lederle FA, GR Johnson, SE Wilson, CW Archer, DJ Ballard, FN Littooy, and LM Messina for the Aneurysm Detection and Management Veterans Affairs Cooperative Study, Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm pages 745–752 (2003), with permission from the Society for Vascular Surgery.

Figure E3. Immediate open repair of small aneurysms (4.0 to 5.5 cm) vs. surveillance: UKSAT mean change in SF-20 scores from baseline at 12 months

Figure E4. DREAM trial (n = 153): Changes in Short Form-36: Physical function domain over time: Endovascular repair (EVAR) vs. open repair (OR)

Figure E5. DREAM trial (n = 153): Changes in Short Form-36: Domain of mental health, over time: Endovascular repair (EVAR) vs. open repair (OR)

Figure E6. EVAR1 trial: Euro QoL 5-D (EQSD): Endovascular repair (EVAR) vs. open repair (OR)

Figure E7. EVAR1 trial: Short Form-36 physical component: Endovascular repair (EVAR) vs. open repair (OR)

Figure E8. EVAR1 trial: Short Form-36 mental component: Endovascular repair (EVAR) vs. open repair (OR)