# Appendix D: Data Extraction Forms

Abdominal Aortic Aneurysm (AAA): Surveillance Article Abstraction Form (pages D-2 – D-9)

Abdominal Aortic Aneurysm (AAA): Open vs. Endovascular Repair RCT Article Abstraction Form (pages D-10 – D-16)

Abdominal Aortic Aneurysm (AAA): Hospital/Surgeon Volumes Abstraction Form (pages D-17 – D 27)

To see the Data Extraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Data Extraction Forms