# Appendix C: List of Excluded Studies

## Question 1: RCTs (reason for exclusion is provided in italics following each reference)

Adachi H, Ino T, Mizuhara A, et al. [Clinical significance of selective cerebral perfusion with cold blood on the brain protection]. Nippon Kyobu Geka Gakkai Zasshi. Sep. 1995;43(9):1605-10. (Jap) Not AAA; not English language. [pmid: 8530845].
Adiseshiah M, Bray AJ, Bergeron P, et al. Endoluminal repair of large abdominal aortic aneurysms using PTFE: a feasibility study. J Endovasc Surg. Aug. 1997;4(3):286-9. Not RCT. [pmid: 9291055].
Adriaensen ME, Bosch JL, Halpern EF, et al. Elective endovascular versus open surgical repair of abdominal aortic aneurysms: systematic review of short-term results. Radiology. Sep. 2002;224(3):739-47. Not RCT. [pmid: 12202708].
Alimi YS, Hartung O, Cavalero C, et al. Intestinal retractor for transperitoneal laparoscopic aortoiliac reconstruction: experimental study on human cadavers and initial clinical experience. Surg Endosc. Oct. 2000;14(10):915-9. Not RCT. [pmid: 11080403].
Allen BT, Hovsepian DM, Reilly JM, et al. Endovascular stent grafts for aneurysmal and occlusive vascular disease. Am J Surg. Dec. 1998;176(6):574-80. Not RCT. [pmid: 9926793].
Almgren B, Cars O, Eriksson I, Erlendsdottir H. Pharmacokinetics of dicloxacillin in serum and aortic wall during aneurysmal surgery. Acta Chir Scand. Jan. 1986;152:19-21. Not EVAR vs open or surveillance trial. [pmid: 3953214].
Alric P, Hinchliffe RJ, Wenham PW, et al. Lessons learned from the long-term follow-up of a first-generation aortic stent graft. J Vasc Surg. Feb. 2003;37(2):367-73. Not RCT. [pmid: 12563208].
Amesur NB, Zajko AB, Orons PD, et al. Embolotherapy of persistent endoleaks after endovascular repair of abdominal aortic aneurysm with the ancure-endovascular technologies endograft system. J Vasc Interv Radiol. Oct. 1999;10(9):1175-82. Not RCT. [pmid: 10527194].
Amesur NB, Zajko AB, Orons PD, et al. Endovascular treatment of iliac limb stenoses or occlusions in 31 patients treated with the ancure endograft. J Vasc Interv Radiol. Apr. 2000;11(4):421-8. Not RCT. [pmid: 10787199].
Ariyoshi H, Okuyama M, Okahara K, et al. Expanded polytetrafluoroethylene (ePTFE) vascular graft loses its thrombogenicity six months after implantation. Throm Res. Dec 1. 1997;88(5):427-33. Not RCT.
Ashoke R, Brown LC, Rodway A, et al. Color duplex ultrasonography is insensitive for the detection of endoleak after aortic endografting: a systematic review. J Endovasc Ther. Jun. 2005;12(3):297-305. Not EVAR vs open or surveillance trial. [pmid: 15943504].
Axelrod DJ, Lookstein RA, Guller J, et al. Inferior mesenteric artery embolization before endovascular aneurysm repair: technique and initial results. J Vasc Interv Radiol. Nov. 2004;15(11):1263-7. Not EVAR vs open or surveillance trial. [pmid: 15525746].
Ayuso JR, de Caralt TM, Pages M, et al. MRA is useful as a follow-up technique after endovascular repair of aortic aneurysms with nitinol endoprostheses. J Magn Reson Imaging. Nov. 2004;20(5):803-10. Not EVAR vs open or surveillance trial. [pmid: 15503334].
Balm R, Eikelboom BC, May J, et al. Early experience with transfemoral endovascular aneurysm management (TEAM) in the treatment of aortic aneurysms. Eur J Vasc Endovasc Surg. Feb. 1996;11(2):214-20. Not RCT. [pmid: 8616656].
Barnes RW, Baker WH, Shanik G, et al. Value of concomitant sympathectomy in aortoiliac reconstruction. Results of a prospective, randomized study. Arch Surg. Nov. 1977;112(11):1325-30. Not EVAR vs open or surveillance trial. [pmid: 921531].
Batt M, Magne JL, Alric P, et al. In situ revascularization with silver-coated polyester grafts to treat aortic infection: early and midterm results. J Vasc Surg. Nov. 2003;38(5):983-9. Not EVAR vs open or surveillance trial. [pmid: 14603204].
Baum RA, Shetty SK, Carpenter JP, et al. Limb kinking in supported and unsupported abdominal aortic stent-grafts. J Vasc Interv Radiol. Oct. 2000;11(9):1165-71. Not EVAR vs open or surveillance trial. [pmid: 11041473].
Baxendale BR, Baker DM, Hutchinson A, et al. Haemodynamic and metabolic response to endovascular repair of infra-renal aortic aneurysms. Br J Anaesth. Nov. 1996;77(5):581-5. Not RCT. [pmid: 8957971].
Becquemin JP, Haiduc F, Cavillon A. Thrombogenicity of an elastomer-coated aortofemoral Dacron prosthetic graft in humans. Ann Vasc Surg. Sep. 1994;8(5):443-51. Not EVAR vs open or surveillance trial. [pmid: 7811582].
Becquemin JP, Lapie V, Favre JP, et al. Mid-term results of a second generation bifurcated endovascular graft for abdominal aortic aneurysm repair: the French Vanguard trial. J Vasc Surg. Aug. 1999;30(2):209-18. Not RCT. [pmid: 10436440].
Beebe HG, Cronenwett JL, Katzen BT, et al. Results of an aortic endograft trial: impact of device failure beyond 12 months. J Vasc Surg. Feb. 2001;33(2 Suppl):S55-63. Not RCT. [pmid: 11174813].
Bertrand M, Godet G, Koskas F, et al. Endovascular treatment of abdominal aortic aneurysms: is there a benefit regarding postoperative outcome?. Eur J Anaesth. Apr. 2001;18(4):245-50. Not RCT.
Biasi GM, Piglionica MR, Meregaglia D, et al. European multicentre experience with modular device (Medtronic AneuRx) for the endoluminal repair of infrarenal abdominal aortic aneurysms. J Mal Vasc. Dec. 1998;23(5):374-80. Not RCT. [pmid: 9894194].
Blankensteijn JD. Mortality and morbidity rates after conventional abdominal aortic aneurysm repair. Semin Interv Cardiol. Mar. 2000;5(1):7-13. Not RCT. [pmid: 10875218].
Blum U, Voshage G, Beyersdorf F, et al. Two-center German experience with aortic endografting. J Endovasc Surg. May. 1997;4(2):137-46. Not RCT. [pmid: 9185001].
Blum U, Voshage G, Lammer J, et al. Endoluminal stent-grafts for infrarenal abdominal aortic aneurysms. N Engl J Med. Jan 2. 1997;336(1):13-20. Not EVAR vs open or surveillance trial. [pmid: 8970935].
Bolke E, Jehle PM, Storck M, et al. Endovascular stent-graft placement versus conventional open surgery in infrarenal aortic aneurysm: a prospective study on acute phase response and clinical outcome. Clin Chim Acta. Dec. 2001;314(12):203-7. Not RCT. [pmid: 11718696].
Bonazzi M, Gentile F, Biasi GM, et al. Impact of perioperative haemodynamic monitoring on cardiac morbidity after major vascular surgery in low risk patients. A randomised pilot trial. Eur J Vasc Endovasc Surg. May. 2002;23(5):445-51. Not EVAR vs open or surveillance trial. [pmid: 12027474].
Borner G, Ivancev K, Sonesson B, et al. Percutaneous AAA repair: is it safe?. J Endovasc Ther. Dec. 2004;11(6):621-6. Not RCT. [pmid: 15615552].
Bove PG, Long GW, Shanley CJ, et al. Transrenal fixation of endovascular stent-grafts for infrarenal aortic aneurysm repair: mid-term results. J Vasc Surg. May. 2003;37(5):938-42. Not RCT. [pmid: 12756336].
Brener BJ, Faries P, Connelly T, et al. An in situ adjustable endovascular graft for the treatment of abdominal aortic aneurysms. J Vasc Surg. Jan. 2002;35(1):114-9. Not RCT. [pmid: 11802141].
Broeders IA, Blankensteijn JD, Gvakharia A, et al. The efficacy of transfemoral endovascular aneurysm management: a study on size changes of the abdominal aorta during mid-term follow-up. Eur J Vasc Endovasc Surg. Aug. 1997;14(2):84-90. Not RCT.
Broeders IA, Blankensteijn JD, Wever JJ, et al. Mid-term fixation stability of the EndoVascular Technologies endograft. EVT Investigators. Eur J Vasc Endovasc Surg. Oct. 1999;18(4):300-7. Not RCT. [pmid: 10550264].
Brustia P, Renghi A, Gramaglia L, et al. Mininvasive abdominal aortic surgery. Early recovery and reduced hospitalization after multidisciplinary approach. J Cardiovasc Surg. Oct. 2003;44(5):629-35. Not RCT. [pmid: 14735052].
Burtoft JN, Robicsek F, Daugherty HK, et al. Comparative analysis of thrombogenicity and clinical patency between woven and knitted aorto-iliac and aorto-femoral prostheses. ASAIO Trans. Jul–Sep. 1987;33(3):207-11. Not RCT. [pmid: 2960333].
Bush RL, Najibi S, Lin PH, et al. Early experience with the bifurcated Excluder endoprosthesis for treatment of the abdominal aortic aneurysm. J Vasc Surg. Sep. 2001;34(3):497-502. Not RCT. [pmid: 11533603].
Buth J, van Marrewijk CJ, Harris PL, et al. Outcome of endovascular abdominal aortic aneurysm repair in patients with conditions considered unfit for an open procedure: a report on the EUROSTAR experience. J Vasc Surg. Feb. 2002;35(2):211-21. Not RCT. [pmid: 11854717].
Carpenter JP, Anderson WN, Brewster DC, et al. Multicenter pivotal trial results of the Lifepath System for endovascular aortic aneurysm repair. J Vasc Surg. Jan. 2004;39(1):34-43. Not RCT. [pmid: 14718809].
Carpenter JP. Endologix Investigators. Midterm results of the multicenter trial of the powerlink bifurcated system for endovascular aortic aneurysm repair. J Vasc Surg. Nov. 2004;40(5):849-59. Not RCT. [pmid: 15557896].
Carpenter JP. Endologix Investigators. Multicenter trial of the PowerLink bifurcated system for endovascular aortic aneurysm repair. J Vasc Surg. Dec. 2002;36(6):1129-37. Not RCT. [pmid: 12469043].
Cartes-Zumelzu F, Lammer J, Hoelzenbein T, et al. Endovascular placement of a nitinol-ePTFE stent-graft for abdominal aortic aneurysms: initial and midterm results. J Vasc Interv Radiol. May. 2002;13(5):465-73. Not RCT. [pmid: 11997354].
Castronuovo JJ Jr, James KV, Resnikoff M, et al. Laparoscopic-assisted abdominal aortic aneurysmectomy. J Vasc Surg. Aug. 2000;32(2):224-33. Not RCT. [pmid: 10917981].
Chavan A, Cohnert TU, Heine J, Dresler C, Leuwer M, Harringer W, et al. Endoluminal grafting of abdominal aortic aneurysms: experience with the Talent endoluminal stent graft. Eur Radiol. 2000;10(4):636-41. Not RCT. [pmid: 10795547].
Christ F, Gamble J, Raithel P, Steckmeier B, Messmer K. [Preoperative changes in fluid filtration capacity in patients undergoing vascular surgery]. Anaesthesist. Jan. 1999;48(1):9-18. (Ger) Not RCT; not English language. [pmid: 10073242].
Chuter TA, Wendt G, Hopkinson BR, et al. Transfemoral insertion of a bifurcated endovascular graft for aortic aneurysm repair: the first 22 patients. Cardiovasc Surg. Apr. 1995;3(2):121-8. Not RCT. [pmid: 7606396].
Cina CS, Abouzahr L, Arena GO, et al. Cerebrospinal fluid drainage to prevent paraplegia during thoracic and thoracoabdominal aortic aneurysm surgery: a systematic review and meta-analysis. J Vasc Surg. Jul. 2004;40(1):36-44. Not EVAR vs open or surveillance trial. [pmid: 15218460].
Conners MS 3rd, Tonnessen BH, Sternbergh WC 3rd, et al. Does ASA classification impact success rates of endovascular aneurysm repairs?. Ann Vasc Surg. Sep. 2002;16(5):550-5. Not RCT. [pmid: 12203004].
Coppi G, Moratto R, Silingardi R, et al. The Italian trial of endovascular AAA exclusion using the Parodi endograft. J Endovasc Surg. Aug. 1997;4(3):299-306. Not EVAR vs open or surveillance trial. [pmid: 9291058].
Coppi G, Pacchioni R, Moratto R, et al. Experience with the Stentor endograft at four Italian centers. J Endovasc Surg. Aug. 1998;5(3):206-15. Not RCT. [pmid: 9761571].
Courbier R, Ferdani M, Jausseran JM, et al. The role of omentopexy in the prevention of femoral anastomotic aneurysm. J Cardiovasc Surg. Mar–Apr. 1992;33(2):149-53. Not RCT. [pmid: 1572869].
Criado FJ, Clark NS, McKendrick C, et al. Update on the Talent LPS AAA stent graft: results with “enhanced talent”. Semin Vasc Surg. Jun. 2003;16(2):158-65. Not RCT. [pmid: 12920687].
Criado FJ, Fairman RM, Becker GJ, et al. Talent LPS AAA stent graft: results of a pivotal clinical trial. J Vasc Surg. Apr. 2003;37(4):709-15. Not RCT. [pmid: 12663967].
Criado FJ, Fry PD, Machan LS, et al. The talent endoluminal AAA stent-graft system. Report of the phase I USA trial, and summary of worldwide experience. J Mal Vasc. Dec. 1998;23(5):371-3. Not RCT. [pmid: 9894193].
Criado FJ, Wilson EP, Abul-Khoudoud O, et al. Brachial artery catheterization to facilitate endovascular grafting of abdominal aortic aneurysm: safety and rationale. J Vasc Surg. Dec. 2000;32(6):1137-41. Not RCT. [pmid: 11107085].
Criado FJ, Wilson EP, Wellons E, et al. Early experience with the Talent stent-graft system for endoluminal repair of abdominal aortic aneurysms. Tex Heart Inst J. 2000;27(2):128-35. Not RCT. [pmid: 10928500]. [pmcid: 101047].
d'Audiffret A, Santilli S, Tretinyak A, et al. Fate of the ectatic infrarenal aorta: expansion rates and outcomes. Ann Vasc Surg. Sep. 2002;16(5):534-6. Not EVAR vs open or surveillance trial. [pmid: 12183768].
Dake MD, Kato N, Mitchell RS, et al. Endovascular stent-graft placement for the treatment of acute aortic dissection. N Engl J Med. May 20. 1999;340(20):1546-52. Not EVAR vs open or surveillance trial. [pmid: 10332016].
Darling RC 3rd, Cordero JA Jr, Chang BB, et al. Advances in the surgical repair of ruptured abdominal aortic aneurysms. Cardiovasc Surg. Dec. 1996;4(6):720-3. Not RCT. [pmid: 9012998].
Darling RC 3rd, Shah DM, McClellan WR, et al. Decreased morbidity associated with retroperitoneal exclusion treatment for abdominal aortic aneurysm. J Cardiovasc Surg. Jan–Feb. 1992;33(1):65-9. Not EVAR vs open or surveillance trial. [pmid: 1545000].
De Mol Van Otterloo JC, Van Bockel JH, Ponfoort ED, et al. Systemic effects of collagen-impregnated aortoiliac Dacron vascular prostheses on platelet activation and fibrin formation. J Vasc Surg. Jul. 1991;14(1):59-66. Not EVAR vs open or surveillance trial. [pmid: 1829489].
Deaton DH, Balch D, Kesler C, et al. Telemedicine and endovascular aortic grafting. Am J Surg. Jan. 1999;177(1):75-7. Not EVAR vs open or surveillance trial. [pmid: 10037313].
Deaton DH, Bogey WM, Chiang K, et al. Bifurcated endovascular grafting for abdominal aortic aneurysm. Ann Vasc Surg. Jan. 1999;13(1):23-31. Not RCT. [pmid: 9878653].
Deleersnijder R, Daenens K, Fourneau I, et al. Endovascular repair of inflammatory abdominal aortic aneurysms with special reference to concomitant ureteric obstruction. Eur J Vasc Endovasc Surg. Aug. 2002;24(2):146-9. Not EVAR vs open or surveillance trial. [pmid: 12389237].
Donati A, Cornacchini O, Loggi S, et al. A comparison among portal lactate, intramucosal sigmoid Ph, and deltaCO2 (PaCO2 - regional Pco2) as indices of complications in patients undergoing abdominal aortic aneurysm surgery. Anesth Analg. Oct. 2004;99(4):1024-31. Not EVAR vs open or surveillance trial. [pmid: 15385343].
Dorman BH, Elliott BM, Spinale FG, et al. Protamine use during peripheral vascular surgery: a prospective randomized trial. J Vasc Surg. Sep. 1995;22(3):248-55. Not EVAR vs open or surveillance trial. [pmid: 7674467].
Duda D, Lorenz W, Celik I. Histamine release in mesenteric traction syndrome during abdominal aortic aneurysm surgery: prophylaxis with H1 and H2 antihistamines. Inflamm Res. Oct. 2002;51(10):495-9. Not EVAR vs open or surveillance trial. [pmid: 12477078].
Duda D, Lorenz W, Celik I. [Mesenteric traction syndrome during the operation of aneurysms of the abdominal aorta—histamine release and prophylaxis with antihistaminics]. Anaesthesiol Reanim. 2003;28(4):97-103. (Ger) Not EVAR vs open or surveillance trial. [pmid: 14528656].
Ebaugh JL, Matsumura JS, Morasch MD, et al. Morphometric analysis of the popliteal artery for endovascular treatment. Vasc Endovasc Surg. Jan–Feb. 2003;37(1):23-6. Not EVAR vs open or surveillance trial.
Edwards WH Jr, Naslund TC, Edwards WH Sr, et al. Endovascular grafting of abdominal aortic aneurysms. A preliminary study. Ann Surg. May. 1996;223(5):568-73. Not RCT. [pmid: 8651747]. [pmcid: 1235183].
Ellozy SH, Carroccio A, Lookstein RA, et al. First experience in human beings with a permanently implantable intrasac pressure transducer for monitoring endovascular repair of abdominal aortic aneurysms. J Vasc Surg. Sep. 2004;40(3):405-12. Not RCT. [pmid: 15337865].
Engellau L, Olsrud J, Brockstedt S, et al. MR evaluation ex vivo and in vivo of a covered stent-graft for abdominal aortic aneurysms: ferromagnetism, heating, artifacts, and velocity mapping. J Magn Reson Imaging. Jul. 2000;12(1):112-21. Not RCT. [pmid: 10931571].
Ersoy H, Jacobs P, Kent CK, et al. Blood pool MR angiography of aortic stent-graft endoleak. AJR Am J Roentgenol. May. 2004;182(5):1181-6. Not EVAR vs open or surveillance trial. [pmid: 15100115].
Eyraud D, Bertrand M, Fleron MH, et al. [Risk factors for mortality in abdominal aortic surgery]. Ann Fr Anesth Reanim. Jun. 2000;19(6):452-8. (Fre) Not RCT. [pmid: 10941445].
Fairman RM, Velazquez O, Baum R, et al. Endovascular repair of aortic aneurysms: critical events and adjunctive procedures. J Vasc Surg. Jun. 2001;33(6):1226-32. Not RCT. [pmid: 11389422].
Falk V, Vettelschoss M, Walther T, et al. Surgical treatment of abdominal aortic aneurysms of octogenarians. Cardiovasc Surg. Dec. 1996;4(6):727-31. Not RCT. [pmid: 9013000].
Fanti L, Masci E, Mariani A, et al. Is endoscopy useful for early diagnosis of ischaemic colitis after aortic surgery? Results of a prospective trial. Ital J Gastroenterol Hepatol. Aug. 1997;29(4):357-60. Not RCT. [pmid: 9476191].
Faries PL, Brener BJ, Connelly TL, et al. A multicenter experience with the Talent endovascular graft for the treatment of abdominal aortic aneurysms. J Vasc Surg. Jun. 2002;35(6):1123-8. Not RCT. [pmid: 12042722].
Fiane AE, Videm V, Lingaas PS, et al. Mechanism of complement activation and its role in the inflammatory response after thoracoabdominal aortic aneurysm repair. Circulation. Aug 19. 2003;108(7):849-56. Not RCT. [pmid: 12900342].
Fisher JB, Dennis RC, Valeri CR, et al. Effect of graft material on loss of erythrocytes after aortic operations. Surg Gynecol Obstet. Aug. 1991;173(2):131-6. Not EVAR vs open or surveillance trial. [pmid: 1833839].
Friedman SG, Sowerby SA, Del Pin CA, et al. A prospective randomized study of abdominal aortic surgery without postoperative nasogastric decompression. Cardiovasc Surg. Aug. 1996;4(4):492-4. Not EVAR vs open or surveillance trial. [pmid: 8866087].
Fujii H, Ujiie T, Ariizumi K, et al. [Surgical treatment of acute aortic dissections—a clinical study using a ringed intraluminal graft]. Nippon Kyobu Geka Gakkai Zasshi. Sep. 1995;43(9):1611-6. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 8530846].
Furunaga A, Tsuboi H, Katoh T, et al. [Clinical analysis of the surgical therapy of DeBakey type I acute aortic dissection]. Kyobu Geka. Apr. 1995;48(4):306-8. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 7715116].
Godet G, Canessa R, Arock M, et al. [Effects of platelet-rich plasma on hemostasis and transfusion requirement in vascular surgery]. Ann Fr Anesth Reanim. 1995;14(3):265-70. (Fre) Not EVAR vs open or surveillance trial; not English language. [pmid: 7486296].
Goeau-Brissonniere OA, Qanadli SD, Ippoliti A, et al. Can knitting structure affect dilation of polyester bifurcated prostheses? A randomized study with the use of helical computed tomography scanning. J Vasc Surg. Jan. 2000;31(1 Pt 1):157-63. Not EVAR vs open or surveillance trial. [pmid: 10642718].
Goueffic Y, Becquemin JP, Desgranges P, et al. Midterm survival after endovascular versus open repair of infrarenal aortic aneurysms. J Endovasc Ther. Feb. 2005;12(1):47-57. Not RCT. [pmid: 15683271].
Grabowska-Gawel A, Wisniewski J. [Effectiveness of extrameningeally administered opioids in patients with aortic prosthesis]. Pol Merkuriusz Lek. Jun. 2004;16(96):516-8. (Pol) Not EVAR vs open or surveillance trial; not English language.
Greenberg R. Zenith Investigators. The Zenith AAA endovascular graft for abdominal aortic aneurysms: clinical update. Semin Vasc Surg. Jun. 2003;16(2):151-7. Not RCT. [pmid: 12920686].
Greenberg RK, Chuter TA, Lawrence-Brown M, et al. Analysis of renal function after aneurysm repair with a device using suprarenal fixation (Zenith AAA Endovascular Graft) in contrast to open surgical repair. J Vasc Surg. Jun. 2004;39(6):1219-28. Not RCT. [pmid: 15192560].
Greenberg RK, Chuter TA, Sternbergh WC 3rd, et al. Zenith AAA endovascular graft: intermediate-term results of the US multicenter trial. J Vasc Surg. Jun. 2004;39(6):1209-18. Not RCT. [pmid: 15192559].
Greenberg RK, Lawrence-Brown M, Bhandari G, et al. An update of the Zenith endovascular graft for abdominal aortic aneurysms: initial implantation and mid-term follow-up data. J Vasc Surg. Feb. 2001;33(2 Suppl):S157-64. Not RCT. [pmid: 11174829].
Guo W, Ge L, Zhang G, Liang F, et al. [Endovascular treatment for abdominal aortic aneurysm, a primary study]. Chung-Hua i Hsueh Tsa Chih. Mar. 2002;82(5):291-3. (Chi) Not RCT. [pmid: 11953181].
Hagberg RC, Safi HJ, Sabik J, et al. Improved intraoperative management of anastomotic bleeding during aortic reconstruction: results of a randomized controlled trial. Am Surg. Apr. 2004;70(4):307-11. Not EVAR vs open or surveillance trial. [pmid: 15098782].
Hankeln K, Senker R, Beez M. [Comparative study of the intraoperative effectiveness of 5% human albumin or 10% hydroxyethyl starch (HAES-steril) on hemodynamics and oxygen transport in 40 patients]. Infusionstherapie (Basel). Jun. 1990;17(3):135-40. (Ger) Not EVAR vs open or surveillance trial, not English language.
Hansen CJ, Aziz I, Kim BB, et al. Results from the Endologix PowerLink multicenter trial. Semin Vasc Surg. Jun. 2003;16(2):166-70. Not RCT. [pmid: 12920688].
Harafuji K, Chikamori T, Kawaguchi S, et al. Preoperative risk stratification for endovascular surgery using pharmacologic stress myocardial imaging. Am J Cardiol. Dec 1. 2004;94(11):1471-4. Not RCT. [pmid: 15566932].
Hausegger KA, Mendel H, Tiessenhausen K, et al. Endoluminal treatment of infrarenal aortic aneurysms: clinical experience with the Talent stent-graft system. J Vasc Interv Radiol. Mar. 1999;10(3):267-74. Not RCT. [pmid: 10102189].
Hessmann M, Dossche K, Wellens F, et al. Surgical treatment of thoracic aneurysm: a 5-year experience. Cardiovasc Surg. Feb. 1995;3(1):19-25. Not RCT. [pmid: 7780703].
Houweling PL, Ionescu TI, Leguit P, et al. Comparison of the cardiovascular effects of intravenous, epidural and intrathecal sufentanil analgesia as a supplement to general anaesthesia for abdominal aortic aneurysm surgery. Eur J Anaesthesiol. Nov. 1993;10(6):403-11. Not EVAR vs open or surveillance trial. [pmid: 11767316].
Hovsepian DM, Siegel BA, Kimbiris G, et al. Tc-99m sulfur colloid scintigraphy for detecting perigraft flow following endovascular aortic aneurysm repair: A feasibility study. Cardiovasc Interv Radiol. Nov–Dec. 1999;22(6):447-51. Not EVAR vs open or surveillance trial.
Howell M, Doughtery K, Strickman N, et al. Percutaneous repair of abdominal aortic aneurysms using the AneuRx stent graft and the percutaneous vascular surgery device. Catheter Cardiovasc Interv. Mar. 2002;55(3):281-7. Not EVAR vs open or surveillance trial. [pmid: 11870928].
Howell MH, Zaqqa M, Villareal RP, et al. Endovascular exclusion of abdominal aortic aneurysms: initial experience with stent-grafts in cardiology practice. Tex Heart Inst J. 2000;27(2):136-45. Not RCT. [pmid: 10928501]. [pmcid: 101048].
Ince H, Petzsch M, Rehders T, et al. Percutaneous endovascular repair of aneurysm after previous coarctation surgery. Circulation. Dec 16. 2003;108(24):2967-70. Not RCT. [pmid: 14662704].
Jones K, Powell J, Brown L, et al. The influence of 4G/5G polymorphism in the plasminogen activator inhibitor-1 gene promoter on the incidence, growth and operative risk of abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. May. 2002;23(5):421-5. Not EVAR vs open or surveillance trial. [pmid: 12027469].
Karch LA, Henretta JP, Hodgson KJ, et al. Algorithm for the diagnosis and treatment of endoleaks. Am J Surg. Sep. 1999;178(3):225-31. Not EVAR vs open or surveillance trial. [pmid: 10527444].
Karner J, Schemper M, Teleky B, et al. Aorto-Y-bifurcation graft: Dacron versus PTFE. Preliminary results of a randomized prospective study. Int Surg. Oct–Dec. 1988;73(4):218-20. Not EVAR vs open or surveillance trial. [pmid: 2978036].
Kazui T, Komatsu S. [Selection of surgical treatment for aortic dissection on the basis of pathophysiology]. Jpn Circ J. 1993;57(Suppl 4):1313-6. (Jap) Not RCT; not English language. [pmid: 7966974].
Kelley-Patteson C, Ammar AD, Kelley H. Should the Cell Saver Autotransfusion Device be used routinely in all infrarenal abdominal aortic bypass operations?. J Vasc Surg. Aug. 1993;18(2):261-5. Not EVAR vs open or surveillance trial. [pmid: 8350435].
Kibbe MR, Matsumura JS. Excluder Investigators. The Gore Excluder US multi-center trial: analysis of adverse events at 2 years. Semin Vasc Surg. Jun. 2003;16(2):144-50. Not RCT. [pmid: 12920685].
Kieffer E, Maraval M, Natali J. [Cure of abdominal aortic aneurysm at the origin of the renal arteries]. Nouv Presse Med. Mar 30. 1974;3(13):807-8. (Fre) Not EVAR vs open or surveillance trial; not English language. [pmid: 4600208].
Kindgen-Milles D, Muller E, Buhl R, et al. Nasal-continuous positive airway pressure reduces pulmonary morbidity and length of hospital stay following thoracoabdominal aortic surgery. Chest. Aug. 2005;128(2):821-8. Not EVAR vs open or surveillance trial. [pmid: 16100174].
Kinney EV, Kaebnick HW, Mitchell RA, et al. Minimally invasive aortic surgery: endovascular stent-graft repair of abdominal aortic aneurysm. J Ky Med Assoc. Nov. 1999;97(11):518-24. Not RCT. [pmid: 10589178].
Kolvenbach R. Hand-assisted laparoscopic abdominal aortic aneurysm repair. Semin Laparosc Surg. Jun. 2001;8(2):168-77. Not EVAR vs open or surveillance trial. [pmid: 11441406].
Kolvenbach R, Da Silva L, Deling O, et al. Video-assisted aortic surgery. J Am Coll Surg. Apr. 2000;190(4):451-7. Not RCT. [pmid: 10757383].
Kolvenbach R, Pinter L, Raghunandan M, et al. Laparoscopic remodeling of abdominal aortic aneurysms after endovascular exclusion: a technical description. J Vasc Surg. Dec. 2002;36(6):1267-70. Not RCT. [pmid: 12469062].
Komori K, Ishida M, Matsumoto T, et al. Cytokine patterns and the effects of a preoperative steroid treatment in the patients with abdominal aortic aneurysms. Int Angiol. Sep. 1999;18(3):193-7. Not EVAR vs open or surveillance trial. [pmid: 10688417].
Koschyk DH, Meinertz T, Hofmann T, et al. Value of intravascular ultrasound for endovascular stent-graft placement in aortic dissection and aneurysm. J Card Surg. Sep–Oct. 2003;18(5):471-7. Not RCT. [pmid: 12974938].
Koskas F, Cluzel P, Kieffer E, et al. [Tailored endoprostheses for the endovascular treatment of aorto-iliac aneurysms: current features and perspectives]. Bull Acad Natl Med. 2002;186(2):393-408. (Fre) Not RCT; not English language. [pmid: 12145846].
Kotake Y, Moriyama K, Innami Y, et al. Performance of noninvasive partial CO2 rebreathing cardiac output and continuous thermodilution cardiac output in patients undergoing aortic reconstruction surgery. Anesthesiology. Aug. 2003;99(2):283-8. Not EVAR vs open or surveillance trial. [pmid: 12883400].
Kovalenko VI. [Disorder of the rheological properties of the blood as a risk factor in interventions on the abdominal aorta and its branches]. Vestn Khir Im I I Grek. Mar. 1979;122(3):82-7. (Rus) Not EVAR vs open or surveillance trial; not English language.
Kritpracha B, Beebe HG, Criado FJ, et al. Post-endograft abdominal aortic aneurysm shrinkage varies among hospitals: observations from multicenter trials. J Endovasc Ther. Aug. 2004;11(4):454-9. Not EVAR vs open or surveillance trial. [pmid: 15298499].
Lachat ML, Pfammatter T, Witzke HJ, et al. Endovascular repair with bifurcated stent-grafts under local anaesthesia to improve outcome of ruptured aortoiliac aneurysms. Eur J Vasc Endovasc Surg. Jun. 2002;23(6):528-36. Not EVAR vs open or surveillance trial. [pmid: 12093070].
Laohapensang K, Rerkasem K, Chotirosniramit N. Left retroperitoneal versus midline transperitoneal approach for abdominal aortic aneurysms (AAAs) repair. J Med Assoc Thai. May. 2005;88(5):601-6. Not EVAR vs open or surveillance trial. [pmid: 16149675].
Larsen KE, Justesen P, Rohr N. [Endovascular treatment of abdominal aortic aneurysms]. Ugeskr Laeger. Apr 22. 2002;164(17):2288-91. (Dan) Not EVAR vs open or surveillance trial. [pmid: 11989179].
Lau LL, Gardiner KR, Martin L, et al. Extraperitoneal approach reduces neutrophil activation, systemic inflammatory response and organ dysfunctionin aortic aneurysm surgery. Eur J Vasc Endovasc Surgm. Apr. 2001;21(4):326-33. Not EVAR vs open or surveillance trial.
Lau LL, Halliday MI, Lee B, et al. Intestinal manipulation during elective aortic aneurysm surgery leads to portal endotoxaemia and mucosal barrier dysfunction. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):619-24. Not EVAR vs open or surveillance trial. [pmid: 10873730].
Lee AM, Rockman CB, Riles TS, et al. Report of a single-institution experience using the EVT endovascular abdominal aortic aneurysm graft in 25 patients. Ann Vasc Surg. Jan. 1999;13(1):60-6. Not EVAR vs open or surveillance trial. [pmid: 9878658].
Lethagen S, Rugarn P, Bergqvist D. Blood loss and safety with desmopressin or placebo during aorto-iliac graft surgery. Eur J Vasc Surg. Apr. 1991;5(2):173-8. Not EVAR vs open or surveillance trial. [pmid: 1903723].
Leyh RG, Fischer S, Kallenbach K, et al. High failure rate after valve-sparing aortic root replacement using the “remodeling technique” in acute type A aortic dissection. Circulation. Sep 24. 2002;106(12 Suppl 1):I229-33. Not EVAR vs open or surveillance trial. [pmid: 12354738].
Lifeline Registry of Endovascular Aneurysm Repair Steering Committee. Lifeline Registry of Endovascular Aneurysm Repair: Registry data report. J Vasc Surg. Mar. 2002;35(3):616-20. Not RCT. [pmid: 11877719].
Lloyd WE, Paty PS, Darling RC 3rd, et al. Results of 1000 consecutive elective abdominal aortic aneurysm repairs. Cardiovasc Surg. Dec. 1996;4(6):724-6. Not EVAR vs open or surveillance trial. [pmid: 9012999].
Lottman PE, Laheij RJ, Cuypers PW, et al. Health-related quality of life outcomes following elective open or endovascular AAA repair: a randomized controlled trial. J Endovasc Ther. Jun. 2004;11(3):323-9. No clinical outcomes of interest. [pmid: 15174920].
Lyden SP, Sternbach Y, Waldman DL, et al. Clinical implications of internal iliac artery embolization in endovascular repair of aortoiliac aneurysms. Ann Vasc Surg. Sep. 2001;15(5):539-43. Not EVAR vs open or surveillance trial. [pmid: 11665437].
Makaroun M, Zajko A, Orons P, et al. The experience of an academic medical center with endovascular treatment of abdominal aortic aneurysms. Am J Surg. Aug. 1998;176(2):198-202. Not EVAR vs open or surveillance trial. [pmid: 9737632].
Makaroun M, Zajko A, Sugimoto H, et al. Fate of endoleaks after endoluminal repair of abdominal aortic aneurysms with the EVT device. Eur J Vasc Endovasc Surg. Sep. 1999;18(3):185-90. Not EVAR vs open or surveillance trial. [pmid: 10479624].
Makaroun MS, Chaikof E, Naslund T, et al. Efficacy of a bifurcated endograft versus open repair of abdominal aortic aneurysms: a reappraisal. J Vasc Surg. Feb. 2002;35(2):203-10. Not RCT. [pmid: 11854716].
Makaroun MS, Deaton DH. Is proximal aortic neck dilatation after endovascular aneurysm exclusion a cause for concern?. J Vasc Surg. Feb. 2001;33(2 Suppl):S39-45. Not EVAR vs open or surveillance trial. [pmid: 11174811].
Malina M, Nilsson M, Brunkwall J, et al. Quality of life before and after endovascular and open repair of asymptomatic AAAs: a prospective study. J Endovasc Ther. Oct. 2000;7(5):372-9. Not RCT. [pmid: 11032255].
Matsumoto M, Hata T, Tsushima Y, et al. Minimally invasive vascular surgery for repair of infrarenal abdominal aortic aneurysm with iliac involvement. J Vasc Surg. Apr. 2002;35(4):654-60. Not RCT. [pmid: 11932658].
Matsumura JS, Brewster DC, Makaroun MS, et al. A multicenter controlled clinical trial of open versus endovascular treatment of abdominal aortic aneurysm. J Vasc Surg. Feb. 2003;37(2):262-71. Not RCT. [pmid: 12563194].
Matsumura JS, Chaikof EL. Continued expansion of aortic necks after endovascular repair of abdominal aortic aneurysms. EVT Investigators. EndoVascular Technologies, Inc. J Vasc Surg. Sep. 1998;28(3):422-30. Not EVAR vs open or surveillance trial. [pmid: 9737451].
Matsumura JS, Katzen BT, Hollier LH, et al. Update on the bifurcated EXCLUDER endoprosthesis: phase I results. J Vasc Surg. Feb. 2001;33(2 Suppl):S150-3. Not EVAR vs open or surveillance trial. [pmid: 11174827].
Matsumura JS, Moore WS. Clinical consequences of periprosthetic leak after endovascular repair of abdominal aortic aneurysm. Endovascular Technologies Investigators. J Vasc Surg. Apr. 1998;27(4):606-13. Not EVAR vs open or surveillance trial. [pmid: 9576072].
May J, White GH, Yu W, et al. Concurrent comparison of endoluminal repair vs. no treatment for small abdominal aortic aneurysms. Eur J Vasc Endovasc Surg. May. 1997;13(5):472-6. Not RCT. [pmid: 9166270].
May J, White GH, Yu W, et al. Endovascular grafting for abdominal aortic aneurysms: changing incidence and indication for conversion to open operation. Cardiovasc Surg. Apr. 1998;6(2):194-7. Not RCT. [pmid: 9610834].
McFalls EO, Ward HB, Moritz TE, et al. Coronary-artery revascularization before elective major vascular surgery. N Engl J Med. Dec 30. 2004;351(27):2795-804. Not EVAR vs open or surveillance trial. [pmid: 15625331].
McGahan TJ, Berry GA, McGahan SL, et al. Results of autopsy 7 months after successful endoluminal treatment of an infrarenal abdominal aortic aneurysm. J Endovasc Surg. Nov. 1995;2(4):348-55. Not EVAR vs open or surveillance trial. [pmid: 9234154].
Meierhenrich R, Gauss A, Anhaeupl T, et al. Analysis of diastolic function in patients undergoing aortic aneurysm repair and impact on hemodynamic response to aortic cross-clamping. J Cardiothorac Vasc Anesth. Apr. 2005;19(2):165-72. Not EVAR vs open or surveillance trial. [pmid: 15868522].
Milne AA, Murphy WG, Reading SJ, et al. A randomised trial of fibrin sealant in peripheral vascular surgery. Vox Sang. 1996;70(4):210-2. Not EVAR vs open or surveillance trial. [pmid: 9123925].
Mocini D, Uguccioni M, Galli C, et al. Dipyridamole echocardiography and 99mTc-MIBI spect dipyridamole scintigraphy for cardiac evaluation prior to peripheral vascular surgery. Minerva Cardioangiol. May. 1995;43(5):185-90. Not EVAR vs open or surveillance trial. [pmid: 7478041].
Moore WS. The Guidant Ancure bifurcation endograft: five-year follow-up. Semin Vasc Surg. Jun. 2003;16(2):139-43. Not RCT. [pmid: 12920684].
Moore WS. The role of endovascular grafting technique in the treatment of infrarenal abdominal aortic aneurysm. Cardiovasc Surg. Apr. 1995;3(2):109-14. Not RCT. [pmid: 7606394].
Moore WS, Brewster DC, Bernhard VM. Aorto-uni-iliac endograft for complex aortoiliac aneurysms compared with tube/bifurcation endografts: results of the EVT/Guidant trials. J Vasc Surg. Feb. 2001;33(2 Suppl):S11-20. Not RCT. [pmid: 11174807].
Moore WS, Matsumura JS, Makaroun MS, et al. Five-year interim comparison of the Guidant bifurcated endograft with open repair of abdominal aortic aneurysm. J Vasc Surg. Jul. 2003;38(1):46-55. Not RCT. [pmid: 12844088].
Moore WS, Rutherford RB. Transfemoral endovascular repair of abdominal aortic aneurysm: results of the North American EVT phase 1 trial. EVT Investigators. J Vasc Surg. Apr. 1996;23(4):543-53. Not EVAR vs open or surveillance trial. [pmid: 8627888].
Nakajima T, Kawazoe K, Komoda K, et al. Midline retroperitoneal versus midline transperitoneal approach for abdominal aortic aneurysm repair. J Vasc Surg. Aug. 2000;32(2):219-23. Not EVAR vs open or surveillance trial. [pmid: 10917980].
Nakayama S, Yamazato A, Hanada M, et al. [Results of surgical treatment of aortic dissections]. Nippon Geka Hokan. May 1. 1994;63(3):99-103. (Jap) Not RCT. [pmid: 7887769].
Nakayama Y, Sakata R, Umebayashi Y, et al. [An evaluation of aortic root reconstruction using Carrel patch method with coronary anastomosis]. Kyobu Geka. Jun. 1996;49(6):452-5. (Jap) Not EVAR vs open or surveillance trial. [pmid: 8847841].
Naslund TC, Edwards WH Jr, Neuzil DF, et al. Technical complications of endovascular abdominal aortic aneurysm repair. J Vasc Surg. Sep. 1997;26(3):502-9. Not EVAR vs open or surveillance trial. [pmid: 9308596].
Neimark MI, Merkulov IV, Flat MK. [Renal protective function in surgical treatment for chronic infrarenal aortic aneurysms]. Anesteziol Reanimatol 2005 Jul–Aug; (4):18–22. (Rus) Not EVAR vs open or surveillance trial
Nienaber CA, Ince H, Weber F, et al. Emergency stent-graft placement in thoracic aortic dissection and evolving rupture. J Card Surg. Sep–Oct. 2003;18(5):464-70. Not EVAR vs open or surveillance trial. [pmid: 12974937].
Norgren L, Holtas S, Persson G, et al. Immune response to collagen impregnated Dacron double velour grafts for aortic and aorto-femoral reconstructions. Eur J Vasc Surg. Aug. 1990;4(4):379-84. Not EVAR vs open or surveillance trial. [pmid: 2144492].
Ohkado A, Shiina Y, Nakajima T, et al. Evaluation of effect and distribution of heparin administered in vascular reconstructive surgery. Panminerva Med. Mar. 1999;41(1):18-21. Not EVAR vs open or surveillance trial. [pmid: 10230251].
Ohmi M, Ito T, Niibori K, et al. [Separate perfusion of upper and lower body under mild hypothermia during operation on the thoracoabdominal aorta]. Kyobu Geka. Aug. 1995;48(9):725-9. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 7564031].
Orend KH, Pamler R, Goerich J, et al. [Value of stent-assisted aneurysm treatment]. Langenbecks Arch Chir Suppl Kongressbd. 1998;115:1234-6. (Ger) Not English language. [pmid: 9931845].
Ouriel K, Clair DG, Greenberg RK, et al. Endovascular repair of abdominal aortic aneurysms: device-specific outcome. J Vasc Surg. May. 2003;37(5):991-8. Not EVAR vs open or surveillance trial. [pmid: 12756344].
Paaske WP, Laustsen J. Early results of 132 aortic or aorto-iliac arterial reconstructions with the new Stretch ePTFE vascular prosthesis. Int Angiol. Dec. 1994;13(4):296-9. Not EVAR vs open or surveillance trial. [pmid: 7790748].
Parra JR, Crabtree T, McLafferty RB, et al. Anesthesia technique and outcomes of endovascular aneurysm repair. Ann Vasc Surg. Jan. 2005;19(1):123-9. Not EVAR vs open or surveillance trial. [pmid: 15714381].
Patra P, Chaillou P, Bizouarn P. Intraoperative autotransfusion for repair of unruptured aneurysms of the infrarenal abdominal aorta. A multicenter study of 203 patients. Association Universitaire de Recherche en Chirurgie (AURC). J Cardiovasc Surg. Jun. 2000;41(3):407-13. Not EVAR vs open or surveillance trial. [pmid: 10952334].
Paty PS, Darling RC 3rd, Chang BB, et al. A prospective randomized study comparing exclusion technique and endoaneurysmorrhaphy for treatment of infrarenal aortic aneurysm. J Vasc Surg. Mar. 1997;25(3):442-5. Not EVAR vs open or surveillance trial. [pmid: 9081124].
Pevec WC, Holcroft JW, Blaisdell FW. Ligation and extraanatomic arterial reconstruction for the treatment of aneurysms of the abdominal aorta. [Review]. J Vasc Surg. Oct. 1994;20(4):629-36. Not RCT. [pmid: 7933265].
Piquet P, Amabile P, Rollet G. Minimally invasive retroperitoneal approach for the treatment of infrarenal aortic disease. J Vasc Surg. Sep. 2004;40(3):455-62. Not EVAR vs open or surveillance trial. [pmid: 15337873].
Quarmby JW, Burnand KG, Lockhart SJ, et al. Prospective randomized trial of woven versus collagen-impregnated knitted prosthetic Dacron grafts in aortoiliac surgery. Br J Surg. Jun. 1998;85(6):775-7. Not EVAR vs open or surveillance trial. [pmid: 9667705].
Raman KG, Missig-Carroll N, Richardson T, et al. Color-flow duplex ultrasound scan versus computed tomographic scan in the surveillance of endovascular aneurysm repair. J Vasc Surg. Oct. 2003;38(4):645-51. Not EVAR vs open or surveillance trial. [pmid: 14560207].
Rapp HJ, Rabethge S, Luiz T, et al. Perioperative ST-segment depression and troponin T release. Identification of patients with highest risk for myocardial damage. Acta Anaesthesiol Scand. Feb. 1999;43(2):124-9. Not EVAR vs open or surveillance trial. [pmid: 10027017].
Robbins M, Kritpracha B, Beebe HG, et al. Suprarenal endograft fixation avoids adverse outcomes associated with aortic neck angulation. Ann Vasc Surg. Mar. 2005;19(2):172-7. Not EVAR vs open or surveillance trial. [pmid: 15770368].
Sadahiro M, Sakurai M, Hata M, et al. [Open distal anastomosis or aortic balloon occlusion technique during complete aortic arch replacement]. Jpn J Thorac Cardiovasc Surg. Jul. 1998;46(7):610-5. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 9750443].
Sadahiro M, Tabayashi K, Ohmi M, et al. [Surgical treatment of type A aortic dissection based on the location of the entry]. Nippon Kyobu Geka Gakkai Zasshi. Mar. 1995;43(3):306-12. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 7769334].
Sampram ES, Karafa MT, Mascha EJ, et al. Nature, frequency, and predictors of secondary procedures after endovascular repair of abdominal aortic aneurysm. J Vasc Surg. May. 2003;37(5):930-7. Not EVAR vs open or surveillance trial. [pmid: 12756335].
Sangiorgi G, D'Averio R, Mauriello A, et al. Plasma levels of metalloproteinases-3 and -9 as markers of successful abdominal aortic aneurysm exclusion after endovascular graft treatment. Circulation. Sep 18. 2001;104(12 Suppl 1):I288-95. Not EVAR vs open or surveillance trial. [pmid: 11568071].
Sato DT, Goff CD, Gregory RT, et al. Endoleak after aortic stent graft repair: diagnosis by color duplex ultrasound scan versus computed tomography scan. J Vasc Surg. Oct. 1998;28(4):657-63. Not EVAR vs open or surveillance trial. [pmid: 9786261].
Schepens MA, Dekker E, Hamerlijnck RP, et al. Survival and aortic events after graft replacement for thoracoabdominal aortic aneurysm. Cardiovasc Surg. Dec. 1996;4(6):713-9. Not EVAR vs open or surveillance trial. [pmid: 9012997].
Schurink GW, Aarts NJ, van Bockel JH. Endoleak after stent-graft treatment of abdominal aortic aneurysm: a meta-analysis of clinical studies. Br J Surg. May. 1999;86(5):581-7. Not RCT. [pmid: 10361173].
Shah DM, Darling RC 3rd, Chang BB, et al. Access to the right renal artery from the left retroperitoneal approach. Cardiovasc Surg. Dec. 1996;4(6):763-5. Not EVAR vs open or surveillance trial. [pmid: 9013006].
Shah DM, Darling RC 3rd, Kreienberg PB, et al. A critical approach for longitudinal clinical trial of stretch PTFE aortic grafts. Cardiovasc Surg. Aug. 1997;5(4):414-8. Not EVAR vs open or surveillance trial. [pmid: 9350798].
Skora J, Janczak D, Szyber P, et al. [Radioisotopic diagnosis of infected anastomotic groin aneurysms after complications with aorto-bifemoral vascular prosthesis]. Wiad Lek. 1997;50(Suppl 1 Pt 2):23-6. (Pol) Not EVAR vs open or surveillance trial. [pmid: 9424879].
Speziale F, Zaccaria A, Rizzo L, et al. [Use of endoprosthesis in aortoiliac aneurysms]. Minerva Cardioangiol. Dec. 1999;47(12):565-6. (Ita) Not EVAR vs open or surveillance trial. [pmid: 10670205].
Sprouse LR 2nd, Meier GH 3rd, Parent FN, et al. Is three-dimensional computed tomography reconstruction justified before endovascular aortic aneurysm repair?. J Vasc Surg. Sep. 2004;40(3):443-7. Not EVAR vs open or surveillance trial. [pmid: 15337871].
Sternbergh WC 3rd, Money SR. Hospital cost of endovascular versus open repair of abdominal aortic aneurysms: a multicenter study. J Vasc Surg. Feb. 2000;31(2):237-44. Not RCT. [pmid: 10664492].
Stratton JR, Ritchie JL. Effect of suloctidil on tomographically quantitated platelet accumulation in Dacron aortic grafts. Am J Cardiol. Jul 1. 1986;58(1):152-6. Not EVAR vs open or surveillance trial. [pmid: 3014851].
Sueda T, Morita S, Okada K, et al. Selective intercostal arterial perfusion during thoracoabdominal aortic aneurysm surgery. Ann Thorac Surg. Jul. 2000;70(1):44-7. Not EVAR vs open or surveillance trial. [pmid: 10921680].
Teufelsbauer H, Prusa AM, Wolff K, et al. Endovascular stent grafting versus open surgical operation in patients with infrarenal aortic aneurysms: a propensity score-adjusted analysis. Circulation. Aug 13. 2002;106(7):782-7. Not RCT. [pmid: 12176947].
Thompson JP, Boyle JR, Thompson MM, et al. Nocturnal hypoxaemia and respiratory function after endovascular and conventional abdominal aortic aneurysm repair. Br J Anaesth. Jan. 1999;82(1):129-31. Not RCT. [pmid: 10325849].
Torsello GB, Kasprzak B, Klenk E, et al. Endovascular suture versus cutdown for endovascular aneurysm repair: a prospective randomized pilot study. J Vasc Surg. Jul. 2003;38(1):78-82. Not EVAR vs open or surveillance trial. [pmid: 12844093].
Treiman GS, Lawrence PF, Edwards WH Jr, et al. An assessment of the current applicability of the EVT endovascular graft for treatment of patients with an infrarenal abdominal aortic aneurysm. J Vasc Surg. Jul. 1999;30(1):68-75. Not EVAR vs open or surveillance trial. [pmid: 10394155].
Turnipseed WD, Carr SC, Hoch JR, et al. Minimal incision aortic surgery (MIAS). Ann Vasc Surg. Mar. 2003;17(2):180-4. Not EVAR vs open or surveillance trial. [pmid: 12632268].
Ueki M, Yokono S, Nogaya J, et al. [Effects of ulinastatin on renal function after subrenal aortic cross-clamping]. Masui. Mar 3. 1995;44(3):357-61. (Jap) Not EVAR vs open or surveillance trial; not English language. [pmid: 7745788].
Utoh J, Goto H, Hirata T, et al. Postoperative inflammatory reactions to sealed Dracon prostheses: a comparison of Gelseal and Hemashield. J Cardiovasc Surg. Jun. 1997;38(3):287-90. Not EVAR vs open or surveillance trial. [pmid: 9219480].
Utoh J, Miyauchi Y, Goto H, et al. Inflammatory reactions after vascular prosthesis implantation: a comparison of gelatin-sealed and unsealed Dacron prostheses. Surg Today. 1996;26(4):258-61. Not EVAR vs open or surveillance trial. [pmid: 8727946].
Valdes F, Seitz J, Fava M, et al. [Endovascular treatment of abdominal aortic aneurysm. Initial experience]. Rev Med Chil. Oct. 1998;126(10):1206-15. (Spa) Not EVAR vs open or surveillance trial. [pmid: 10030092].
Valentine RJ, Duke ML, Inman MH, et al. Effectiveness of pulmonary artery catheters in aortic surgery: a randomized trial. J Vasc Surg. Feb. 1998;27(2):203-11. Not EVAR vs open or surveillance trial. [pmid: 9510275].
Vallabhaneni SR, Gilling-Smith GL, How TV, et al. Aortic side branch perfusion alone does not account for high intra-sac pressure after endovascular repair (EVAR) in the absence of graft-related endoleak. Eur J Vasc Endovasc Surg. Apr. 2003;25(4):354-9. Not EVAR vs open or surveillance trial. [pmid: 12651175].
van Marrewijk C, Buth J, Harris PL, et al. Significance of endoleaks after endovascular repair of abdominal aortic aneurysms: The EUROSTAR experience. J Vasc Surg. Mar. 2002;35(3):461-73. Not RCT. [pmid: 11877693].
Velazquez OC, Carpenter JP, Baum RA, et al. Perigraft air, fever, and leukocytosis after endovascular repair of abdominal aortic aneurysms. Am J Surg. Sep. 1999;178(3):185-9. Not EVAR vs open or surveillance trial. [pmid: 10527435].
Villareal RP, Kar B, Howell MH, et al. Bare metal stents with or without coil embolization for abdominal aortic aneurysm exclusion in high-risk patients. Catheter Cardiovasc Interv. Sep. 2001;54(1):12-8. Not EVAR vs open or surveillance trial. [pmid: 11553942].
Volta CA, Ferri E, Marangoni E, et al. Respiratory function after aortic aneurysm repair: a comparison between retroperitoneal and transperitoneal approaches. Intensive Care Med. Aug. 2003;29(8):1258-64. Not EVAR vs open or surveillance trial. [pmid: 12830373].
von Segesser LK, Lorenzetti E, Lachat M, et al. Aortic valve preservation in acute type A dissection: is it sound?. J Thorac Cardiovasc Surg. Feb. 1996;111(2):381-90. Not EVAR vs open or surveillance trial. [pmid: 8583811].
Wagar D. Gadolinium CT aortography in stent-graft repair of abdominal aortic aneurysms. Acad Radiol. May. 2002;9(Suppl 1):S220-2. Not EVAR vs open or surveillance trial. [pmid: 12019873].
Wakefield TW, Shulkin BL, Fellows EP, et al. Platelet reactivity in human aortic grafts: a prospective, randomized midterm study of platelet adherence and release products in Dacron and polytetrafluoroethylene conduits. J Vasc Sur. Feb. 1989;9(2):234-43. Not EVAR vs open or surveillance trial.
Walschot LH, Laheij RJ, Verbeek AL. Outcome after endovascular abdominal aortic aneurysm repair: a meta-analysis. J Endovasc The. Feb. 2002;9(1):82-9. Not RCT.
Waters JH, Gottlieb A, Schoenwald P, et al. Normal saline versus lactated Ringer's solution for intraoperative fluid management in patients undergoing abdominal aortic aneurysm repair: an outcome study. Anesth Anal. Oct. 2001;93(4):817-22. Not EVAR vs open or surveillance trial.
Webster SE, Smith J, Thompson MM, et al. Does the sequence of clamp application during open abdominal aortic aneurysm surgery influence distal embolisation?. Eur J Vasc Endovasc Sur. Jan. 2004;27(1):61-4. Not EVAR vs open or surveillance trial.
Wenk H, Shekarriz H, Bruch HP. [Choice of vascular prosthesis material in treatment of infrarenal abdominal aortic aneurysms—initial results of a prospective randomized study]. Zentralbl Chir. 1997;122(9):743-6. (Ger) Not EVAR vs open or surveillance trial; not English language. [pmid: 9454481].
White RA, Donayre CE, Walot I, et al. Modular bifurcation endoprosthesis for treatment of abdominal aortic aneurysms. Ann Surg. Sep. 1997;226(3):381-9. Not EVAR vs open or surveillance trial. [pmid: 9339944]. [pmcid: 1191043].
Wijnen MH, Roumen RM, Vader HL, et al. A multiantioxidant supplementation reduces damage from ischaemia reperfusion in patients after lower torso ischaemia. A randomised trial. Eur J Vasc Endovasc Surg. Jun. 2002;23(6):486-90. Not EVAR vs open or surveillance trial. [pmid: 12093062].
Wilson NV, Melissari E, Standfield NJ, et al. Intra-operative antithrombotic therapy with low molecular weight heparin in aortic surgery. How should heparin be administered?. Eur J Vasc Surg. Oct. 1991;5(5):565-9. Not EVAR vs open or surveillance trial. [pmid: 1660009].
Wolowczyk L, Nevin M, Day A, et al. The effect of acute normovolaemic haemodilution on the inflammatory response and clinical outcome in abdominal aortic aneurysm repair—results of a pilot trial. Eur J Vasc Endovasc Surg. Jul. 2005;30(1):12-9. Not EVAR vs open or surveillance trial. [pmid: 15933977].
Yamasaki R, Komori K, Mori E, et al. [Usefulness of endovascular grafting for abdominal aortic aneurysm]. Fukuoka Igaku Zasshi. Jul. 1999;90(7):318-23. (Jap) Not RCT. [pmid: 10483147].
Yasuhara H, Shigematsu H, Muto T. Advantages of straight graft for abdominal aortic aneurysm repair. Panminerva Med. Sep. 1998;40(3):199-203. Not EVAR vs open or surveillance trial. [pmid: 9785917].
Zannetti S, De Rango P, Parente B, et al. Role of duplex scan in endoleak detection after endoluminal abdominal aortic aneurysm repair. Eur J Vasc Endovasc Surg. May. 2000;19(5):531-5. Not EVAR vs open or surveillance trial. [pmid: 10828236].
Zarins CK. AneuRx Clinical Investigators. The US AneuRx Clinical Trial: 6-year clinical update 2002. J Vasc Surg. Apr. 2003;37(4):904-8. Not RCT. [pmid: 12664000].
Zarins CK, Bloch DA, Crabtree T, et al. Aneurysm enlargement following endovascular aneurysm repair: AneuRx clinical trial. J Vasc Surg. Jan. 2004;39(1):109-17. Not RCT. [pmid: 14718827].
Zarins CK, Bloch DA, Crabtree T, et al. Stent graft migration after endovascular aneurysm repair: importance of proximal fixation. J Vasc Surg. Dec. 2003;38(6):1264-72. Not RCT. [pmid: 14681625].
Zarins CK, Crabtree T, Arko FR, et al. Endovascular repair or surveillance of patients with small AAA. Eur J Vasc Endovasc Surg. May. 2005;29(5):496-503. Not RCT. [pmid: 15966088].
Zarins CK, White RA, Schwarten D, et al. AneuRx stent graft versus open surgical repair of abdominal aortic aneurysms: multicenter prospective clinical trial. J Vasc Surg. Feb. 1999;29(2):292-305. Not RCT. [pmid: 9950987].
Zimmer S, Heiss MM, Schardey HM, et al. [Inflammatory syndrome after endovascular implantation of an aortic stent—a comparative study]. Langenbecks Arch Chir Suppl Kongressbd. 1998;115(Suppl I):13-7. (Ger) Not RCT. [pmid: 14518202].

## Question 2: Volume (reason for exclusion is provided in italics following each reference)

Albertini JN, Branchereau A, Hopkinson B, et al. Mortality and morbidity following endovascular repair of abdominal aortic aneurysms: analysis of two single centre experiences. Eur J Vasc Endovasc Surg. Nov. 2001;22(5):429-35. No volumes data. [pmid: 11735181].
Bastounis E, Filis K, Georgopoulos S, et al. Selective use of the intensive care unit after elective infrarenal abdominal aortic aneurysm repair. Int Angiol. Sep. 2003;22(3):308-16. No volumes data. [pmid: 14612859].
Carpenter JP. Endologix Investigators. Midterm results of the multicenter trial of the powerlink bifurcated system for endovascular aortic aneurysm repair. J Vasc Surg. Nov. 2004;40(5):849-59. No volumes data. [pmid: 15557896].
Cheng SW, Ting AC, Tsang SH. Epidemiology and outcome of aortic aneurysms in Hong Kong. World J Surg. Feb. 2003;27(2):241-5. No volumes data. [pmid: 12616444].
Cowan JA Jr, Dimick JB, Henke PK, et al. Surgical treatment of intact thoracoabdominal aortic aneurysms in the United States: hospital and surgeon volume-related outcomes. J Vasc Surg. Jun. 2003;37(6):1169-74. Not unruptured AAA treatment. [pmid: 12764260].
Cowan JA Jr, Dimick JB, Wainess RM, et al. Ruptured thoracoabdominal aortic aneurysm treatment in the United States: 1988 to 1998. J Vasc Surg. Aug. 2003;38(2):319-22. Not unruptured AAA treatment. [pmid: 12891114].
de Donato G, Sarradon P, Weber G, et al. Current role of the minimally invasive direct aortic surgery for 3-A repair (MIDAS-3A). [Review]. Chir Ital. Sep–Oct. 2003;55(5):625-36. No volumes data. [pmid: 14587105].
Dimick JB, Pronovost PJ, Cowan JA, et al. The volume-outcome effect for abdominal aortic surgery: differences in case-mix or complications?. Arch Surg. Jul. 2002;137(7):828-32. Data previously reported. [pmid: 12093341].
Dimick JB, Pronovost PJ, Cowan JA Jr, et al. Should older patients be selectively referred to high-volume centers for abdominal aortic surgery?. Vascular. Jan. 2004;12(1):51-6. Data previously reported. [pmid: 15127855].
Dimick JB, Upchurch GR Jr. The quality of care for patients with abdominal aortic aneurysms. [Review]. Cardiovasc Surg. Oct. 2003;11(5):331-6. Data previously reported. [pmid: 12958541].
Dueck AD, Johnston KW, Alter D, et al. Predictors of repair and effect of gender on treatment of ruptured abdominal aortic aneurysm. J Vasc Surg. Apr. 2004;39(4):784-7. Not unruptured AAA treatment. [pmid: 15071441].
Dueck AD, Kucey DS, Johnston KW, et al. Survival after ruptured abdominal aortic aneurysm: effect of patient, surgeon, and hospital factors. J Vasc Surg. Jun. 2004;39(6):1253-60. Not unruptured AAA treatment. [pmid: 15192566].
Forbes TL, De Rose G, Harris KA. A CUSUM analysis of ruptured abdominal aortic aneurysm repair. Ann Vasc Surg. Sep. 2002;16(5):527-33. Not unruptured AAA treatment. [pmid: 12203003].
Huber TS, Seeger JM. Dartmouth Atlas of Vascular Health Care review: impact of hospital volume, surgeon volume, and training on outcome. J Vasc Surg. Oct. 2001;34(4):751-6. Review. [pmid: 11668335].
Shaw PM, Veith FJ, Lipsitz EC, et al. Open aneurysm repair at an endovascular center: value of a modified retroperitoneal approach in patients at high risk with difficult aneurysms. J Vasc Surg. Sep. 2003;38(3):504-10. No volumes data. [pmid: 12947268].
Tu JV, Austin PC, Johnston KW. The influence of surgical specialty training on the outcomes of elective abdominal aortic aneurysm surgery. J Vasc Surg. Mar. 2001;33(3):447-52. No volumes data. [pmid: 11241111].
Urbach DR, Baxter NN. Does it matter what a hospital is “high volume” for? Specificity of hospital volume-outcome associations for surgical procedures: analysis of administrative data. Qual Saf Health Care. Oct. 2004;13(5):379-83. Not US study. [pmid: 15465942]. [pmcid: 1743878].
Waters JH, Gottlieb A, Schoenwald P, et al. Normal saline versus lactated Ringer's solution for intraoperative fluid management in patients undergoing abdominal aortic aneurysm repair: an outcome study. Anesth Analg. Oct. 2001;93(4):817-22. No volumes data. [pmid: 11574339].
Wong JC, Torella F, Haynes SL, et al. Autologous versus allogeneic transfusion in aortic surgery: a multicenter randomized clinical trial. Ann Surg. Jan. 2002;235(1):145-51. No volumes data. [pmid: 11753054]. [pmcid: 1422408].

## Question 4: Cost (reason for exclusion is provided in italics following each reference)

Abularrage CJ, Sheridan MJ, Mukherjee D. Endovascular versus “fast-track” abdominal aortic aneurysm repair. Vasc Endovasc Sur. May–Jun. 2005;39(3):229-36. Less than 50 patients / treatment arm.
Adachi K, Iwasawa T, Ono T. Screening for abdominal aortic aneurysms during a basic medical checkup in residents of a Japanese rural community. Surg Today. 2000;30(7):594-9. Not AAA EVAR/open treatment trial. [pmid: 10930224].
Anonymous. Screening for abdominal aortic aneurysms. Health News 2003 Oct; 9(10):10. Not AAA EVAR/open treatment trial
Anonymous. Socioeconomic tips of the month. Coding for endovascular abdominal aortic aneurysm repair. Bull Am Coll Surg 2001 Mar; 86(3):44–5. No cost data
Anonymous. Stemming losses from AAA endografts. OR Manager 2003 Jun; 19(6):26. No cost data
Arko FR, Filis KA, Heikkinen MA, et al. Duplex scanning after endovascular aneurysm repair: an alternative to computed tomography. [Review]. Semin Vasc Surg. Jun. 2004;17(2):161-5. Not AAA EVAR/open treatment trial. [pmid: 15185182].
Aune S, Laxdal E, Pedersen G, et al. Lifetime gain related to cost of repair of ruptured abdominal aortic aneurysm in octogenarians. Eur J Vasc Endovasc Surg. Mar. 2004;27(3):299-304. No data of interest. [pmid: 14760600].
Axelrod DA, Diwan A, Stanley JC, et al. Cost of routine screening for carotid and lower extremity occlusive disease in patients with abdominal aortic aneurysms. J Vasc Surg. Apr. 2002;35(4):754-8. Not AAA EVAR/open treatment trial. [pmid: 11932675].
Bader RS, Goldberg L, Sahn DJ. Risk of sudden cardiac death in young athletes: which screening strategies are appropriate? [Review]. Pediatr Clin North Am. Oct. 2004;51(5):1421-41. Not AAA EVAR/open treatment trial. [pmid: 15331292].
Ballard DJ, Fowkes FG, Powell JT. Surgery for small asymptomatic abdominal aortic aneurysms. [Review]. Cochrane Database Syst Rev 2000; (2):CD001835. Review
Ballard JL, Abou-Zamzam AM, Teruya TH, et al. Quality of life before and after endovascular and retroperitoneal abdominal aortic aneurysm repair. J Vasc Surg. Apr. 2004;39(4):797-803. Less than 50 patients in treatment arm. [pmid: 15071445].
Ballard JL, Yonemoto H, Killeen JD. Cost-effective aortic exposure: a retroperitoneal experience. Ann Vasc Surg. Jan. 2000;14(1):1-5. Less than 50 patients / treatment arm. [pmid: 10629256].
Barone JE, Tucker JB, Bull SM. The Leapfrog Initiative: a potential threat to surgical education. Curr Surg. Mar–Apr. 2003;60(2):218-21. No cost data. [pmid: 14972300].
Beard JD. Screening for abdominal aortic aneurysm. Br J Surg. May. 2003;90(5):515-6. Not AAA EVAR/open treatment trial. [pmid: 12734854].
Becker C. Stealth fighter. Abdominal aortic aneurysms can kill quickly and silently. Some say the best prevention is increased screening and surgery to implant sophisticated grafts. Mod Healthc. Feb 14. 2005;35(7):52-56. Not AAA EVAR/open treatment trial.
Bein B, Turowski P, Renner J, et al. Comparison of xenon-based anaesthesia compared with total intravenous anaesthesia in high risk surgical patients. Anaesthesia. Oct. 2005;60(10):960-7. Not AAA EVAR/open treatment trial. [pmid: 16179039].
Beinfeld MT, Wittenberg E, Gazelle GS. Cost-effectiveness of whole-body CT screening. Radiology. Feb. 2005;234(2):415-22. Not AAA EVAR/open treatment trial. [pmid: 15670999].
Bell PR. Endovascular repair of abdominal aortic aneurysms. Vasc Med. 2002;7(4):253-5. Not AAA EVAR/open treatment trial. [pmid: 12710838].
Bendick PJ, Zelenock GB, Bove PG, et al. Duplex ultrasound imaging with an ultrasound contrast agent: the economic alternative to CT angiography for aortic stent graft surveillance. Vasc Endovasc Surg. May–Jun. 2003;37(3):165-70. Not AAA EVAR/open treatment trial.
Bensenor IM. Screening for abdominal aortic aneurysm. [comment]. Sao Paulo Med J. Jul 1. 2004;122(4):139-40. Not AAA EVAR/open treatment trial. [pmid: 15543366].
Berman SS, Gentile AT, Berens ES, et al. Institutional economic losses associated with AAA repair are independent of technique. J Endovasc Ther. Jun. 2002;9(3):282-8. Less than 50 patients / treatment arm. [pmid: 12096941].
Bertges DJ, Rhee RY, Muluk SC, et al. Is routine use of the intensive care unit after elective infrarenal abdominal aortic aneurysm repair necessary?. J Vasc Surg. Oct. 2000;32(4):634-42. No AAA repair cost data. [pmid: 11013024].
Boll AP, Severens JL, Verbeek AL, et al. Mass screening on abdominal aortic aneurysm in men aged 60 to 65 years in The Netherlands. Impact on life expectancy and cost-effectiveness using a Markov model. Eur J Vasc Endovasc Surg. Jul. 2003;26(1):74-80. Not AAA EVAR/open treatment trial. [pmid: 12819652].
Bonamigo TP, Siqueira I. Screening for abdominal aortic aneurysms. Rev Hosp Clin Fac Med Sao Paulo. Mar–Apr. 2003;58(2):63-8. Not AAA EVAR/open treatment trial. [pmid: 12845357].
Brown LC, Epstein D, Manca A, et al. The UK Endovascular Aneurysm Repair (EVAR) trials: design, methodology and progress. Eur J Vasc Endovasc Surg. Apr. 2004;27(4):372-81. No cost data. [pmid: 15015186].
Buckley CJ, Patterson DE, Manning LG, et al. Quality vascular surgical care: the importance of innovation and change in an era of dwindling reimbursement. South Med J. Apr. 2001;94(4):411-6. Not AAA EVAR/open treatment trial. [pmid: 11332908].
Bush RL, Najibi S, Lin PH, et al. Conservatism and new technology: the impact on abdominal aortic aneurysm repair. Am Surg. Jan. 2002;68(1):57-60. No cost data. [pmid: 12467319].
Cambria RP, Clouse WD, Davison JK, et al. Thoracoabdominal aneurysm repair: results with 337 operations performed over a 15-year interval. Ann Surg. Oct. 2002;236(4):471-9. No AAA repair cost data. [pmid: 12368676]. [pmcid: 1422602].
Chew HF, You CK, Brown MG, et al. Mortality, morbidity, and costs of ruptured and elective abdominal aortic aneurysm repairs in Nova Scotia, Canada. Ann Vasc Surg. Mar. 2003;17(2):171-9. Less than 50 patients / arm. [pmid: 12616362].
Chiu KM, Lin TY, Huang PH, et al. Hand-assisted laparoscopic surgery for abdominal aortic aneurysm. J Formos Med Assoc. Sep. 2004;103(9):724-6. Not AAA EVAR/open treatment trial. [pmid: 15361948].
Connelly JB, Hill GB, Millar WJ. The detection and management of abdominal aortic aneurysm: a cost-effectiveness analysis. Clin Invest Med. Aug. 2002;25(4):127-33. Not AAA EVAR/open treatment trial. [pmid: 12220039].
Cornuz J, Sidoti Pinto C, Tevaearai H, et al. Risk factors for asymptomatic abdominal aortic aneurysm: systematic review and meta-analysis of population-based screening studies. [Review]. Eur J Public Health. Dec. 2004;14(4):343-9. Not AAA EVAR/open treatment trial. [pmid: 15542867].
Daly KJ, Torella F, Ashleigh R, et al. Screening, diagnosis and advances in aortic aneurysm surgery. [Review]. Gerontology. Nov–Dec. 2004;50(6):349-59. Not AAA EVAR/open treatment trial. [pmid: 15477695].
DeBois WJ, Girardi LN, Lawrence S, et al. Perfusion method for thoracoabdominal aneurysm repair using the open distal technique. Perfusion. Jun. 2000;15(3):231-6. Not AAA EVAR/open treatment trial. [pmid: 10866425].
Demaria RG, Borie F, Albat B, et al. Simple surgical technique to prevent direct secondary aortoenteric fistulas. [Review]. J Cardiovasc Surg. Feb. 2002;43(1):99-101. Not AAA EVAR/open treatment trial. [pmid: 11803339].
Derrow AE, Seeger JM, Dame DA, et al. The outcome in the United States after thoracoabdominal aortic aneurysm repair, renal artery bypass, and mesenteric revascularization. J Vasc Surg. Jul. 2001;34(1):54-61. Not AAA EVAR/open treatment trial. [pmid: 11436075].
Duncan JL, Wolf B, Nichols DM, et al. Screening for abdominal aortic aneurysm in a geographically isolated area. Br J Surg. Aug. 2005;92(8):984-8. Not AAA EVAR/open treatment trial. [pmid: 16034847].
Ebaugh JL, Garcia ND, Matsumura JS. Screening and surveillance for abdominal aortic aneurysms: who needs it and when. [Review]. Semin Vasc Surg. Sep. 2001;14(3):193-9. Not AAA EVAR/open treatment trial. [pmid: 11561280].
Edwards JT, Wood CJ, Mendelson RM, et al. Extracolonic findings at virtual colonoscopy: implications for screening programs. Am J Gastroenterol. Oct. 2001;96(10):3009-12. Not AAA EVAR/open treatment trial. [pmid: 11693340].
Engellau L, Albrechtsson U, Hojgard S, et al. Costs in follow-up of endovascularly repaired abdominal aortic aneurysms. Magnetic resonance imaging with MR angiography versus EUROSTAR protocols. Int Angiol. Mar. 2003;22(1):36-42. Not AAA EVAR/open treatment trial. [pmid: 12771854].
Fleisher LA, Corbett W, Berry C, et al. Cost-effectiveness of differing perioperative beta-blockade strategies in vascular surgery patients. J Cardiothorac Vasc Anesth. Feb. 2004;18(1):7-13. Not AAA EVAR/open treatment trial. [pmid: 14973792].
Forbes TL. Costs of open versus endovascular abdominal aortic aneurysm repair. [comment]. J Am Coll Surg. Feb. 2004;198(2):329. Comment. [pmid: 14759791].
Forbes TL, DeRose G, Kribs S, et al. A cost-effectiveness analysis of standard versus endovascular abdominal aortic aneurysm repair. Can J Surg. Dec. 2002;45(6):420-4. Less than 50 patients / arm. [pmid: 12500916].
Galloo P. Introduction of stent grafts in the management of patients with a abdominal or thoracic aortic aneurysm: why, perspectives, results. Acta Chir Belg. Feb. 2004;104(1):8-10. Not AAA EVAR/open treatment trial. [pmid: 15053458].
Gardner A, Gibbs N, Evans C, et al. Relative cost of autologous red cell salvage versus allogeneic red cell transfusion during abdominal aortic aneurysm repair. Anaesth Intensive Care. Dec. 2000;28(6):646-9. Not AAA EVAR/open treatment trial. [pmid: 11153290].
Gioia LC, Filion KB, Haider S, et al. Hospital readmissions following abdominal aortic aneurysm repair. Ann Vasc Surg. Jan. 2005;19(1):35-41. Not AAA EVAR/open treatment trial. [pmid: 15714365].
Golzarian J, Dussaussois L, Ait Said K, et al. Embolization of large aneurysms with long wire coils. Cardiovasc Intervent Radiol. Jan–Feb. 2002;25(1):26-9. Not AAA treatment trial. [pmid: 11907770].
Gray Sears CL, Ward JF, Sears ST, et al. Prospective comparison of computerized tomography and excretory urography in the initial evaluation of asymptomatic microhematuria. J Urol. Dec. 2002;168(6):2457-60. Not AAA EVAR/open treatment trial. [pmid: 12441939].
Green RM, Waldman D. Center for Vascular Disease Uo Rochester. Five-year results of a merger between vascular surgeons and interventional radiologists in a university medical center. J Vasc Surg. Dec. 2003;38(6):1213-9. Not AAA EVAR/open treatment trial. [pmid: 14681616].
Greenhalgh RM, Powell JT. Screening men for aortic aneurysm[comment]. BMJ. Nov 16. 2002;325(7373):1123-4. Not AAA EVAR/open treatment trial. [pmid: 12433740]. [pmcid: 1124619].
Gurbuz A, Kirali K, Tuncer A, et al. Combined transdiaphragmatic MIDCAB with right gastroepiploic artery and abdominal aortic aneurysm repair. Cardiovasc Surg. Oct. 2000;8(6):503-6. Not AAA EVAR/open treatment trial. [pmid: 10996108].
Hallett JW Jr. Predicting the future of vascular health care: the impact of the baby boom generation. Semin Vasc Surg. Mar. 2001;14(1):54-63. Not AAA EVAR/open treatment trial. [pmid: 11239386].
Hara AK, Johnson CD, MacCarty RL, et al. Incidental extracolonic findings at CT colonography. Radiology. May. 2000;215(2):353-7. Not AAA EVAR/open treatment trial. [pmid: 10796907].
Haulon S, Tyazi A, Willoteaux S, et al. Embolization of type II endoleaks after aortic stent-graft implantation: technique and immediate results. J Vasc Surg. Oct. 2001;34(4):600-5. No cost data. [pmid: 11668311].
Haveman JW, Karliczek A, Verhoeven E, et al. Multicentre Aneurysm Screening Study (MASS). [comment]. Lancet. Mar 22. 2003;361(9362):1058. Comment. [pmid: 12660086].
Henriksson M, Lundgren F. Decision-analytical model with lifetime estimation of costs and health outcomes for one-time screening for abdominal aortic aneurysm in 65-year-old men. Br J Surg. Aug. 2005;92(8):976-83. Not AAA EVAR/open treatment trial. [pmid: 16034844].
Hobbs S, Claridge M, Drage M, et al. Strategies to improve the effectiveness of abdominal aortic aneurysm screening programmes. J Med Screen. 2004;11(2):93-6. Not AAA EVAR/open treatment trial. [pmid: 15153325].
Hobbs SD, Wilmink AB, Bradbury AW. Ethnicity and peripheral arterial disease. [Review]. Eur J Vasc Endovasc Surg. Jun. 2003;25(6):505-12. Not AAA EVAR/open treatment trial. [pmid: 12787691].
Huynh TT, Miller CC 3rd, Estrera AL, et al. Determinants of hospital length of stay after thoracoabdominal aortic aneurysm repair. J Vasc Surg. Apr. 2002;35(4):648-53. Not AAA EVAR/open treatment trial. [pmid: 11932657].
Ishikawa S, Takahashi T, Sato Y, et al. Screening cost for abdominal aortic aneurysms: Japan-based estimates. Surg Today. 2004;34(10):828-31. Not AAA EVAR/open treatment trial. [pmid: 15449151].
Johnson BL, Dalman RL. Duplex surveillance of abdominal aortic stent grafts. [Review]. Semin Vasc Surg. Sep. 2001;14(3):227-32. Not AAA EVAR/open treatment trial. [pmid: 11561285].
Kan CB, Wang JS, Yu TJ, et al. Is combined abdominal aortic aneurysm repair and coronary artery bypass grafting feasible?. Chin Med J. Jan. 2002;65(1):29-33. Not AAA EVAR/open treatment trial.
Kaspersen JH, Aasland J, Leira HO, et al. Three-dimensional teleradiology for surveillance following endovascular aortic aneurysm repair: a feasibility study. J Endovasc Ther. Apr. 2005;12(2):196-9. Not AAA EVAR/open treatment trial. [pmid: 15823066].
Kedjanyi WK, Gupta D. Near total transection of the trachea following percutaneous dilatational tracheostomy. J R Coll Surg Edinb. Aug. 2001;46(4):242-3. Not AAA EVAR/open treatment trial. [pmid: 11523719].
Kertai MD, Bax JJ, Boersma E, et al. The prognostic value of dobutamine stress echocardiography in patients with abdominal aortic aneurysm and concomitant coronary artery disease. [Review]. J Cardiovasc Surg. Jun. 2003;44(3):423-30. Not AAA EVAR/open treatment trial. [pmid: 12832996].
Kim LG, Scott RA, Thompson SG, et al. Implications of screening for abdominal aortic aneurysms on surgical workload. Br J Surg. Feb. 2005;92(2):171-6. Not AAA EVAR/open treatment trial. [pmid: 15505873].
Krupski WC. Con: Endovascular stent repair for aortic aneurysm surgery is not associated with lower perioperative risk. [comment]. [Review]. J Cardiothorac Vasc Anesth. Oct. 2003;17(5):659-67. Review. [pmid: 14579225].
Krupski WC, Rutherford RB. Update on open repair of abdominal aortic aneurysms: the challenges for endovascular repair. [Review]. J Am Coll Surg. Dec. 2004;199(6):946-60. Review. [pmid: 15555979].
Laohapensang K, Rerkasem K, Chotirosniramit N. Left retroperitoneal versus midline transperitoneal approach for abdominal aortic aneurysms (AAAs) repair. J Med Assoc Thai. May. 2005;88(5):601-6. Less than 50 patients / arm. [pmid: 16149675].
Lederle FA. Ultrasonographic screening for abdominal aortic aneurysms. [Review]. Ann Int Med. Sep 16. 2003;139(6):516-22. Not AAA EVAR/open treatment trial. [pmid: 13679330].
Lee TY, Korn P, Heller JA, et al. The cost-effectiveness of a “quick-screen” program for abdominal aortic aneurysms. Surgery. Aug. 2002;132(2):399-407. Not AAA EVAR/open treatment trial. [pmid: 12219041].
Leshno M, Levy H. Stochastic dominance and medical decision making. Health Care Manag Sci. Aug. 2004;7(3):207-15. Not AAA EVAR/open treatment trial. [pmid: 15648563].
Liapis C, Kakisis J, Kaperonis E, et al. Changes of the infrarenal aortic segment after conventional abdominal aortic aneurysm repair. Eur J Vasc Endovasc Surg. Jun. 2000;19(6):643-7. Not AAA EVAR/open treatment trial. [pmid: 10873734].
Lindholt JS, Juul S, Fasting H, et al. Hospital costs and benefits of screening for abdominal aortic aneurysms. Results from a randomised population screening trial. Eur J Vasc Endovasc Surg. Jan. 2002;23(1):55-60. Not AAA EVAR/open treatment trial. [pmid: 11748949].
Lippmann M, Lingam K, Rubin S, et al. Anesthesia for endovascular repair of abdominal and thoracic aortic aneurysms: a review article. [Review]. J Cardiovasc Surg. Jun. 2003;44(3):443-51. Not AAA EVAR/open treatment trial. [pmid: 12832999].
Lippmann M, Rubin S, Ginsburg R, et al. An alternative anesthetic technique for the morbidly obese patient undergoing endovascular repair of an abdominal aortic aneurysm. Anesth Analg. Oct. 2003;97(4):981-3. Not AAA EVAR/open treatment trial. [pmid: 14500144].
Lipsitz EC, Ohki T, Veith FJ, et al. Limited role for IVUS in the endovascular repair of aortoiliac aneurysms. J Cardiovasc Surg. Dec. 2001;42(6):787-92. Not AAA EVAR/open treatment trial. [pmid: 11698948].
Longo C, Upchurch GR Jr. Abdominal aortic aneurysm screening: recommendations and controversies. [Review]. Vasc Endovasc Surg. May–Jun. 2005;39(3):213-9. Not AAA EVAR/open treatment trial.
Malinzak LE, Long GW, Bove PG, Brown OW, Romano W, Shanley CJ, et al. Gastrointestinal complications following infrarenal endovascular aneurysm repair. Vascular & Endovascular Surgery. Mar–Apr. 2004;38(2):137-42. Not AAA EVAR/open treatment trial. [pmid: 15064844].
Maloney JD, Hoch JR, Carr SC, et al. Preliminary experience with minilaparotomy aortic surgery. Ann Vasc Surg. Jan. 2000;14(1):6-12. Not AAA EVAR/open treatment trial. [pmid: 10629257].
Matsumoto K, Murayama T, Nagasaki K, et al. One-stage surgical management of concomitant abdominal aortic aneurysm and gastric or colorectal cancer. World J Surg. Apr. 2002;26(4):434-7. Less than 50 patients / arm. [pmid: 11910475].
Matsumoto M, Hata T, Tsushima Y, et al. Minimally invasive vascular surgery for repair of infrarenal abdominal aortic aneurysm with iliac involvement. J Vasc Surg. Apr. 2002;35(4):654-60. Less than 50 patients / arm. [pmid: 11932658].
Milner QJ, Burchett KR. Long-term survival following emergency abdominal aortic aneurysm repair. Anaesthesia. May. 2000;55(5):432-5. Not AAA EVAR/open treatment trial. [pmid: 10792133].
Montgomery ML, Sullivan JP. Advances in interventional radiology. The search for less invasive management sparks new approaches. [Review]. Postgrad Med 2001 Jun; 109(6):93–4, 97–9, 103–4. Review
Morimoto K, Taniguchi I, Miyasaka S, et al. Usefulness of one-stage coronary artery bypass grafting on the beating heart and abdominal aortic aneurysm repair. Ann Thorac Cardiovasc Surg. Feb. 2004;10(1):29-33. Not AAA EVAR/open treatment trial. [pmid: 15008696].
Morishita K, Kawaharada N, Fukada J, et al. Can minilaparotomy abdominal aortic aneurysm repair be performed safely and effectively without special skills?. Surgery. Apr. 2003;133(4):390-5. Not AAA EVAR/open treatment trial. [pmid: 12717356].
Mosorin M, Juvonen J, Biancari F, et al. Use of doxycycline to decrease the growth rate of abdominal aortic aneurysms: a randomized, double-blind, placebo-controlled pilot study. J Vasc Surg. Oct. 2001;34(4):606-10. Not AAA EVAR/open treatment trial. [pmid: 11668312].
Muir Gray JA. Screening for abdominal aortic aneurysm. Br J Surg. Sep. 2003;90(9):1165. Not AAA EVAR/open treatment trial. [pmid: 12945090].
Multicentre Aneurysm Screening Study Group. Multicentre aneurysm screening study (MASS): cost effectiveness analysis of screening for abdominal aortic aneurysms based on four year results from randomised controlled trial. BMJ. Nov 16. 2002;325(7373):1135. Not AAA EVAR/open treatment trial. [pmid: 12433761].
Myers KA. Endoluminal grafting for abdominal aortic aneurysms: where will the buck stop? [comment]. Aust N Z J Surg. Nov. 2000;70(11):767-8. Not AAA EVAR/open treatment trial. [pmid: 11147434].
Nomura F, Mukai S, Fumimoto Y, et al. Reliable and cost-effective system for surgical stent graft insertion. Ann Thorac Surg. Dec. 2000;70(6):2171-2. Not AAA EVAR/open treatment trial. [pmid: 11156152].
Patra P, Chaillou P, Bizouarn P. Intraoperative autotransfusion for repair of unruptured aneurysms of the infrarenal abdominal aorta. A multicenter study of 203 patients. Association Universitaire de Recherche en Chirurgie (AURC). J Cardiovasc Surg. Jun. 2000;41(3):407-13. Not AAA EVAR/open treatment trial. [pmid: 10952334].
Pentikainen TJ, Sipila T, Rissanen P, et al. Cost-effectiveness of targeted screening for abdominal aortic aneurysm. Monte Carlo-based estimates. Int J Technol Assess Health Care. 2000;16(1):22-34. Not AAA EVAR/open treatment trial. [pmid: 10815351].
Post PN, Kievit J, van Bockel JH. Optimal follow-up strategies after aorto-iliac prosthetic reconstruction: a decision analysis and cost-effectiveness analysis. Eur J Vasc Endovasc Surg. Sep. 2004;28(3):287-95. Not AAA EVAR/open treatment trial. [pmid: 15288633].
Powell JT, Brady AR. Detection, management, and prospects for the medical treatment of small abdominal aortic aneurysms. [Review]. Arterioscler Thromb Vasc Biol. Feb. 2004;24(2):241-5. Not AAA EVAR/open treatment trial. [pmid: 14604835].
Prinssen M, Buskens E, Blankensteijn JD. The Dutch Randomised Endovascular Aneurysm Management (DREAM) trial. Background, design and methods. J Cardiovasc Surg. Jun. 2002;43(3):379-84. No cost data. [pmid: 12055570].
Pronovost P, Garrett E, Dorman T, et al. Variations in complication rates and opportunities for improvement in quality of care for patients having abdominal aortic surgery. Langenbecks Arch Surg. Jul. 2001;386(4):249-56. Not AAA EVAR/open treatment trial. [pmid: 11466565].
Prytherch DR, Ridler BM, Ashley S, et al. Risk-adjusted predictive models of mortality after index arterial operations using a minimal data set. Br J Surg. Jun. 2005;92(6):714-8. Not AAA EVAR/open treatment trial. [pmid: 15810045].
Puech-Leao P. Screening for abdominal aortic aneurysms: is it worthy?[comment]. Rev Hosp Clin Fac Med Univ Sao Paulo. Mar–Apr. 2003;58(2):61-2. Not AAA EVAR/open treatment trial.
Ravhon R, Adam D, Zelmanovitch L. Validation of ultrasonic image boundary recognition in abdominal aortic aneurysm. IEEE Trans Med Imaging. Aug. 2001;20(8):751-63. Not AAA EVAR/open treatment trial. [pmid: 11513026].
Rigberg DA, Dorafshar A, Sridhar A, et al. Abdominal aortic aneursym: stent graft vs clinical pathway for direct retroperitoneal repair. Arch Surg. Sep. 2004;139(9):941-4. Not AAA EVAR/open treatment trial. [pmid: 15381610].
Rosenberg BL, Comstock MC, Butz DA, et al. Endovascular abdominal aortic aneurysm repair is more profitable than open repair based on contribution margin per day. Surgery. Mar. 2005;137(3):285-92. No cost data. [pmid: 15746778].
Rubin GD, Armerding MD, Dake MD, et al. Cost identification of abdominal aortic aneurysm imaging by using time and motion analyses. Radiology. Apr. 2000;215(1):63-70. Not AAA EVAR/open treatment trial. [pmid: 10751469].
Rutherford RB. Structural failures in abdominal aortic aneurysm stentgrafts: Threat to durability and challenge to technology. [Review]. Semin Vasc Surg. Dec. 2004;17(4):294-7. Not AAA EVAR/open treatment trial. [pmid: 15614754].
Rutherford RB, Krupski WC. Current status of open versus endovascular stent-graft repair of abdominal aortic aneurysm. [Review]. J Vasc Surg. May. 2004;39(5):1129-39. Review. [pmid: 15111875].
Saket RR, Razavi MK, Padidar A, et al. Novel intravascular ultrasound-guided method to create transintimal arterial communications: initial experience in peripheral occlusive disease and aortic dissection. J Endovasc Ther. Jun. 2004;11(3):274-80. Not AAA EVAR/open treatment trial. [pmid: 15174902].
Scott RA, Bridgewater SG, Ashton HA. Randomized clinical trial of screening for abdominal aortic aneurysm in women. Br J Surg. Mar. 2002;89(3):283-5. Not AAA EVAR/open treatment trial. [pmid: 11872050].
Shuhaiber JH, Whitehead SM. The impact of introducing an autologous intraoperative transfusion device to a community hospital. Ann Vasc Surg. Jul. 2003;17(4):424-9. Not AAA EVAR/open treatment trial. [pmid: 14670022].
Siepel T, Clifford DS, James PA, et al. The ultrasound-assisted physical examination in the periodic health evaluation of the elderly. J Fam Pract. Jul. 2000;49(7):628-32. Not AAA EVAR/open treatment trial. [pmid: 10923573].
Soisalon-Soininen S, Rissanen P, Pentikainen T, et al. Cost-effectiveness of screening for familial abdominal aortic aneurysms. Vasa. Nov. 2001;30(4):262-70. Not AAA EVAR/open treatment trial. [pmid: 11771210].
Sparks AR, Johnson PL, Meyer MC. Imaging of abdominal aortic aneurysms. [Review]. Am Fam Physician. Apr 15. 2002;65(8):1565-70. Not AAA EVAR/open treatment trial. [pmid: 11989632].
Steinmetz E, Rubin BG, Sanchez LA, et al. Type II endoleak after endovascular abdominal aortic aneurysm repair: a conservative approach with selective intervention is safe and cost-effective. J Vasc Surg. Feb. 2004;39(2):306-13. Not AAA EVAR/open treatment trial. [pmid: 14743129].
Sternbergh WC. The costs of endovascular versus transabdominal abdominal aortic aneurysm (AAA) repair. [comment]. Ann Surg. Nov. 2000;232(5):725-6. Commentary.
Sweeney AB, Flora HS, Chaloner EJ, et al. Integrated care pathways for vascular surgery: an analysis of the first 18 months. Postgrad Med J. Mar. 2002;78(917):175-7. Not AAA EVAR/open treatment trial. [pmid: 11884705]. [pmcid: 1742285].
Tang T, Lindop M, Munday I, et al. A cost analysis of surgery for ruptured abdominal aortic aneurysm. Eur J Vasc Endovasc Surg. Sep. 2003;26(3):299-302. Not AAA EVAR/open treatment trial. [pmid: 14509894].
Thurnher S, Cejna M. Imaging of aortic stent-grafts and endoleaks. [Review]. Radiol Clin North Am. Jul. 2002;40(4):799-833. Not AAA EVAR/open treatment trial. [pmid: 12171186].
Torsello GB, Kasprzak B, Klenk E, et al. Endovascular suture versus cutdown for endovascular aneurysm repair: a prospective randomized pilot study. J Vasc Surg. Jul. 2003;38(1):78-82. Less than 50 patients / treatment arm. [pmid: 12844093].
Townsend J, Buxton M, Harper G. Prioritisation of health technology assessment. The PATHS model: methods and case studies. [Review]. Health Technol Assess 2003; 7(20):iii, 1–82. Not AAA EVAR/open treatment trial
Turnipseed W, Tefera G, Carr S. Comparison of minimal incision aortic surgery with endovascular aortic repair. Am J Surg. Sep. 2003;186(3):287-91. Review. [pmid: 12946834].
Turnipseed WD, Carr SC, Hoch JR, et al. Minimal incision aortic surgery (MIAS). Ann Vasc Surg. Mar. 2003;17(2):180-4. Not AAA EVAR/open treatment trial. [pmid: 12632268].
Turnipseed WD, Carr SC, Tefera G, et al. Minimal incision aortic surgery. J Vasc Surg. Jul. 2001;34(1):47-53. Less than 50 patients / treatment arm. [pmid: 11436074].
Urban BA, Fishman EK. Tailored helical CT evaluation of acute abdomen. [Review]. Radiographics. May–Jun. 2000;20(3):725-49. Not AAA EVAR/open treatment trial. [pmid: 10835125].
Velazquez OC, Woo EY, Carpenter JP, et al. Decreased use of iliac extensions and reduced graft junctions with software-assisted centerline measurements in selection of endograft components for endovascular aneurysm repair. J Vasc Surg. Aug. 2004;40(2):222-7. Not AAA EVAR/open treatment trial. [pmid: 15297814].
Vogel TR, Nackman GB, Brevetti LS, et al. Resource utilization and outcomes: effect of transfer on patients with ruptured abdominal aortic aneurysms. Ann Vasc Surg. Mar. 2005;19(2):149-53. Not AAA EVAR/open treatment trial. [pmid: 15770369].
Wanhainen A, Lundkvist J, Bergqvist D, et al. Cost-effectiveness of different screening strategies for abdominal aortic aneurysm. J Vasc Surg. May. 2005;41(5):741-51. Not AAA EVAR/open treatment trial. [pmid: 15886653].
Wieslander CK, Huang CC, Omura MC, et al. Endovascular workforce for peripheral vascular disease: current and future needs. J Vasc Surg. Jun. 2002;35(6):1218-25. Not AAA EVAR/open treatment trial. [pmid: 12042734].
Wilmink AB, Quick CR, Hubbard CS, et al. Effectiveness and cost of screening for abdominal aortic aneurysm: results of a population screening program. J Vasc Surg. Jul. 2003;38(1):72-7. Not AAA EVAR/open treatment trial. [pmid: 12844092].
Wilson KA, Lee AJ, Lee AJ, et al. The relationship between aortic wall distensibility and rupture of infrarenal abdominal aortic aneurysm. J Vasc Surg. Jan. 2003;37(1):112-7. Not AAA EVAR/open treatment trial. [pmid: 12514586].
Wolff KS, Prusa AM, Polterauer P, et al. Endografting increases total volume of AAA repairs but not at the expense of open surgery: experience in more than 1000 patients. J Endovasc Ther. Jun. 2005;12(3):274-9. Not AAA EVAR/open treatment trial. [pmid: 15943501].
Wong JC, Torella F, Haynes SL, et al. Autologous versus allogeneic transfusion in aortic surgery: a multicenter randomized clinical trial. Ann Surg. Jan. 2002;235(1):145-51. Not AAA EVAR/open treatment trial. [pmid: 11753054]. [pmcid: 1422408].
Wong JG. Appropriate abdominal aortic aneurysm screening. [comment]. Postgrad Med. Mar. 2000;107(3):21-2. Not AAA EVAR/open treatment trial.
Zierler BK, Gray DT. The principles of cost-effectiveness analysis and their application. [Review]. J Vasc Surg. Jan. 2003;37(1):226-34. Not AAA EVAR/open treatment trial. [pmid: 12514610].